# Appendix C Screening Forms

Abstract Screen (Include)

Abstract Screen (Exclude)

Article Screen (Include)

Article Screen (Exclude)