# Appendix B Detailed Search Strategies

Appendix Table B1 General search strings

| | | | Apr 2011 through Dec 2011
PubMed | ((“end of life”[tiab] OR “palliative care”[mh] OR “palliative care”[tiab] OR “hospice care”[mh] OR “hospice care”[tiab] OR “supportive care”[tiab] OR “terminally ill”[tiab] OR “terminal care”[tiab]) AND (“quality improvement”[mh] OR “quality improvement”[tiab] OR “quality assurance, health care”[mh] OR “quality assurance”[tiab] OR “continuity of patient care”[mh] OR “patient care planning”[mh] OR “patient care planning”[tiab] OR consult[tiab] OR “systematic measurement”[tiab] OR “systematic assessment”[tiab])) NOT (editorial[pt] OR comment[pt]) | 3419 | Limited to 2000-2011 | 222
PsycINFO | (End of life OR palliative care OR hospice care OR supportive care OR terminally ill OR terminal care ) AND (Quality improvement OR quality assurance OR continuity of patient care OR patient care planning OR consult OR systematic measurement) from 2000 to 2011 | 170 | | 23
CINAHL | (End of life OR palliative care OR hospice care OR supportive care OR terminally ill OR terminal care ) AND (Quality improvement OR quality assurance OR continuity of patient care OR patient care planning OR consult OR systematic measurement) from 2000 to 2011 | 1020 | | 73
Cochrane
1 | Palliative care OR Palliative care MeSH | 1592
2 | Hospice care OR Hospice care MeSH | 154
3 | Quality assurance, health care MeSH | 750
4 | Continuity of patient care MeSH | 437
5 | Patient care planning OR patient care planning MeSH | 408
6 | End of life OR supportive care OR terminally ill OR terminal care | 4532
7 | #1 OR #2 OR #6 | 5864
8 | Quality assurance OR quality assurance, health care MeSH | 988
9 | Patient care planning OR patient care planning MeSH | 1680
10 | Quality improvement OR (quality assurance, health care MeSH OR quality assurance) OR continuity of patient care MeSH OR (patient care planning OR patient care planning MeSH) OR consult OR systematic measurement OR systematic assessment | 12296
11 | #7 AND #10 | 1209
12 | #11 from 2000 to 2011 | 989 | | 71
DARE | (End of life OR palliative care OR hospice care OR supportive care OR terminally ill OR terminal care ) AND (Quality improvement OR quality assurance OR continuity of patient care OR patient care planning OR consult OR systematic measurement) from 2000 to 2011 | 42919420530 | | 0

Appendix Table B2 Cancer management and pain search strings

| | | | Apr 2011 through Dec 2011
PubMed | ((Cancer[tiab] AND care[tiab]) AND (communication[mh] OR communication[tiab] OR psychosocial[tiab] OR distress[tiab] OR (pain[tiab] AND management[tiab]))) NOT (editorial[pt] OR comment[pt]) | 4536 | Limited to 2000-2011 | 623
PsycInfo | (Cancer AND Care) AND Communication OR psychosocial OR distress OR (Pain AND management) from 2000 to 2011 | 1059 | | 186
CINAHL
1 | Cancer AND care | 83460
2 | Communication OR psychosocial OR distress | 234643
3 | Pain AND management | 51896
4 | S2 OR S3 | 279667
5 | S1 AND S4 | 18212
6 | S1 AND S4 from 2000 to 2011 | 2251 | | 402
Cochrane
1 | Cancer AND care | 4880
2 | Communication MeSH | 1002
3 | (Cancer AND care) AND (Communication) | 63
4 | Communication | 4739
5 | (Cancer AND care) AND (Communication MeSH OR Communication tiab) | 182
6 | Psychosocial OR distress | 8672
7 | Pain MeSH | 8539
8 | Pain | 51077
9 | Management | 29126
10 | (Cancer AND care) AND (Communication MeSH OR Communication tiab OR psychosocial OR distress OR ((pain MeSH OR pain tiab) AND management)) | 601
11 | (Cancer AND care) AND (Communication MeSH OR Communication tiab OR psychosocial OR distress OR ((pain MeSH OR pain tiab) AND management)) from 2000 to 2011 | 454 | | 330
DARE | Cancer AND care AND (communication OR psychosocial OR distress OR (pain AND management)) from 2000-2011 | 1891076121 | | 3

Appendix Table B.3 Nursing home and care planning pain search strings

| | | | Apr 2011 through Dec 2011
PubMed | (“nursing homes”[mh] OR “nursing homes”[tiab] OR “nursing home”[tiab]) AND (“patient care planning”[mh] OR “patient care planning”[tiab] OR (pain[tiab] AND management[tiab])) NOT (editorial[pt] OR comment[pt]) | 653 | Limited to 2000-2011 | 41
PsycINFO | (Nursing homes OR nursing home) AND patient care planning OR (pain and management) from 2000-2011 | 149 | | 0
CINAHL | (Nursing homes OR nursing home) AND patient care planning OR (pain and management) from 2000-2011 | 520 | | 0
Cochrane
1 | Nursing homes MeSH | 855
2 | Patient care planning MeSH | 408
3 | Nursing homes OR nursing home OR nursing homes MeSH | 3070
4 | Patient care planning OR patient care planning MeSH | 1680
5 | Pain and management | 4507
6 | #3 AND (#4 OR #5) | 172 | | 1
DARE | (Nursing homes OR nursing home) AND patient care planning OR (pain and management) from 2000-2011 | 100757234986 | | 0