# Appendix A Acronyms

Acronym: Definition
RCT: Randomized Controlled Trial
QOL: Quality of Life
KQ: Key Question
BPI: Brief Pain Inventory
POLST: Physicians Orders for Life Sustaining Treatment
EPC: Evidence-based Practice Center
COPD: Chronic Obstructive Pulmonary Disease
ROB: Risk of Bias
AHRQ: Agency for Healthcare Research and Quality
CQG: Closing The Quality Gap