# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Eric Vohr and Nancy Hutton, M.D.