# Results

## Search Results

A total of 10,189 articles were identified with the search algorithms for Key Question 1 (KQ1) (Figure 5). Of these, 241 articles were pulled for full-text review and 15 were included in this review. For KQs 2 and 3, a total of 5,324 care coordination articles were identified, of which 43 were included.

Figure 5 Article flowchart

Abbreviation: KQ = Key Question

Figure 5 is a flow diagram depicting the number of articles generated in the initial search and their travel through the screening process to final disposition for included or excluded status.

## KQ1a What general population outcomes have been validated on and/or adjusted to accommodate disabled populations?

The literature search identified a few major initiatives in development and assessments of outcomes and a number of individual studies. Without specific outcome measurement terms (such as the SF-36) or disease or disability conditions (such as spinal cord injury) to focus on, the search process was not sensitive or specific enough to qualify the search as exhaustive. At best, the search results can be considered a sample. However, they are indicative of early stages of outcome research development in fields that are undergoing considerable updating with the advent of the ICF.

In general, there are few direct examples of work from the perspective of disability as a complicating condition. The majority of the presented outcomes efforts generally stem from the perspective of disability as the main condition of concern. We identified no articles that evaluated measures for the express purpose of care coordination or quality improvement. The outcome measures do not break down cleanly into disability etiologies, categories, or age groups.

Fifteen articles were included for KQ1a. Six articles critically reviewed available outcome measures for given populations and domains. Of these, five were part of a series of papers published in 2000 that used formal criteria to examine the state of outcomes research measurement in rehabilitation. Three studies evaluated the adaptation of general population measures for use in disability populations. Two studies were examples of disability-related outcome measures evaluated for expansion into another disability population (which suggests the possibility that the outcome measure may become more generic). Four articles reported the development of new measures. Table 4 gives a list of outcomes by article and ICF domain.

Table 4 Outcome measure list

Study Domain | Outcome Measure List
Critical evaluations of available outcome measures for given populations and outcome domains
Resnik, 2009^58^ Participation (9 ICF activities and participation domain chapters: Learning and applying knowledge; General tasks and demands; Communication; Mobility; Self-care; Domestic life; Interpersonal interactions and relationships; Major life areas; Community, social, and civic life) | Community Living Skills Scale (CLSS) (all 9 ICF chapters)59 Mayo Portland Adaptability Index (MPAI) version 4 (all 9 ICF chapters)60,61 Participation Measure for post acute care (all 9 ICF chapters)62 Psychosocial Adjustment to Illness Scale (PAIS-SR) (all 9 ICF chapters)63 LIFE-H shortened V.3.1 (all 9 ICF chapters)64 Other outcome measures examined that did not map to all 9 chapters: Adelaide Activities Profile (AAP)65 Bybee Self Report Community Functioning Scale66 Craig Handicap Assessment Technique (CHART)67 Craig Handicap Assessment Technique Short Form (CHART-SF)67 Community Integration Questionnaire (CIQ)68 Community Integration Measure (CIM)69 Nottingham Extended Activities of Daily Living (EADL)70 Frenchay Activities Index (FAI)71 Frontal Systems Behavioral Scale (FrSBe)72 Functional Status Questionnaire (FSQ)73 Groningen Social Disabilities Schedule (GSDS-II)74 Groningen Questionnaire About Social Behaviors74 Impact on Participation and Autonomy Questionnaire (IPAQ)75 ICF Checklist76 The Life Functioning Questionnaire (LFQ)77 London Handicap Scale (LHS)78 Multinomah Community Ability Scale: Self Report (MCAS-SR)79 Post-Traumatic Stress Disorder (PTSD) Checklist Military80 Participation Objective Participation Subjective (POPS)81 Participation Survey/Mobility (PARTS/M)82 Perceived Impact of Problem Profile (PIPP)83 Quality of Life Scale (QOLS)84 Rivermead Head Injury Follow-up Questionnaire (RHFUQ)85 Reintegration to Normal Living Index (RNLI)86 Reintegration to Normal Living Index – Postal Version (RNLI-P)86 Social Functioning Questionnaire (SFQ)87 Social Functioning Scale (SFS)88 Sydney Psychosocial Reintegration Scale (SPRS)89 Subjective Index of Physical and Social Outcome (SIPSO)90 Work and Social Adjustment Scale (WSAS)91 World Health Organization Disability Assessment Schedule (WHODAS) 12 item self-report92 World Health Organization Disability Assessment Schedule (WHODAS) 36 item self-report92
Vahle, 2000^93^ Depression Symptoms | Brief Symptom Inventory (BSI) (tested in 4 disability groups)94 Center for Epidemiologic Studies Depression Scale (CES-D) (tested in 2 disability groups)95 Zung Self-Rating Depression Scale (SDS)96 Beck Depression Inventory (BDI)97 Depression Adjective Check List (DACL)98 Talbieh Brief Distress Inventory and Medical-based Emotional Distress Scale (TBDI)99 Sickness Impact Profile (SIP)100 Medical Outcomes Study Short-Form Health Survey (SF-36)101
Andresen, 2000^102^ Generic HRQoL (mixed ICF domains) | SF-36 (examples included testing in 15 disability groups)103 SIP (examples included testing in 9 disability groups)104 Quality of Well-being Scale (QWB) (examples included testing in 8 disability groups)105 Nottingham Health Profile106 World Health Organization Quality of Life Survey (WHOQOL-100)107 QWB (preference based - QALY)105 Health Utility Index (preference based – QALY)108 EuroQual EQ-5D (preference based – QALY)109
Lollar, 2000^110^ Children’s Outcomes (assessed by ICF level) | Rand Health Status Measure for Children (HSMC) – Person, Society levels111 Functional Status II-R (FS II-R) – Person level112 Functional Independence Measure for Children (WeeFIM) – Body, Person levels113 Pediatric Evaluation of Disability Inventory (PEDI) – Person, Society, Environmental levels114 School Function Assessment (SFA) – Person, Society, Environmental levels115 Child Health and Illness Profile – Adolescent Edition (CHIP-AE) – Person, Society levels116 Child Health Questionnaire (CHQ) – Person, Society levels117 Questionnaire for Identifying Children with Chronic Conditions (QUICCC) - Person, Society, Environmental levels118 POSNA Pediatric Musculoskeletal Functional Health Questionnaire (POSNA) – Body, Person level119 ABILITIES Index – Body, Person level120 Gross Motor Function Measure (GMFM) – Person level121 Youth Quality of Life Instrument – Research Version (YQOL-S) - Person, Society, Environmental levels122 Quality of Well-Being Scale (QWB) (measure may not be appropriate for children younger than 14) – Body, Person levels123
Dijkers, 2000^124^ Social Outcomes (Participation) | CHART long form (broad ICF coverage)125 CHART short form (broad ICF coverage)126 CIQ (broad ICF coverage)127 Assessment of Life Habits (LIFE-H) (broad ICF coverage)128 LHS (broad ICF coverage)129 Other outcome measures examined deemed to lack broad ICF coverage:; - FAI130; - WHOQOL131; - SF-36^132^; - RNLI133; - GSDS-II134; - Social Adjustment Scale Self-Report (SAS-SR)135; - Katz Patient Adjustment Scale R2^135^; - AAP136; - EADL129
Cohen, 2000^137^ Functional Status | Katz ADLs Index138 Barthel Index139 Level of Rehabilitation Scale (LORS)140 Patient Evaluation and Conference System (PECS)141 Functional Independence Measure (FIM)142
Single studies evaluating general population measures for use in disability populations
Kalpakjian, 2005)143 Body function | Menopause Symptom List (MSL)144
Burggraaff, 2010^145^ Body function | Radner Reading Charts (RRC)146
Nanda, 2003^147^ Health status – multiple domains | Abbreviated Sickness Impact Profile (SIP68)148
Disability-related outcomes evaluated for expansion into another disability population
Bossaert, 2009^149^ Environmental | Supports Intensity Scale150
Bagley, 2010^151^ Activity and performance | Activities Scale ASKp38^152^
New measures
Faull, 2007^153^ Multiple domains | QE Health Scale Holistic Health Measure
Alderman, 2011^154^ Multiple domains | St. Andrew’s-Swansea Neurobehavioral Outcome Scale
Petry, 2009^155^ Multiple domains | QoL – Profound Multiple Disabilities
King, 2007^156^ | Children’s Assessment of Participation and Enjoyment (CAPE)

Note: More detail on articles is provided in Tables 5, 8–10.

The discussion of the material included in KQ1a is given in several segments. First, we present literature that critically reviewed available outcomes for given populations and domains. Next, we present single studies evaluating general population measures for disability populations. We follow that with some examples of disability-related outcomes that were being evaluated for expansion into another disability population, which would suggest the possibility that the outcome measure may become more generic.

### Articles That Critically Evaluated Multiple Outcome Measures

Six articles used formal criteria to assess multiple outcome measures for particular populations or broad outcome domains (See Table 5). Five articles are drawn from a series of papers published in 2000 from the Conference on the Science of Disability Outcome Research sponsored by the Center for Disease Control in 2000.^93,102,110,124,137^ The body of work documented a conceptual approach and provided criteria for evaluating the state of the science of rehabilitation outcomes research. The series evaluated outcome measures commonly used in rehabilitation research. Each paper focuses on a different category mapped to the ICF, which was known as the ICIDH at that time. The papers provide a considerable amount of detail on the psychometrics and appropriateness of the examined outcome measures. The majority of the measures were for adults or older adults across a spectrum of ICF domains. All the measures were generic, rather than condition-specific. One article addressed measurement issues for children with disabilities, noting that the environmental factors are crucial to children because of their dependence on family or other caregivers.110 The importance of a life-course perspective is also heightened because children’s’ development process is pronounced and involves a larger array of domains, including behavioral, psychological, and social development.

Table 5 Articles with critical assessments of outcome measures

Article | Domain | # of Measures Screened | # of Measures Evaluated | Criteria | Comments
Vahle, 2000^93^ | General Depression | 7 | 2 | Measurement characteristics; developmental testing of, and research using, measures | 2 measures fully evaluated. Overlap of depression symptoms and physical impairments requires careful assessment of the tool.
Andresen, 2000^102^ | General Generic HRQoL | 8 | 3 | Measurement characteristics; developmental testing of, and research using, measures | 3 measures fully evaluated. Despite relatively large research base, all require appropriate psychometric evaluation for specific populations. All 3 mingle impairment, function, and participation ICF domains.
Lollar, 2000^110^ | Children 3 ICF levels, Environmental | 13 | 13 | Measurement characteristics; developmental testing of, and research using, measures | Children themselves are often not a part of the assessment process. Minimal measures for environmental issues.
Dijkers, 2000^124^ | Social Outcomes (adults) | 16 | 5 | Measurement characteristics; developmental testing of, and research using, measures | Outcomes include social adjustment, community integration, independent living, participation. Outcomes mapped to 9 ICF chapters.
Cohen, 2000^137^ | Generic Functional Status | 5 | 5 | Measurement characteristics; developmental testing of, and research using, measures | All measures need to be evaluated for appropriateness for the population. Barthel may have floor/ceiling effects, Katz using interview mode is not tested. Authors suggest FIM is least biased and highest in reliability, validity, and responsiveness, but ceiling effects for outpatients.
Resnik, 2009^58^ | Participation | 40 | 34 | Comprehensiveness – linked to all 9 ICF chapters | 5 measures were comprehensive, but differed in specifics of coverage and approach.

Note: See Table 4 for more detail on specific measures screened and evaluated.

The series of papers focused on disability as a primary condition, not a complicating condition. However, it was noted that while functional measures have often been used for program quality assessment, there is not adequate research to support the validity of the measures for such use.137 Models for case-mix adjustment are also lacking.137

A later paper examined a much larger set of outcomes measures for participation,58 compared to the paper published in 2000, where the term social outcomes was used.124 Both papers determined that five outcome measures comprehensively mapped to all nine chapters of the ICF. However, across the two sets of five there was only one overlapping measure, the Life-H.

While the article was not included in this review because it did not address a generic measure, Mortenson and colleagues157 used the criteria established for the series on disability outcomes research35 to assess wheelchair specific activity and participation outcome measures. The study provided a similar report card for six outcome measures.

A rehabilitation outcome database was developed through a collaboration between the Rehabilitation Institute of Chicago’s Center for Rehabilitation Outcomes Research and Northwestern University Feinberg School of Medicine’s Medical Social Sciences Informatics, and funded by the National Institute on Disability and Rehabilitation Research (www.rehabmeasures.org). The database was originally populated with measures for stroke and spinal cord injury patients. Traumatic brain injury outcome measures are currently being added. The database includes a range of generic general population measures to specific measures of body function and activity. ICF domains, but not specifics, are noted. Table 6 provides a selection of outcome measures from the database.

Table 6 Select measures from the rehabilitation outcome database^a^

Outcome Measure (acronym, title) | Purpose | Area of Assessment | ICF Domain/Domain | Assessment Type | Diagnosis/Populations Tested | Age Range | Psychometrics SEM, MDC, MCID, Cutoff Score, Normative Data | Notes
CHART Craig Handicap Assessment and Reporting Technique | Based on ICIDH to measure 6 domains. Assess how people function as active members of community | ADL; Behavior; Cognition; Coordination; Functional Mobility; Occupational Performance; Social Relationship; Social Support | Participation ADL | Patient reported | SPI, Stroke, TBI, | Adult, Elderly adult | Not established, Not established, Not established, NA, Yes | Ceiling effects for SCI; proxy rate more disabled. Most discrepancy for social integration
ABC Activities-Specific Balance Confidence Scale | measure confidence performing activities without falling | Balance, vestibular and non-vestibular; Functional Mobility | Activity Motor, ADL | Patient reported | MS, Stroke, Parkinsons, Vestibular disorders | 18–65+ | Yes (some), Yes (some), Not established, Yes, Yes | Possible ceiling effect above 80 score.
BI Barthel Index | Assess self-care ability; 10 ADL/mobility activities | ADL, Functional Mobility; Gait | Activity Motor, ADL | Performance | ABI, geriatrics, stroke | 18–65+ | Yes stroke, Yes stroke, Not established, Not established, Yes
BDI-II Beck Depression Inventory | Quantifies depression severity | Depression | Body Function Emotion | Patient reported | Medical patients | 13–64 | Not established, Not established, Not established, Yes, Yes | Floor/ceiling not established. Self-report may be susceptible to context. Not tested for proxy. May yield high false positive rate in stroke patients.
COPM Canadian Occupational Performance Measure | Assess perceived performance in self-care, productivity, and leisure | ADL, Functional Mobility; Life Participation; Occupational Performance | Participation ADL, Motor, General Health | patient reported outcomes | Designed for all populations | 6–65+ | Not established, Not established, Not established, Not established, Not established | Change of 2 points clinically significant. Interview process not standardized.
CES-D Center for Epidemiological Studies Depression Scale | Brief self-report on current depression symptoms | Depression | Activity Emotion | patient reported outcomes | General population, tested on multiple patient populations and ethnic context | 13–65+ | Not established, Not established, Not established, Yes, Yes | No indication of floor/ceiling. 6 and 4 item versions available.
CIQ-II Community Integration Questionnaire II | Assess social role limitations and community interaction | ADL, Life Participation | Participation | patient reported outcomes | 23 conditions/populations. Developmental, traumatic and disease-acquired, and aging | 18–64 | Not established, Not established, Not established, Not established, Yes | Some floor/ceiling effects may be present in sub-scales. Differences based on age, gender, education may be present.

a http://www.rehabmeasures.org/default.aspx.

Specific disabling conditions are outside the scope of this review. However, an effort worth noting is underway to use the ICF framework to establish core sets for patients with specific chronic conditions. The process used may be informative to disability researchers as another example of a consensus process using formal criteria. Both comprehensive and brief sets for specific populations are being developed through a formal decisionmaking and consensus process that uses evidence and expert opinion.158,159 After the preparatory phase and the establishment of international consensus, the core sets will be tested and validated. Core sets are based on the ICF Checklist, a tool developed by WHO to generate patient profiles. Samples of patients of a particular population complete the checklist and frequency of responses is used to identify the most common problems for that population.160 The core sets are intended to recommend data points for robust clinical records and to assist in outcome measure development. Core sets have been reported on for ankylosing spondilitis,161 breast cancer,162 depression,163 osteoporosis,164 chronic ischemic heart disease,165 low back pain,159 chronic widespread pain,166 osteoarthritis,167 stroke,168 geriatric patients in early post-acute care rehabilitation,169 obstructive pulmonary disease,170 obesity,171 diabetes,172 and rheumatoid arthritis.173 Similar efforts (though not necessarily specifically aimed at disabled populations) to establish common data elements to standardize data collection and comparability across studies have been underway in multiple federal agencies, such as the NIH, Veterans Administration, and Department of Defense’s174 collaboration on research in psychology and traumatic brain injury.

Another relevant example of consensus development is found in the work of Hillier and colleagues.175 A compendium of rehabilitation outcome measures for community settings was developed through a participatory process to address fragmented outcome measurement use. With the ICF as the conceptual framework, a preliminary set of approximately 300 outcome measures were examined for acceptable criteria, including psychometric properties. Consultation between the project’s steering committee and stakeholders, including clinicians, researchers, and managers/policymakers, eventually led to a revised set of 28 outcome measures covering all ICF domains. The compendium is reproduced in Table 7.

Table 7 Example of a compendium

ICF Domain | Outcome Measure
QoL | WHQoL-BREF176
Activity | Frenchay Activities Measure)71,130
Environmental factors | Home and Community Environment Instrument (HACE)177
Body structure function:
Cognitive | Rivermead Behavioral Memory Test178
Psychological | Short Orientation-Memory-Concentration Test179
Neuromuscular | Geriatric Depression Scale180 Manual Muscle Testing181 Tardieu Scale182 Wolf Motor Function Test183 Grip Strength184
Activities
Balance & falls | Step Test185 Activities specific Balance Confidence Scale186 Postural Assessment Scale for Stroke187
Mobility/gait | Timed Up and Go Test188 Motor Assessment Scale (mod)189 Six minute walk test190
Upper limb | Chedoke Arm & Hand Activity Inventory191 Hand Active Sensation Test192 Nine Hole Peg Test193
Communication & Swallowing | Frenchay Dysarthria Assessment194 Western Aphasia Battery195 Voice Handicap Index196 RBH Outcome Measure for Swallowing197
Personal factors
Coping | Coping Strategy Indicator198
Behavior and affect | Neuropsychology Behavior and Affect Profile in Stroke Patient199
Activity and/or participation
Goals | Canadian Occupational Performance Measure200 Goal Attainment201
HRQoL | Assessment of QoL202

Note: Hillier S, Comans T, Sutton M, et al. Development of a participatory process to address fragmented application of outcome measurement for rehabilitation in community settings. Disability & Rehabilitation 2010; 32(6):511–20.^175^

### General Population Outcomes Assessed for Disability by a Single Study

Three articles assessed single general population standardized tools for specific disabled populations. All were for acquired disabilities; polio-surviving women of menopausal age,143 elderly patients with low vision,145 and a mixed adult population with generally disease-acquired, or aging into disability147 (Table 8).

Table 8 General population outcome measures assessed for disabled populations—single studies

Outcome (acronym, title) | Purpose | ICF Domain | Assessment Type | Populations Tested Age Range | Comments
MSL Menopause Symptom List (Kalpakjian, 2005)143 U.S. | Assess symptoms related to menopause | NA (body function) | Patient reported | Polio Acquired - disease 40–65 | Factor analysis suggests underlying factor structure differs for women with disabilities. Possible ceiling effect for sleep disturbance. Post-polio sequelae may obscure classic menopause symptoms.
RRC Radner Reading Charts (Burggraaff, 2010)145 Netherlands | Measure reading performance | body function | Observer | Low-vision (Glaucoma, Maculopathy, Cataract, Diabetic retinopathy, Corneal disorders) Aging Mean 80.5 | Fluctuating results leads to moderate reproducibility; best to create optimal reading conditions. High reliability.
SIP68 Abbreviated Sickness Impact Profile (Nanda, 2003)147 U.S. | Generic health status | Mixed | Patient reported | Multiple conditions Acquired – disease/Aging Mean 53.8 | Authors conclude the instrument is promising but requires more research

The literature also provided some examples of outcomes measures created for disability populations. These were either extended to encompass more disability conditions (Table 9), or altogether new outcome measures for a disability population (Table 10).

Table 9 Disability-specific outcome measures assessed for extended disabled populations—single studies

Outcome (acronym, title) | Purpose | Factors | Assessment Type | Populations Tested Age Range | Comments
SIS Supports Intensity Scale (Bossaert, 2009)149 Netherlands | Assess support needs of people with disabilities | Personal and social skills; Community living activities, Activities of daily life, Work | Patient reported | ID/DD, extended to mixed 20–86 years | Factor analysis confirmed 5, rather than 6 factors and a shortened version, SIS-NID.
ASKp38 Activities Scale for Kids – performance (Bagley, 2010)151 US | Assess frequency of performance of childhood activities | Activities of daily life, play | Patient reported | Extended to DD/trauma 6–20 years | Factor analysis confirmed 2, rather than 1 factor.

Table 10 Examples of new outcome measures—single studies

Outcome (acronym, title) | Purpose | Factors | Assessment Type | Populations Tested Age Range | Comments
QEHS QE Health Scale (Faull, 2007)153 New Zealand | Holistic health measure, includes spirituality | One principle component | Patient reported | Physical disabilities Mean 58.33 | 28 items Clinically valid, with satisfactory reliability and validity
SASNOS (Alderman, 2011)154 UK | Assess neurobehavioral disability | Interpersonal behavior; Cognition; Aggression; Inhibition; Communication | Observer | Acquired brain injury Mean 34 | 49 items Discriminant/diagnostic validity excellent, good reliability
QOL-PMD QOL Profound Multiple Disabilities (Petry, 2009)155 Netherlands | Assess quality of life for people with profound multiple disabilities | Physical well-being, Material well-being, Communication & influence, Social well-being, Development, Activities, Total score | “Informants” | Mixed 5–57 years | Medical condition most strongly correlated with scores. Setting and staffing level had significant effect on scores.
CAPE Children’s Assessment of Participation and Enjoyment (King, 2007)156 | Measures participation in recreation and leisure activities | Recreation, Active physical, social, skill based, and self-improvement activity. | Interviewer | Children (6–18 years) with and without physical disabilities | Companion measure is Preferences for Activities of Children (PAC)

## KQ1b What types of modifiers or case-mix adjusters have been used with the general population outcomes to recognize the special circumstances of people with disabilities?

We found no eligible studies of basic medical needs and secondary conditions that examined a mixed population of disabled and nondisabled participants.

One systematic review was tangentially related. This review on the effect of exercise interventions as a preventive measure on subjective quality of life for both clinical and healthy conditions.203 None of the 56 included studies used a mixed population. Studies were examined by intervention purpose: prevention/health promotion, rehabilitation, and disease management. Patients engaged in exercise for rehabilitation from a health event included cancer, CVD, musculoskeletal, neurological, pulmonary, and renal diseases. Patients engaged for chronic disease management included the same disease set plus rheumatoid arthritis and fibromyalgia. While disease severity was collected (mild, moderate, severe, chronic stable, frail, end stage), the review did not use the variable in the analysis. Quality of life measures included FACT, SF-36, HRQoL visual analog, SIP, WHOQOL, POMS, QWB, EuroQoL EQ-5D, among others.

Another tangentially related study addressed associations between the presence of chronic medical needs (chronic diagnoses) and perceived lack of accessibility features in the home according to ADL and IADL stage in a mixed population of disabled and nondisabled elderly people living in the community.204,205 These ICF-based stages define five strata for ADL and IADL (measuring the self care and domestic life chapters). Stage 0 includes people without disabilities and stages I, II, III, and IV represent increasing disability.

## KQ1c What are key parameters for measuring processes related to basic service care access for people with disabilities?

We did not find any eligible studies of basic medical needs and secondary conditions to address this question. It is possible that the specific literature scope limits, particularly limited to an illustrative set of medical service needs, rather than broader medical coverage, reduced our ability to locate such literature. (See KQs 2 and 3 for more results on care coordination process measures.)

## KQs 2 and 3 What measures have been used to assess effectiveness of care for people with disabilities living in the community in the context of coordination among health providers, or between community organizations and health providers?

Of the 45 included articles, representing 44 studies, 7 were RCTs, 9 were prospective observational designs, 3 were retrospective observational designs, 12 were before/after studies, 6 were systematic reviews/guideline studies, and 7 used survey methodology. (Table 11) A detailed list of care coordination articles is shown in Appendix B.

Table 11 Number of studies by target group and age category

Target Group | Children (0–18) | Youth in Transition^*^ | Adults (18–65) | Elderly (65+) | Mixed | Grand Total
Children – developmental | 2 | | | | | 2
Children - acquired | 2 | | | | | 2
Children - mixed | 16 | 1 | | | | 17
Chronic elderly | | | | 5 | 4 | 9
Frail elderly | | | | 7 | | 7
Immobile + transition from inpatient | | | | | 1 | 1
Medicaid + Disabled | | | 3 | | 2 | 5
Medicare + Disabled + Heavy users | | | | 1 | | 1
Grand Total | 20 | 1 | 3 | 13 | 7 | 44

* Youth in Transition means youth who are being prepared to transition from youth to adult services.

Of the 44 included articles, 34 addressed interventions which included elements of both coordination among providers and coordination between providers and families or social services. This makes it difficult to address KQs 2 and 3 separately. The discussion below is organized into three sections: interventions mainly focused on coordination among providers, interventions mainly focused on coordination between providers and families or social services, and interventions that included elements of both.

### Coordination Among Providers

Two studies of the effects of coordination focused on programs primarily coordinating among providers.206,207 One of these programs was a coordinated followup of infants with prenatally diagnosed giant omphaloceles;206 the other was the PACE program targeting frail, chronically ill older adults with the goal of keeping them in the community as long as possible.207

Danzer et al. used the Bayley Scales of Infant Development, which measures neurodevelopment in infants as their primary outcome measure.206 The very small sample size (n=31) and homogeneity of their sample meant that no outcomes were presented by independent variables (e.g., severity of omphalocele—all children studied had the worst category—giant omphalocele).

Temkin-Greener, et al. used change in functional status as their outcome measure; this was operationalized as a change in the number of ADL dependencies found during periodic assessments (at least every 6 months for 3 years).207 This outcome was not reported by any person-level variables, although characteristics such as disease state (a series of binary variables indicating the presence of diseases including arthritis, CHF, dementia, COPD, renal failure, etc.), lagged number of IADLs, bladder and bowel incontinence, and impairment in vision, hearing, communication, or cognition were included in the regressions to “risk adjust” the coefficient estimates.

This study also measured several health care use “outcomes” that were not used as outcomes per se. In addition to the primary outcome variable of functional status, several measures of service use were also modeled, including short-term nursing home stays, hospitalizations, day center attendance, etc. The propensity of each of the studied sites to provide those services was then used to model change in functional status for the key analysis of the study.

### Coordination Between Providers and Family/Social

Nine studies focused on programs primarily concerned with coordination between providers and families, caregivers, social services, etc.208–216 Of these, seven served children or young adults (under age 21), one served stroke survivors,209 and one served frail older adults.211

Of the child-focused studies, three focused on children or young adults with physical disabilities (one of these was a systematic review).214–216 and two looked at interventions for children with traumatic brain injury.210,213 One study addressed the broad category of children with special healthcare needs.212 One study was focused quite narrowly on children with dysfunctional elimination syndrome.208

#### Outcomes

The studies of children with TBI focused on functional outcomes related to the children’s behavior (Table 12). Several scales were used: The Neurodevelopmental Inventory, Behavior Rating Inventory of Executive Functions (BRIEF), Behavior Assessment System for Children (BASC), Eyberg Child Behavior Inventory (ECBI). The systematic review of early interventions for children with physical disabilities also reported assessments of behavior, including parent’s rating of the child’s interactions with preschool peers and a structured questionnaire on peer acceptance.

Table 12 Number of measures (articles) by age category for care coordination between provider and family/social

Measure Type | Children | Elderly | Mix | Grand Total
Access | 1 (1) | | | 1 (1)
Caregiver | 2 (1) | | | 2 (1)
Cost and Use | | 1 (1) | | 1 (1)
Goals | 5 (3) | | | 5 (3)
Health and Function | 9 (4) | 4 (1) | 2 (1) | 15 (6)
Process | 7 (5) | | 2 (1) | 9 (6)
Satisfaction | 4 (3) | | | 4 (3)
Grand Total | 28 | 5 | 4 | 37

Some children’s studies reported goal development and attainment as outcomes of the intervention.214–216

#### Process Measures

Perhaps because care coordination programs are largely still quite new, the literature focused primarily on the initial implementation of interventions rather than the assessment of the quality of the implementation. That is, no measures were found that assessed changes in process measures of quality over time.

Process measures were sometimes included as proxy outcomes. Participant adherence to treatment,209 frequency of contacts with physicians,212 school adherence to child’s treatment plan,208 and the Measure of Processes of Care scale (MPOC)216 are examples of these process measures.

The two studies of adults/elderly people used standard clinical scales to assess health and health-related QOL: SF-36, Geriatric Depression Scale, APACHE III, SF-8, OASIS. This kind of scale was not generally used in the studies of interventions for children. The study of children with DES did, however, use a standard clinical measure for incontinence: number of wet days per month.208

### Coordination Among Providers and Between Providers and Family/Social Services

Of the 34 articles that addressed both types of care coordination, 27 were studies, 2 were expert guidelines, 4 were literature reviews, and 1 was a description of a program.

Children represented the most frequently addressed population, with 13 articles. The elderly were addressed in 11 articles. Seven articles looked at a mix of ages (though for some of these studies the vast majority of participants were elderly). Adults (roughly ages 21 to 65) were addressed in three of the articles.

A total of 109 measurements were abstracted from these 34 articles (Table 13). A detailed list of measures used in the care coordination articles is in Appendix B. The two most frequently measured domains were cost/use (25 measures from 15 articles) and health/function (22 measures from 12 articles). Examples of frequently seen cost and use measures are number of emergency room visits, hospital length of stay, total costs of care, and frequency or number of interventions. Examples of frequently seen health and function measures include count of ADLs/IADLs, number of school absences, SF-36 or SF-8, incidence of secondary conditions, and survival without institutionalization.

Table 13 Number of measures (articles) by age category for care coordination among providers or between provider and family/social

Measure Type | Children | Youth in Transition^*^ | Adults | Elderly | Mix | Grand Total
Access | 9 (5) | | | | | 9 (5)
Provider | | | | 1 (1) | | 1 (1)
Caregiver | 8 (4) | | | 8 (5) | | 16 (9)
Cost and use | 7 (7) | | 5 (1) | 5 (4) | 11 (4) | 28 (16)
Health and function | 4 (4) | | 3 (1) | 14 (6) | 3 (2) | 24 (13)
Process | 5 (1) | | 1 (1) | 2 (2) | 1 (1) | 9 (5)
Satisfaction | 4 (1) | | 2 (1) | 7 (7) | | 13 (9)
Self-efficacy | | | | 2 (2) | | 2 (2)
Qualitative feedback | | | | | 1(1) | 1 (1)
Guideline | 6 (1) | | | | | 6 (1)
Grand Total | 43 | | 11 | 39 | 16 | 109

* Youth in Transition means youth who are being prepared to transition from youth to adult services.

Measurements of caregiver concerns were measured only in articles on children and the elderly. There were four articles each on children and the elderly that included these measures (a total of 15 measures). Examples include scales assessing caregiver burden and measures of caregiver satisfaction with care.

Only articles on children included measures of access to care (generally self-reported issues with access, but also including constructed items from the CSHCN survey creating a binary “access to medical home” measure). There were nine such measures from five studies.

Only articles on the elderly included measures of self-efficacy. Two studies measured this domain.

Thirteen articles included measures of satisfaction or experience of care. Two of these used the PACIC (Patient Assessment of Care for Chronic Conditions), and two used items from the CAHPS (consumer assessment of healthcare providers and systems) questionnaire.

Care coordination is one component of quality. Within quality improvement, an important effort to develop and report a standard set of performance measures is the National Core Indicators (NCI).217 The NCI is a collaborative effort between the National Association of State Directors of Developmental Disabilities Services (NASDDDS), the Human Services Research Institute (HSRI), and participating states (currently 28 states). The goal of the collaboration was to develop a core set of measures that states use to manage quality of developmental disability services, and to allow between-state comparisons. The NCI includes outcomes related to health, wellness, and medications, among other consumer and family outcomes and system performance outcomes. While the scope of the NCI is larger than this review covers, the full set of outcomes is reproduced in Table 14. The domains and items provide insight into how quality indicators may be conceptualized and suggest potential areas of cross-fertilization between professions and disciplines.

Table 14 National core indicators (NCI) domains and items^a^

Subdomains | Items
Community Inclusion | (in the past month, unless noted) Go shopping Go out on errands or appointments Go out for entertainment Go to religious services Go out for exercise Go on vacation (in past year)
Choice and Decisionmaking | (did you choose) The place where you live (if not family) The people you live with (if not family) The staff who help at home Your work or day activity The staff who help at work or day activity The case manager/service coordinator The daily schedule How to spend your free time What to buy with your spending money
Relationships | (proportion of people) Have friends and caring relationships with people other than support staff and family members Have a close friend, someone you can talk to about personal things Are able to see your (a) families and (b) friends whenever they want. Feel lonely Go on a date if you want to You get to help others
Satisfaction | (proportion of people) Satisfied with where you live Like to live somewhere else Satisfied with your job Have a community job but would like to work somewhere else Satisfied with your day program or other daily activity Go to a day program or activity but would like to go somewhere else or do something else during the day
Service Coordination | (proportion of people) Have met your service coordinator Your service coordinator asks you what you want Your service coordinator helps you get what you want Your service coordinator calls you back right away You helped make your service plan
Access | (proportion of people) Have adequate transportation when you want to go somewhere Use different types of transportation Get the services you need Your staff has adequate training
Health, Welfare, and Rights
Safety | (proportion of people who report) Never feel scared or afraid in their home, neighborhood, workplace, and day program/daily activity Have someone to go to for help when they feel afraid
Health | (proportion of people) Had a complete annual physical exam in past year Had a Pap test in the past 3 years (women 18+ years) Had a routine dental exam in the past year Have poor health Have a primary care doctor Had a vision screening in the past year Had a hearing test within the past 5 years Had a flu vaccination in the past year Ever had a vaccination for pneumonia Had a mammogram within the past 2 years (women 40+) Had a PSA test within the past year (Men 50+) Had a screening for colorectal cancer within the past year (50+)
Wellness | (proportion who maintain unhealthy habits) Smoking Weight Exercise
Medications | (proportion of people) Take medication for mood disorders, anxiety, behavior problems, or psychotic disorders
Respect/Rights | (proportion of people) Basic rights are not respected by others, including (a) having one’s mail opened without permission, (b) having restrictions on being alone with others, (c) having restrictions on using the phone/internet, and having people enter their (d) home and (e) bedroom without permission Have participated in a self-advocacy group meeting, conference, or event Report satisfaction with the amount of privacy Most (a) day, (b) work, and (c) home support staff treat them with respect
Self-Determination | (proportion of people self-directing) Currently using a self-directed supports option Who employ their own support workers or use “agency of choice” Someone talked with them about individual budget/services Who have help in deciding how to use the budget/services Who report they can make changes to their budget/services if they need to Who report they get enough help in deciding how to use the budget/services Who receive enough information about their budget/services that is easy to understand Whose support workers come when they are supposed to Who get the help they need to work out problems with the support workers
Work | Average bi-weekly earnings of people who have jobs in the community Average number of hours worked bi-weekly Percent earning at or above the state minimum wages Percent who were continuously employed during previous year Percent who receive vacation and/or sick time benefits Average length of time they have been working at their current job Percent who work in each type of job Proportion of people who have a goal of integrated employment in their individualized service plan Proportion who have a job in the community Proportion who do not have a job in the community but would like to have one Proportion who go to a day program or have some other daily activity Proportion who do volunteer work

a www.nationalcoreindicators.org