# References

1 Shojonia K, McDonald K, Wachter R, et al. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Volume 1 - Series overview and methodology. Technical Review 9. (Contract No. 290-02-0017 to the Stanford University - USCF Evidence-based Practices Center). Rockville, MD. AHRQ Publication No. 04-0021-1. August. 2004.
2 Board on Health Care Services, Institute of Medicine. Priority Areas for National Action: Transforming Health Care Quality. Washington, DC. The National Academies Press. 2003.
3 Iezzoni L. Developing Quality of Care Measures for People with Disabilities: Summary of Expert Meeting. Rockville, MD. Agency for Healthcare Research and Quality. 2010. http://www.ahrq.gov/populations/devqmdis. Accessed on January 2010.
4 Sofaer S, Kreling B, Carmel M. Coordination of care for persons with disabilities enrolled in medicaid managed care A conceptual framework to guide the development of measures. Baruch College School of Public Affairs: Office of Disability, Aging, and Long-Term Care Policy. Office of the Assistant Secretary for Planning and Evaluation. U.S. Department of Health and Human Services. 2000.
5 Jette AM. Toward a common language for function, disability, and health. Physical Therapy. May. 2006;86(5):726-34. [pmid: 16649895].
6 Weiner BK. Difficult medical problems: on explanatory models and a pragmatic alternative. Medical Hypotheses. 2007;68(3):474-9. [pmid: 17055182].
7 Goering S. Revisiting the relevance of the social model of disability. American Journal of Bioethics. Jan. 2010;10(1):54-5. [pmid: 20077341].
8 Kane RL, Priester R, Neumann D. Does disparity in the way disabled older adults are treated imply ageism?. Gerontologist. Jun. 2007;47(3):271-9. [pmid: 17565092].
9 Brown RS, Graham CL, Richeson N, et al. Evaluation of medical student performance on objective structured clinical exams with standardized patients with and without disabilities. Academic Medicine. Nov. 2010;85(11):1766-71. [pmid: 20881817].
10 Larson SA, Anderson L, Doljanac R. Access to Care. Nehring WM, editor. Health Promotion for Persons with Intellectual and Developmental Disabilities. Washington, DC. American Association on Mental Retardation. 2005:129-84.
11 Engel GL. The need for a new medical model: a challenge for biomedicine. Science. Apr. 8. 1977;196(4286):129-36. [pmid: 847460].
12 Adler RH. Engel’s biopsychosocial model is still relevant today. Journal of Psychosomatic Research. Dec. 2009;67(6):607-11. [pmid: 19913665].
13 Rimmer JH. Health promotion for people with disabilities: the emerging paradigm shift from disability prevention to prevention of secondary conditions. Physical Therapy. May. 1999;79(5):495-502. [pmid: 10331753].
14 National Center of Birth Defects and Developmental Disabilities. Chapter 6. Vision for the decade: proceedings and recommendations of a symposium. Healthy People 2010. Atlanta, GA. CDC. 2001.
15 Stineman MG, Streim JE. The biopsycho-ecological paradigm: a foundational theory for medicine. Pm & R. Nov. 2010;2(11):1035-45. [pmid: 21093839].
16 Stineman MG. A model of health environmental integration. Top Stroke Rehabil. Summer. 2001;8(2):34-45. [pmid: 14523744].
17 Kirschner KL, Breslin ML, Iezzoni LI, et al. Attending to inclusion: people with disabilities and health-care reform. Pm & R. Oct. 2009;1(10):957-63. [pmid: 19854424].
18 Baltes PB, Baltes MM. Psychological perspectives on successful aging: the model of selective optimization with compensation. Baltes PB, Baltes MM, editors. Successful aging: Perspectives from the behavioral sciences. New York. Cambridge University Press. 1990.
19 Jensen MP, Molton IR. Preface: aging with a physical disability. Physical Medicine & Rehabilitation Clinics of North America. May. 2010;21(2):xv-xvi. [pmid: 20494274].
20 Committee on Quality of Health Care in America. Crossing the quality chasm: a new health system for the 21st century. Washington, DC. National Academies Press. 2001.
21 Lynn J, Straube BM, Bell KM, et al. Using population segmentation to provide better health care for all: the “Bridges to Health” model. Milbank Quarterly. Jun. 2007;85(2):185-208. discussion 9–12. [pmid: 17517112].
22 Strax TE, Luciano L, Dunn AM, et al. Aging and developmental disability. Physical Medicine & Rehabilitation Clinics of North America. May. 2010;21(2):419-27. [pmid: 20494286].
23 Vita AJ, Terry RB, Hubert HB, et al. Aging, health risks, and cumulative disability. New England Journal of Medicine. Apr. 9. 1998;338(15):1035-41. [pmid: 9535669].
24 Widerstrom-Noga E, Finlayson ML. Aging with a disability: physical impairment, pain, and fatigue. Physical Medicine & Rehabilitation Clinics of North America. May. 2010;21(2):321-37. [pmid: 20494280].
25 Carter GT, Weiss MD, Chamberlain JR, et al. Aging with muscular dystrophy: pathophysiology and clinical management. Physical Medicine & Rehabilitation Clinics of North America. May. 2010;21(2):429-50. [pmid: 20494287].
26 Charlifue S, Jha A, Lammertse D. Aging with spinal cord injury. Physical Medicine & Rehabilitation Clinics of North America. May. 2010;21(2):383-402. [pmid: 20494284].
27 Stern M, Sorkin L, Milton K, et al. Aging with multiple sclerosis. Physical Medicine & Rehabilitation Clinics of North America. May. 2010;21(2):403-17. [pmid: 20494285].
28 Powers L. Health and wellness among persons with disabilities. Consortium RHaW. Changing concepts of health and disability: State of the science conference and policy forum. Portland. Oregon Health and Sciences University. 2003:73-7.
29 Lerner M. Conceptualization of health and social well-being. Health Services Research. 1973;8(1):6-12. [pmid: 4705219].
30 Stineman MG, Rist PM, Kurichi JE, et al. Disability meanings according to patients and clinicians: imagined recovery choice pathways. Quality of Life Research. Apr. 2009;18(3):389-98. [pmid: 19190999].
31 Rist PM, Freas DW, Maislin G, et al. Recovery from disablement: what functional abilities do rehabilitation professionals value the most?. Archives of Physical Medicine & Rehabilitation. Aug. 2008;89(8):1600-6. [pmid: 18597736].
32 Ware JE Jr, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Medical Care. Jun. 1992;30(6):473-83. [pmid: 1593914].
33 Brazier J, Roberts J, Deverill M. The estimation of a preference-based measure of health from the SF-36. Journal of Health Economics. Mar. 2002;21(2):271-92. [pmid: 11939242].
34 Meyers AR, Andresen EM. Enabling our instruments: accommodation, universal design, and access to participation in research. Archives of Physical Medicine & Rehabilitation. Dec. 2000;81(12 Suppl 2):S5-9. [pmid: 11128904].
35 Andresen EM. Criteria for assessing the tools of disability outcomes research. Archives of Physical Medicine & Rehabilitation. Dec. 2000;81(12 Suppl 2):S15-20. [pmid: 11128900].
36 Story MF. Maximizing usability: the principles of universal design. Assistive Technology. 1998;10(1):4-12. [pmid: 10181150].
37 Harniss M, Amtmann D, Cook D, et al. Considerations for developing interfaces for collecting patient-reported outcomes that allow the inclusion of individuals with disabilities. Medical Care. May. 2007;45(5 Suppl 1):S48-54. [pmid: 17443119].
38 Larson SA, Lakin K, LA. Definitions and findings on intellectual disabilities within the disability supplement to the National Health Interview Survey. Barnartt S, Altman BM, Hendershot G, et al., editors. Using Survey Data to Study Disability: Results from the National Health Survey on Disability. Emerald Group Publishing Limited. 2003;3:229-55.
39 Gill TM, Gahbauer EA, Han L, et al. Trajectories of disability in the last year of life. New England Journal of Medicine. Apr. 1. 2010;362(13):1173-80. [pmid: 20357280].
40 Hardy SE, Gill TM. Recovery from disability among community-dwelling older persons. JAMA. Apr. 7. 2004;291(13):1596-602. [pmid: 15069047].
41 World Health Organization. International classification of functioning, disability and health: ICF. Geneva. WHO. 2001.
42 Jette AM, Tao W, Haley SM. Blending activity and participation sub-domains of the ICF. Disability & Rehabilitation. Nov. 30. 2007;29(22):1742-50. [pmid: 17852234].
43 Jette AM, Norweg A, Haley SM. Achieving meaningful measurements of ICF concepts. Disability & Rehabilitation. 2008;30(12–13):963-9. [pmid: 18484391].
44 Verbrugge LM, Jette AM. The disablement process. Social Science & Medicine. Jan. 1994;38(1):1-14. [pmid: 8146699].
45 Committee on Disability in America. Future of disability in America. Washington, DC. National Academies Press. 2007.
46 Ustun B, Chatterji S, Kostanjsek N. Comments from WHO for the Journal of Rehabilitation Medicine Special Supplement on ICF Core Sets. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):7-8. [pmid: 15370741].
47 Cerniauskaite M, Quintas R, Boldt C, et al. Systematic literature review on ICF from 2001 to 2009: its use, implementation and operationalisation. Disability & Rehabilitation. 2011;33(4):281-309. [pmid: 21073361].
48 Colenbrander A. Assessment of functional vision and its rehabilitation. Acta Opthalmologica. Mar. 2010;88(2):163-73. [pmid: 20039847].
49 Simeonsson RJ, McDevitt L. Disability & health: The role of secondary conditions and quality of life. Chapel Hill. University of North Carolina, FPG Child Development Center. 1999.
50 Rimmer JH, Yamaki K, Lowry BMD, et al. Obesity and obesity-related secondary conditions in adolescents with intellectual/developmental disabilities. Journal of Intellectual Disability Research. Sep. 2010;54(9):787-94. [pmid: 20630017].
51 Nosek MA, Hughes RB, Petersen NJ, et al. Secondary conditions in a community-based sample of women with physical disabilities over a 1-year period. Archives of Physical Medicine & Rehabilitation. Mar. 2006;87(3):320-7. [pmid: 16500164].
52 Kinne S, Patrick DL, Doyle DL. Prevalence of secondary conditions among people with disabilities. American Journal of Public Health. Mar. 2004;94(3):443-5. [pmid: 14998811].
53 Rasch EK, Hochberg MC, Magder L, et al. Health of community-dwelling adults with mobility limitations in the United States: prevalent health conditions. Part I. Archives of Physical Medicine & Rehabilitation. Feb. 2008;89(2):210-8. [pmid: 18226643].
54 Ravesloot C, Seekins T, Walsh J. A structural analysis of secondary conditions experienced by people with physical disabilities. Rehabilitation Psychology. 1997;42(1):3-16.
55 Chan L, Shumway-Cook A, Yorkston KM, et al. Design and validation of a methodology using the International Classification of Diseases, 9th Revision, to identify secondary conditions in people with disabilities. Archives of Physical Medicine & Rehabilitation. May. 2005;86(5):1065-9. [pmid: 15895361].
56 McDonald K, Schultz E, Albin L, et al. Care Coordination Atlas, Version 3. Agency for Healthcare Research and Quality. Rockville, MD. November. 2010.
57 McDonald KM, Sundaram V, Bravata DM, et al. Care Coordination. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Rockville (MD). AHRQ. 2007;7.
58 Resnik L, Plow MA. Measuring participation as defined by the international classification of functioning, disability and health: an evaluation of existing measures. Archives of Physical Medicine & Rehabilitation. May. 2009;90(5):856-66. [pmid: 19406308].
59 Smith MK, Ford J. A client-developed functional level scale: The Community Living Skills Scale (CLSS). Journal of Social Service Research. 1990;13:61-84.
60 Malec JF, Kragness M, Evans RW, et al. Further psychometric evaluation and revision of the Mayo-Portland Adaptability Inventory in a national sample. Journal of Head Trauma Rehabilitation. Nov–Dec. 2003;18(6):479-92. [pmid: 14707878].
61 Malec JF. The Mayo-Portland Participation Index: A brief and psychometrically sound measure of brain injury outcome. Archives of Physical Medicine and Rehabilitation. Dec. 2004;85(12):1989-96. [pmid: 15605338].
62 Gandek B, Sinclair SJ, Jette AM, et al. Development and initial psychometric evaluation of the participation measure for post-acute care (PM-PAC). American Journal of Physical Medicine & Rehabilitation. Jan. 2007;86(1):57-71. [pmid: 17033591].
63 Derogatis LR. The Psychosocial Adjustment to Illness Scale (Pais). Journal of Psychosomatic Research. 1986;30(1):77-91. [pmid: 3701670].
64 Fougeyrollas P, Noreau L, Bergeron H, et al. Social consequences of long term impairments and disabilities: conceptual approach and assessment of handicap. International Journal of Rehabilitation Research. Jun. 1998;21(2):127-41. [pmid: 9924676].
65 Clark MS, Bond MJ. The Adelaide Activities Profile - a Measure of the Life-Style Activities of Elderly People. Aging-Clinical and Experimental Research. Aug. 1995;7(4):174-84.
66 Bybee D, Mowbray CT, Oyserman D, et al. Variability in community functioning of mothers with serious mental illness. Journal of Behavioral Health Services & Research. Jul–Sep. 2003;30(3):269-89. [pmid: 12875096].
67 Whiteneck GG, Charlifue SW, Gerhart KA, et al. Quantifying Handicap - a New Measure of Long-Term Rehabilitation Outcomes. Archives of Physical Medicine and Rehabilitation. Jun. 1992;73(6):519-26. [pmid: 1622299].
68 Willer B, Ottenbacher KJ, Coad ML. The Community Integration Questionnaire - a Comparative-Examination. American Journal of Physical Medicine & Rehabilitation. Apr. 1994;73(2):103-11. [pmid: 8148099].
69 McColl MA, Davies D, Carlson P, et al. The community integration measure: Development and preliminary validation. Archives of Physical Medicine and Rehabilitation. Apr. 2001;82(4):429-34. [pmid: 11295000].
70 Lincoln NB, Gladman JR. The Extended Activities of Daily Living scale: a further validation. Disability & Rehabilitation. Jan–Mar. 1992;14(1):41-3. [pmid: 1586760].
71 Wade DT, Legh-Smith J, Langton Hewer R. Social activities after stroke: measurement and natural history using the Frenchay Activities Index. Int Rehabil Med. 1985;7(4):176-81. [pmid: 4093249].
72 Grace J, Stout JC, Malloy PF. Assessing frontal lobe behavioral syndromes with the Frontal Lobe Personality Scale. Assessment. Sep. 1999;6(3):269-84. [pmid: 10445964].
73 Jette AM, Davies AR, Cleary PD, et al. The Functional Status Questionnaire - Reliability and Validity When Used in Primary Care. Journal of General Internal Medicine. May–Jun. 1986;1(3):143-9. [pmid: 3772582].
74 Wiersma D, DeJong A, Ormel J. The Groningen Social Disabilities Schedule: development, relationship with I.C.I.D.H., and psychometric properties. International Journal of Rehabilitation Research. 1988;11(3):213-24. [pmid: 2978514].
75 Cardol M, de Haan RJ, van den Bos GAM, et al. The development of a handicap assessment questionnaire: the Impact on Participation and Autonomy (IPA). Clinical Rehabilitation. Oct. 1999;13(5):411-9. [pmid: 10498348].
76 World Health Organization. The ICF Checklist Version 2.1a. Geneva. World Health Organization. 2001.
77 Altshuler L, Mintz J, Leight K. The Life Functioning Questionnaire (LFQ): a brief, gender-neutral scale assessing functional outcome. Psychiatry Research. Oct. 10. 2002;112(2):161-82. [pmid: 12429362].
78 Harwood RH, Rogers A, Dickinson E, et al. Measuring handicap: the London Handicap Scale, a new outcome measure for chronic disease. Qual Health Care. Mar. 1994;3(1):11-6. [pmid: 10171955].
79 O’Malia L, McFarland BH, Barker S, et al. A level-of-functioning self-report measure for consumers with severe mental illness. Psychiatr Serv. Mar. 2002;53(3):326-31. [pmid: 11875227].
80 Dobie DJ, Kivlahan DR, Maynard C, et al. Screening for post-traumatic stress disorder in female Veteran’s Affairs patients: validation of the PTSD checklist. Gen Hosp Psychiatry. Nov–Dec. 2002;24(6):367-74. [pmid: 12490337].
81 Brown M, Dijkers MPJM, Gordor WA, et al. Participation objective, participation subjective - A measure of participation combining outsider and insider perspectives. Journal of Head Trauma Rehabilitation. Nov–Dec. 2004;19(6):459-81. [pmid: 15602309].
82 Gray DB, Hollingsworth HH, Stark SL, et al. Participation survey/mobility: psychometric properties of a measure of participation for people with mobility impairments and limitations. Archives of Physical Medicine & Rehabilitation. Feb. 2006;87(2):189-97. [pmid: 16442971].
83 Pallant JF, Misajon R, Bennett E, et al. Measuring the impact and distress of health problems from the individual’s perspective: development of the Perceived Impact of Problem Profile (PIPP). Health Qual Life Outcomes. 2006;4:36. [pmid: 16808842].
84 Burckhardt CS, Anderson KL. The Quality of Life Scale (QOLS): reliability, validity, and utilization. Health Qual Life Outcomes. 2003;1:60. [pmid: 14613562].
85 Crawford S, Wenden FJ, Wade DT. The Rivermead head injury follow up questionnaire: a study of a new rating scale and other measures to evaluate outcome after head injury. J Neurol Neurosurg Psychiatry. May. 1996;60(5):510-4. [pmid: 8778254].
86 Stark SL, Edwards DF, Hollingsworth H, et al. Validation of the Reintegration to Normal Living Index in a population of community-dwelling people with mobility limitations. Archives of Physical Medicine & Rehabilitation. Feb. 2005;86(2):344-5. [pmid: 15706566].
87 Tyrer P, Nur U, Crawford M, et al. The Social Functioning Questionnaire: a rapid and robust measure of perceived functioning. Int J Soc Psychiatry. Sep. 2005;51(3):265-75. [pmid: 16252794].
88 Birchwood M, Smith J, Cochrane R, et al. The Social Functioning Scale. The development and validation of a new scale of social adjustment for use in family intervention programmes with schizophrenic patients. Br J Psychiatry. Dec. 1990;157:853-9. [pmid: 2289094].
89 Tate R, Hodgkinson A, Veerabangsa A, et al. Measuring psychosocial recovery after traumatic brain injury: psychometric properties of a new scale. Journal of Head Trauma Rehabilitation. Dec. 1999;14(6):543-57. [pmid: 10671700].
90 Trigg R, Wood VA. The validation of the Subjective Index of Physical and Social Outcome (SIPSO). Clinical Rehabilitation. May. 2003;17(3):283-9. [pmid: 12735535].
91 Mundt JC, Marks IM, Shear MK, et al. The Work and Social Adjustment Scale: a simple measure of impairment in functioning. Br J Psychiatry. May. 2002;180:461-4. [pmid: 11983645].
92 World Health Organization. WHODAS II Disability Assessment Schedule: training manual: a guide to administration. Geneva. World Health Organization. 2000.
93 Vahle VJ, Andresen EM, Hagglund KJ. Depression measures in outcomes research. Archives of Physical Medicine & Rehabilitation. Dec. 2000;81(12 Suppl 2):S53-62. [pmid: 11128905].
94 Derogatis LR, Melisaratos N. The Brief Symptom Inventory: an introductory report. Psychol Med. Aug. 1983;13(3):595-605. [pmid: 6622612].
95 Radloff LS. The CES-D Scale: a self-report depression scale for research in the general population. Applied Psycholical Measurement. 1977;1:385-401.
96 Zung WW. A Self-Rating Depression Scale. Arch Gen Psychiatry. Jan. 1965;12:63-70. [pmid: 14221692].
97 Beck AT, Erbaugh J, Ward CH, et al. An Inventory for Measuring Depression. Archives of General Psychiatry. 1961;4(6):561-&. [pmid: 13688369].
98 Lubin B. Adjective Checklists for Measurement of Depression. Archives of General Psychiatry. 1965;12(1):57-62. [pmid: 14221691].
99 Ritsner M, Rabinowitz J, Slyuzberg M. The Talbieh Brief Distress Inventory - a Brief Instrument to Measure Psychological Distress among Immigrants. Comprehensive Psychiatry. Nov–Dec. 1995;36(6):448-53. [pmid: 8565450].
100 Bergner M, Bobbitt RA, Carter WB, et al. The Sickness Impact Profile - Development and Final Revision of a Health-Status Measure. Medical Care. 1981;19(8):787-805. [pmid: 7278416].
101 Ware JE, Sherbourne CD. The Mos 36-Item Short-Form Health Survey (Sf-36).1. Conceptual-Framework and Item Selection. Medical Care. Jun. 1992;30(6):473-83. [pmid: 1593914].
102 Andresen EM, Meyers AR. Health-related quality of life outcomes measures. Archives of Physical Medicine & Rehabilitation. Dec. 2000;81(12 Suppl 2):S30-45. [pmid: 11128902].
103 Hays RD, Sherbourne CD, Mazel RM. The RAND 36-Item Health Survey 1.0. Health Econ. Oct. 1993;2(3):217-27. [pmid: 8275167].
104 Bergner M, Bobbitt RA, Carter WB, et al. The Sickness Impact Profile: development and final revision of a health status measure. Medical Care. Aug. 1981;19(8):787-805. [pmid: 7278416].
105 Andresen EM, Rothenberg BM, Kaplan RM. Performance of a self-administered mailed version of the Quality of Well-Being (QWB-SA) questionnaire among older adults. Medical Care. Sep. 1998;36(9):1349-60. [pmid: 9749658].
106 Hunt SM, McKenna SP, McEwen J, et al. A quantitative approach to perceived health status: a validation study. J Epidemiol Community Health. Dec. 1980;34(4):281-6. [pmid: 7241028].
107 Skevington SM, Bradshaw J, Saxena S. Selecting national items for the WHOQOL: conceptual and psychometric considerations. Social Science & Medicine. Feb. 1999;48(4):473-87. [pmid: 10075173].
108 Feeny D, Furlong W, Boyle M, et al. Multi-attribute health status classification systems. Health Utilities Index Pharmacoeconomics. Jun. 1995;7(6):490-502. [pmid: 10155335].
109 Jenkinson C, Stradling J, Petersen S. Comparison of three measures of quality of life outcome in the evaluation of continuous positive airways pressure therapy for sleep apnoea. J Sleep Res. Sep. 1997;6(3):199-204. [pmid: 9358398].
110 Lollar DJ, Simeonsson RJ, Nanda U. Measures of outcomes for children and youth. Archives of Physical Medicine & Rehabilitation. Dec. 2000;81(12 Suppl 2):S46-52. [pmid: 11128903].
111 Eisen M, Ware JE Jr, Donald CA, et al. Measuring components of children’s health status. Medical Care. Sep. 1979;17(9):902-21. [pmid: 480998].
112 Stein RE, Jessop DJ. Functional status II(R). A measure of child health status. Medical Care. Nov. 1990;28(11):1041-55. [pmid: 2250491].
113 Msall ME, DiGaudio K, Duffy LC, et al. WeeFIM. Normative sample of an instrument for tracking functional independence in children. Clin Pediatr (Phila). Jul. 1994;33(7):431-8. [pmid: 7955782].
114 Haley S, Coster W, Faas R. A content validity study of the Pediatric Evaluation of Disability Inventory. Pediatric Physical Therapy. 1991;3:177-84.
115 Coster WJ, Mancini MC, Ludlow LH. Factor structure of the School Function Assessment. Educational and Psychological Measurement. Aug. 1999;59(4):665-77.
116 Starfield B, Bergner M, Ensminger M, et al. Adolescent health status measurement: development of the Child Health and Illness Profile. Pediatrics. Feb. 1993;91(2):430-5. [pmid: 8424023].
117 Landgraf JM, Abetz L, Ware JE. Child health questionnaire (CHQ): a user’s manual. Boston. The Health Institute, New England Medical Center. 1996.
118 Stein RE, Westbrook LE, Bauman LJ. The Questionnaire for Identifying Children with Chronic Conditions: a measure based on a noncategorical approach. Pediatrics. Apr. 1997;99(4):513-21. [pmid: 9093290].
119 Daltroy LH, Liang MH, Fossel AH, et al. The POSNA pediatric musculoskeletal functional health questionnaire: report on reliability, validity, and sensitivity to change. Pediatric Outcomes Instrument Development Group. Pediatric Orthopaedic Society of North America. J Pediatr Orthop. Sep–Oct. 1998;18(5):561-71. [pmid: 9746401].
120 Simeonsson RJ, Bailey D, Smith T, et al. Young children with disabilities: Functional assessment by teachers. Journal of Developmental and Physical Disabilities. Dec. 1995;7(4):267-84.
121 Russell DJ, Rosenbaum PL, Cadman DT, et al. The gross motor function measure: a means to evaluate the effects of physical therapy. Developmental Medicine & Child Neurology. Jun. 1989;31(3):341-52. [pmid: 2753238].
122 Patrick DL, Connell FA, Edwards TC, et al. Age-appropriate measures of quality of life and disability outcomes among children: the youth quality of life study. Centers for Disease Control and Prevention. 1998. Altana (GA). Centers for Disease Control and Prevention.
123 Kaplan RM, Bush JW, Berry CC. Health status: types of validity and the index of well-being. Health Services Research. Winter. 1976;11(4):478-507. [pmid: 1030700].
124 Dijkers MP, Whiteneck G, El-Jaroudi R. Measures of social outcomes in disability research. Archives of Physical Medicine & Rehabilitation. Dec. 2000;81(12 Suppl 2):S63-80. [pmid: 11128906].
125 Mellick D, Walker N, Brooks CA, et al. Incorporating the cognitive independence domain into CHART. Journal of Rehabilitation Outcomes. 1999;3(3):12-21.
126 Craig Hospital Research Department. Short form-Craig Handicap Assessment and Reporting Technique (CHART). Engelwood. Craig Hospital. 2000.
127 Willer B, Rosenthal M, Kreutzer JS, et al. Assessement of community integration following rehabilitation for traumatic brain injury. Journal of Head Trauma Rehabilitation. 1993;8:75-87.
128 Fougeyrollas P. Documenting environmental factors for preventing the handicap creation process: Quebec contributions relating to ICIDH and social participation of people with functional differences. Disability & Rehabilitation. Apr–Jun. 1995;17(3–4):145-53. [pmid: 7787197].
129 Harwood RH, Ebrahim S. Manual of the London Handicap Scale. Nottingham. Department of Health Care of the Elderly, University of Nottingham. 1995.
130 Holbrook M, Skilbeck CE. An Activities Index for Use with Stroke Patients. Age and Ageing. 1983;12(2):166-70. [pmid: 6869117].
131 WHOQOL Group. The World Health Organization Quality of Life Assessment (WHOQOL): position paper from the World Health Organization. Social Science & Medicine. 1995;41:1403-9. [pmid: 8560308].
132 Ware JE, Snow KK, Kosinski M, et al. SF-36 health survey: manual and interpretation guide. Boston. The Health Institute, New England Medical Center. 1993.
133 Wood-Dauphinee SL, Opzoomer MA, Williams JI, et al. Assessment of global function: The Reintegration to Normal Living Index. Archives of Physical Medicine & Rehabilitation. Aug. 1988;69(8):583-90. [pmid: 3408328].
134 Wiersma D, de Jong A, Kraaykam HM, et al. GSDS-II: The Groningen Social Disabilities Schedule (second version). Groningen. University of Groningen. 1990.
135 Katz MM, Lyerly SB. Methods for measuring adjustment and social behavior in the community. I. Rationale, description, discriminative validity and scale development. Psychological Reports. 1963;13:503-35.
136 Bond MJ, Clark MS. Clinical applications of the Adelaide Activities Profile. Clinical Rehabilitation. Jun. 1998;12(3):228-37. [pmid: 9688039].
137 Cohen ME, Marino RJ. The tools of disability outcomes research functional status measures. Archives of Physical Medicine & Rehabilitation. Dec. 2000;81(12 Suppl 2):S21-9. [pmid: 11128901].
138 Katz S, Ford AB, Moskowitz RW, et al. Studies of Illness in the Aged. The Index of Adl: A Standardized Measure of Biological and Psychosocial Function. JAMA. Sep. 21. 1963;185:914-9. [pmid: 14044222].
139 Mahoney FI, Barthel DW. Functional Evaluation: The Barthel Index. Md State Med J. Feb. 1965;14:61-5. [pmid: 14258950].
140 Carey RG, Posavac EJ. Program evaluation of a physical medicine and rehabilitation unit: a new approach. Archives of Physical Medicine & Rehabilitation. Jul. 1978;59(7):330-7. [pmid: 687042].
141 Harvey RF, Jellinek HM. Functional performance assessment: a program approach. Archives of Physical Medicine & Rehabilitation. Sep. 1981;62(9):456-60. [pmid: 7283689].
142 State University of New York at Buffalo. Guide for the Uniform Data Set for Medical Rehabilitation (Adult FIM). Buffalo. State University of New York at Buffalo. 1978.
143 Kalpakjian CZ, Toussaint LL, Quint EH, et al. Use of a standardized menopause symptom rating scale in a sample of women with physical disabilities. Menopause. Jan–Feb. 2005;12(1):78-87. [pmid: 15668604].
144 Perz JM. Development of the menopause symptom list: a factor analytic study of menopause associated symptoms. Women Health. 1997;25(1):53-69. [pmid: 9253138].
145 Burggraaff MC, van Nispen RMA, Hoek S, et al. Feasibility of the Radner Reading Charts in low-vision patients. Graefes Archive for Clinical & Experimental Ophthalmology. Nov. 2010;248(11):1631-7. [pmid: 20499082].
146 Radner T, Willinger U, Obermayer W, et al. A new German reading chart for the simultaneous evaluation of reading acuity and reading speed. Klinische Monatsblatter Fur Augenheilkunde. Sep. 1998;213(3):174-81. [pmid: 9793916].
147 Nanda U, McLendon PM, Andresen EM, et al. The SIP68: an abbreviated sickness impact profile for disability outcomes research. Quality of Life Research. Aug. 2003;12(5):583-95. [pmid: 13677503].
148 de Bruin AF, Diederiks JP, de Witte LP, et al. The development of a short generic version of the Sickness Impact Profile. Journal of Clinical Epidemiology. Apr. 1994;47(4):407-18. [pmid: 7730866].
149 Bossaert G, Kuppens S, Buntinx W, et al. Usefulness of the Supports Intensity Scale (SIS) for persons with other than intellectual disabilities. Research in Developmental Disabilities. Nov–Dec. 2009;30(6):1306-16. [pmid: 19539445].
150 Thompson JR, Bryant BR, Campbell EM, et al. Supports Intensity Scale Users’ Manual. Washington. American Association on Mental Retardation. 2004.
151 Bagley AM, Gorton GE, Bjornson K, et al. Factor- and item-level analyses of the 38-item activities scale for kids-performance. Developmental Medicine & Child Neurology. Feb. 2011;53(2):161-6. [pmid: 20964671].
152 Allen DD, Gorton GE, Oeffinger DJ, et al. Analysis of the pediatric outcomes data collection instrument in ambulatory children with cerebral palsy using confirmatory factor analysis and item response theory methods. J Pediatr Orthop. Mar. 2008;28(2):192-8. [pmid: 18388715].
153 Faull K, Hills MD. The QE Health Scale (QEHS): assessment of the clinical reliability and validity of a spiritually based holistic health measure. Disability & Rehabilitation. May. 15. 2007;29(9):701-16. [pmid: 17453992].
154 Alderman N, Wood R, Williams C. The development of the St Andrew’s-Swansea Neurobehavioural Outcome Scale: Validity and reliability of a new measure of meurobehavioural disability and social handicap. Brain Injury. 2011;25(1):83-100. [pmid: 21117921].
155 Petry K, Maes B, Vlaskamp C. Measuring the quality of life of people with profound multiple disabilities using the QOL-PMD: first results. Research in Developmental Disabilities. Nov–Dec. 2009;30(6):1394-405. [pmid: 19595562].
156 King G, Law M, King S, et al. Measuring children’s participation in recreation and leisure activities: Construct validation of the CAPE and PAC. Child: Care, Health and Development. Jan. 2007;33(1):28-39.
157 Mortenson WB, Miller WC, Auger C. Issues for the selection of wheelchair-specific activity and participation outcome measures: a review. Archives of Physical Medicine & Rehabilitation. Jun. 2008;89(6):1177-86. [pmid: 18503817].
158 Cieza A, Ewert T, Ustun TB, et al. Development of ICF Core Sets for patients with chronic conditions. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):9-11. [pmid: 15370742].
159 Cieza A, Stucki G, Weigl M, et al. ICF Core Sets for low back pain. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):69-74. [pmid: 15370751].
160 Ewert T, Allen DD, Wilson M, et al. Validation of the International Classification of Functioning Disability and Health framework using multidimensional item response modeling. Disability & Rehabilitation. 2010;32(17):1397-405. [pmid: 20158371].
161 Boonen A, Braun J, van der Horst Bruinsma IE, et al. ASAS/WHO ICF Core Sets for ankylosing spondylitis (AS): how to classify the impact of AS on functioning and health. Annals of the Rheumatic Diseases. Jan. 2010;69(1):102-7. [pmid: 19282309].
162 Brach M, Cieza A, Stucki G, et al. ICF Core Sets for breast cancer. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):121-7. [pmid: 15370759].
163 Cieza A, Chatterji S, Andersen C, et al. ICF Core Sets for depression. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):128-34. [pmid: 15370760].
164 Cieza A, Schwarzkopf S, Sigl T, et al. ICF Core Sets for osteoporosis. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):81-6. [pmid: 15370753].
165 Cieza A, Stucki A, Geyh S, et al. ICF Core Sets for chronic ischaemic heart disease. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):94-9. [pmid: 15370755].
166 Cieza A, Stucki G, Weigl M, et al. ICF Core Sets for chronic widespread pain. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):63-8. [pmid: 15370750].
167 Dreinhofer K, Stucki G, Ewert T, et al. ICF Core Sets for osteoarthritis. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):75-80. [pmid: 15370752].
168 Geyh S, Cieza A, Schouten J, et al. ICF Core Sets for stroke. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):135-41. [pmid: 15370761].
169 Grill E, Hermes R, Swoboda W, et al. ICF Core Set for geriatric patients in early post-acute rehabilitation facilities. Disability & Rehabilitation. Apr. 8–22. 2005;27(7–8):411-7. [pmid: 16040544].
170 Stucki A, Stoll T, Cieza A, et al. ICF Core Sets for obstructive pulmonary diseases. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):114-20. [pmid: 15370758].
171 Stucki A, Daansen P, Fuessl M, et al. ICF Core Sets for obesity. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):107-13. [pmid: 15370757].
172 Ruof J, Cieza A, Wolff B, et al. ICF Core Sets for diabetes mellitus. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):100-6. [pmid: 15370756].
173 Stucki G, Cieza A, Geyh S, et al. ICF Core Sets for rheumatoid arthritis. Journal of Rehabilitation Medicine. Jul. 2004;(44 Suppl):87-93. [pmid: 15370754].
174 National Institute of Neurological Disorders and Stroke. Common Data Elements for Research in Psychological Health and Traumatic Brain Injury. Defense Centers of Excellence for Psychological Health & Traumatic Brain Injury. 2012.
175 Hillier S, Comans T, Sutton M, et al. Development of a participatory process to address fragmented application of outcome measurement for rehabilitation in community settings. [Erratum appears in Disabil Rehabil. 2010;32(14):1219]. Disability & Rehabilitation. 2010;32(6):511-20. [pmid: 19852700].
176 Development of the World Health Organization. WHOQOL-BREF quality of life assessment. The WHOQOL Group. Psychological Medicine. May. 1998;28(3):551-8. [pmid: 9626712].
177 Keysor J, Jette A, Haley S. Development of the home and community environment (HACE) instrument. J Rehabil Med. 2005;37:37-44. [pmid: 15788331].
178 van Balen H, Westzaan P, Mulder T. Stratified norms for the Rivermead Behavioural Memory Test. Neuropsychol Rehabil. 1996;6:203-17.
179 Katzman R, Brown T, Fuld P, et al. Validation of a short Orientation-Memory-Concentration Test of cognitive impairment. Am J Psychiatry. 1983;140:734-9. [pmid: 6846631].
180 Burke WJ, Roccaforte WH, Wengel SP, et al. The reliability and validity of the Geriatric Depression Rating Scale administered by telephone. Journal of the American Geriatrics Society. Jun. 1995;43(6):674-9. [pmid: 7775729].
181 Mulroy SJ, Lassen KD, Chambers SH, et al. The ability of male and female clinicians to effectively test knee extension strength using manual muscle testing. Journal of Orthopaedic & Sports Physical Therapy. Oct. 1997;26(4):192-9. [pmid: 9310910].
182 Haugh AB, Pandyan AD, Johnson GR. A systematic review of the Tardieu Scale for the measurement of spasticity. Disability & Rehabilitation. Aug. 15. 2006;28(15):899-907. [pmid: 16861197].
183 Wolf SL, Catlin PA, Ellis M, et al. Assessing Wolf motor function test as outcome measure for research in patients after stroke. Stroke. Jul. 2001;32(7):1635-9. [pmid: 11441212].
184 Bohannon RW. Measurement of hand grip strength: manual muscle testing versus dynamometry. Psyciother Can. 1999;51:268-72.
185 Hill K, Bernhardt J, McGann A, et al. A new test of dynamic standing balance for stroke patients: reliability, validity and comparison with healthy elderly. Physiother Can. 1996;48:257-62.
186 Powell L, Myers A. The Activities-specific Balance Confidence (ABC) Scale. J Gerontol Med Sci. 1995;59a:28-34.
187 Benaim C, Perennou DA, Villy J, et al. Validation of a standardized assessment of postural control in stroke patients: the Postural Assessment Scale for Stroke Patients (PASS). Stroke. Sep. 1999;30(9):1862-8. [pmid: 10471437].
188 Podsiadlo D, Richardson R. The timed “up and go”: a test of basic mobility for frail elderly persons. J Am Gerontol Soc. 1991;39:142-8.
189 Carr J, Shepherd R, Nordholm L, et al. Investigation of a new motor assessment scale for stroke. Phys Ther. 1985;65:175-80. [pmid: 3969398].
190 Harada ND, Chiu V, Stewart AL. Mobility-related function in older adults: assessment with a 6-minute walk test. Archives of Physical Medicine & Rehabilitation. Jul. 1999;80(7):837-41. [pmid: 10414771].
191 Barreca S, Gowland C, Stratford P, et al. Development of the Chedoke arm and hand activity inventory: item selection. Physiother Can. 1999;29:209-11.
192 Williams PS, Basso DM, Case-Smith J, et al. Development of the Hand Active Sensation Test: reliability and validity. Archives of Physical Medicine & Rehabilitation. Nov. 2006;87(11):1471-7. [pmid: 17084122].
193 Wade DT. Measuring arm impairment and disability after stroke. International Disability Studies. Apr–Jun. 1989;11(2):89-92. [pmid: 2698395].
194 Enderby P. Frenchay dysarthria assessment manual. San Diego, CA. College-Hill Press. 1983.
195 Kertesz A. Western aphasia battery. New York, N.Y. Narcourt Brace Jovanovich. 1982.
196 Jacobson BH. The Voice handicap Index (VHI): development and validation. Am J Speech-Lang Pathol. 1997;6:66-70.
197 Ward E, Controy A. Validity, reliability and responsitivity of the Royal Brisbane Hospital outcome measure for swallowing. Asia Pacific J Speech Lang Hear. 1999;4:109-29.
198 Amirkhan J. A factor analytically derived measure of coping: the coping strategy indicator. J Personal Soc Psychol. 1990;59:1066-74.
199 Nelson L, Satz P, Mitrushina M, et al. Development and validation of the neuropsychology behaviour and affect profile. Psycholo Assess. 1989;1:266-72.
200 Law M, Baptiste S, Carswell A, et al. Canadian occupational performance measure. 3rd ed. Toronto. CAOT Publications ACE. 1998.
201 Forbes DA. Goal Attainment Scaling. A responsive measure of client outcomes. Journal of Gerontological Nursing. Dec. 1998;24(12):34-40. [pmid: 10025309].
202 Hawthorne G, Richardson J, Osborne R. The AQOL instrument: a psychometric measure of HRQoL. Qual Life Res. 1999;8:209-24. [pmid: 10472152].
203 Gillison FB, Skevington SM, Sato A, et al. The effects of exercise interventions on quality of life in clinical and healthy populations; a meta-analysis. Social Science & Medicine. May. 2009;68(9):1700-10. [pmid: 19297065].
204 Stineman MG, Xie D, Pan Q, et al. Activity of daily living staging, chronic health conditions, and perceived lack of home accessibility features for elderly people living in the community. Journal of the American Geriatrics Society. Mar. 2011;59(3):454-62. [pmid: 21361881].
205 Stineman MG, Henry-Sanchez JT, Kurichi JE, et al. Staging activity limitation and participation restriction in elderly community-dwelling persons according to difficulties in self-care and domestic life functioning. Am J Phys Med Rehabil. Feb. 2012;91(2):126-40. [pmid: 22248806].
206 Danzer E, Gerdes M, D’Agostino JA, et al. Prospective, interdisciplinary follow-up of children with prenatally diagnosed giant omphalocele: short-term neurodevelopmental outcome. Journal of Pediatric Surgery. Apr. 2010;45(4):718-23. [pmid: 20385277].
207 Temkin-Greener H, Bajorska A, Mukamel DB. Variations in service use in the program of all-inclusive care for the elderly (PACE): Is more better?. The Journals of Gerontology: Series A: Biological Sciences and Medical Sciences. Jul. 2008;63A(7):731-8.
208 Boisclair-Fahey A. Can individualized health care plans help increase continence in children with dysfunctional elimination syndrome?. Journal of School Nursing. Oct. 2009;25(5):333-41. [pmid: 19342536].
209 Claiborne N. Effectiveness of a Care Coordination Model for Stroke Survivors: A Randomized Study. Health & Social Work. 2006;31(2):87-96. [pmid: 16776026].
210 Dise-Lewis JE, Lewis HC, Reichardt CS. BrainSTARS: pilot data on a team-based intervention program for students who have acquired brain injury. Journal of Head Trauma Rehabilitation. May–Jun. 2009;24(3):166-77. [pmid: 19461364].
211 Douglas SL, Daly BJ, Kelley CG, et al. Chronically critically ill patients: Health-related quality of life and resource use after a disease management intervention. American Journal of Critical Care. Sep. 2007;16(5):447-57. [pmid: 17724242].
212 Nolan KW, Orlando M, Liptak GS. Care coordination services for children with special health care needs: Are we family-centered yet?. Families, Systems, & Health. Sep. 2007;25(3):293-306.
213 Wade SL, Oberjohn K, Burkhardt A, et al. Feasibility and preliminary efficacy of a web-based parenting skills program for young children with traumatic brain injury. Journal of Head Trauma Rehabilitation. Jul–Aug. 2009;24(4):239-47. [pmid: 19625863].
214 Xenakis N, Goldberg J. The Young Women’s Program: A health and wellness model to empower adolescents with physical disabilities. Disability & Health Journal. Apr. 2010;3(2):125-9. [pmid: 21122778].
215 Ziviani J, Darlington Y, Feeney R, et al. From policy to practice: A program logic approach to describing the implementation of early intervention services for children with physical disability. Evaluation & Program Planning. Feb. 2011;34(1):60-8. [pmid: 20546894].
216 Ziviani J, Feeney R, Rodger S, et al. Systematic review of early intervention programmes for children from birth to nine years who have a physical disability. Australian Occupational Therapy Journal. Aug. 2010;57(4):210-23. [pmid: 20854595].
217 Human Services Research Institute. National Core Indicators. http://www2.hsri.org/nci/index.asp?id=home. Accessed on October 10 2011.
218 Iezzoni L. Eliminating health and health care disparities among the growing population of people with disabilities. Health Affairs. 2011;30(10):1947-54. [pmid: 21976339].
219 Drum C, McClain M, Horner-Johnson W, et al. Health disparities chart book on disability and rational and ethnic status in the United States. Institute on Disability University of New Hampshire. 2011.