# Peer Reviewers

Valerie J. Bradley, M.A.

Human Services Research Institute

Cambridge, MA

Sara Galantowicz, M.P.H.

Thomson Reuters (Healthcare) Inc.

Cambridge, MA

Charlene Harrington, Ph.D.

Institute for Health and Aging

San Francisco, CA

Mitchell La Plant, Ph.D.

University of California

San Francisco, CA

Elizabeth Rasch, P.T., Ph.D.

NIH Clinical Center

Bethesda, MD

Margaret Stineman, M.D.

University of Pennsylvania

Philadelphia, PA

Gale Whiteneck

Craig Hospital

Englewood, CO