# Technical Expert Panel

Valerie J. Bradley, M.A.

Human Services Research Institute

Cambridge, MA

Sara Galantowicz, M.P.H.

Thomson Reuters (Healthcare) Inc.

Cambridge, MA

Charlene Harrington, Ph.D.

Institute for Health and Aging

San Francisco, CA

Allen W. Heinemann, Ph.D., ABPP, RFP, FACRM

Northwestern University

Chicago, IL

Lisa Iezzoni, M.D., M.Sc.

Massachusetts General Hospital

Boston, MA

Margaret Stineman, M.D.

University of Pennsylvania

Philadelphia, PA