# Discussion

This review examined outcome measures used in analyses that focused on specific interventions directed at a given medical problem, or comprehensive programs designed to integrate medical and social services for people with disabilities. Despite an abundance of outcome measures and some early efforts in care coordination and related outcome and performance assessment, research on a specific medical problem that incorporates disability as a complicating condition is lacking.

Our review found several examples of efforts to critically assess outcome measures for various disabled populations. Formal outcome measure assessment criteria35 can be leveraged and modified by researchers interested in extending the work to new populations. The criteria used by Andresen and colleagues to evaluate some of the measurement tools reported in the results are one example of a useful approach.35 Table 15 details their criteria. We would add impairments or the population(s) for which the outcome is relevant, and the level of measurement (person versus population level).

Table 15 Criteria to evaluate measurement tools for disability outcomes

Criterion | Application to Disability
Conceptual basis | Reflects ICF dynamic model of impairment and environment impacting participation
Norms | Includes standard comparative data from people with disabilities
Measurement model | Appropriate model: does not evidence severe ceiling/floor effects
Item/instrument bias | Data support lack of bias for people with disabilities
Burden | Brief, easy to administer, acceptable to people with disabilities
Reliability | Consistency of response, particularly when proxies are used
Validity | Adequate convergent/discriminant validity for people with disabilities
Responsiveness | Sensitive to meaningful change over time for people with disabilities
Accessible forms | Alternative administration ways show no mode effects for people with disabilities
Cultural adaptations | Adequate testing in subgroups: validated alternative language formats available

Abbreviation: ICF = International Classification of Functioning, Disability, and Health

Replicable processes do exist for participatory, collaborative methods for developing consensus around core outcome measurement sets. For example, one process that engaged a broad range of stakeholders was Hillier and colleagues’ effort to address fragmented use of outcome measures across rehabilitation in community settings.175

The review generated a lengthy list of outcome measures useful to research and quality improvement that researchers may wish to apply to specific endeavors, including care coordination. Current efforts offer the potential for cross-fertilization. Further, the important questions and appropriate outcomes have potential for overlap with different disability groups. For example, the NCI contains domains and items that could assess quality in long-term care for older adults, whether home-based or institutional. While the level of detail necessary for a researcher to successfully choose and use the measures was beyond the scope of this report, the cited sources provide a starting point. However, much could be gained from developing a core set of outcome measures, as discussed below.

## Research Issues and Gaps

Our review demonstrates how much disability and quality improvement could benefit from organized databases of critically assessed outcome measures. While the review provides examples of critical assessments and inroads into measurement tool databases, much work remains for establishing adequate banks of measures. This is easier said than done.

Disability status can affect the choice of a measure in terms of the spectrum of the targeted outcomes probed. With any outcome assessment, it is critical to use a measure sensitive to the range of possible effects. And just as with function in general, many methods can be used to assess the same underlying problem. Each measure has its own performance characteristics, making it hard to aggregate the already sparse data on how treatments vary across people with different disabilities. Further knowledge synthesis in this area will require greater consensus around which outcomes measures should form the core of all studies. In order to develop practical outcome measures that allow for comparisons across populations, a balance must be struck between granular measurements for specific groups and summary or generic measures for cross-group comparisons. Ultimately, specific group measures and summary or generic measures both serve important purposes.

Professional differences further exacerbate the variation in measurements. Different professions adopt standards for measuring the same underlying construct. In some cases, the differences are a matter of scale, driven by different goals. For example, a geriatrician might use a simple ADL that taps six domains, including dressing. The metric would range from “independent” to “doing the task with complete assistance.” Intermediate steps (such as supervision, cueing, and partial assistance) might also be included. By contrast, an occupational therapist would likely break down the task into 26 steps (e.g. selecting the clothing, putting it on, fastening the closures, etc.). Primary concerns might be speed and level of performance (e.g., are the clothes neat, is the choice appropriate).

The measurement tools we uncovered in this review are addressed at patient-centered and intermediate outcomes typically distinguished by systematic reviews. Access issues are a separate measurement concern. Access may be a matter of adequate transportation to medical care, or of navigating the medical care environment (e.g., getting on the table or into position for an x-ray), or of finding a medical practitioner who is comfortable and knowledgeable about treating the disease in someone with a disability. Organized databases should not undervalue access measures.

Patient reported outcomes, if used thoughtfully and judiciously, are promising for future research. In addition to improving the ability to aggregate data across studies, use of select patient reported outcomes within core outcomes sets may improve researchers’ ability to follow patients over time. When paired with improved measurement tool and fielding techniques, such as computer adapted testing methods, measurements may avoid some of the ceiling and floor effects problems mentioned earlier. However, patient reported outcomes have well-documented issues such as the subjectivity of the measures and the difficulty of establishing change values that represent meaningful differences for different patient populations.

A similar bank of measures would move the disability research field forward in assessing quality of care and care coordination as well. One framework for measures for coordinated care for people with Medicaid Managed Care suggests the following categories:4

- Patient experience
- Family experience
- Family caregiving burden
- Provider experience
- Functional status, independence, and community participation
- Health status
- Prevention of secondary conditions

To these, we would add measures to evaluate fidelity to the care coordination process and measures that capture access to quality care. The care coordination measure bank needs to be sensitive to care transition concerns and to the care complexity of people with disabilities. Measurement of transitions between medical services and social services is crucial. Likewise, transitions between medical service lines cannot comfortably rely on evidence based guidelines that are applicable to patients who lack such complexity.

We found very few direct examples of research conducted on specific interventions for medical needs not directly related to a disability from the perspective of disability as a complicating condition. At the very minimum, disability should (along with other chronic illnesses) be among the covariates examined for individual level outcomes. Disability should also be considered as a component of case mix when examining populations.

The lack of research may also indicate a lack of awareness or unintentional systematic bias against examining disability as a complicating condition, rather than the condition of interest itself. We view this as a legacy of an outdated separate but equal stance towards disabled populations. Alternatively, some disability researchers may disagree with such a formulation as being overly medicalized, and there are instances where such a view does provide a caution against other pervasive, unidentified biases.

A researcher’s own views about whether disease is a complicating factor for the underlying disability (or vice versa) will influence how outcomes are determined for specific research questions. For example, will an infection exacerbate multiple sclerosis or make it more difficult to manage cerebral palsy? Conversely, does treating pneumonia differ according to whether someone has mobility limitations or not? Or does treating a urinary infection in a person with quadriplegia differ from treating the same condition in someone without a disability? Some responses to disability may be akin to ageism. We talk about people developing the problems of aging prematurely, as if they were actually the problems of aging itself, when in fact these problems result from disease. Separating the etiology of a problem into normal aging or pathology is already difficult. How much more complicated is it, then, to classify the same problem in a person with an underlying disability?

Researchers may be inadvertently contributing to a problem persistently faced by people with disabilities who simultaneously experience disparities in healthcare services and greater healthcare needs.218,219 Researchers contribute to this disparity by using research designs and practices that systematically exclude people with disabilities or incompletely capture the outcomes they value. The context and environment within which researchers work further adds to this problem. As Meyer and Andresen state, researchers design research in ways that exclude people with disabilities because researchers themselves also have constraints.34

Ultimately, thoughtful consideration of the unintentional impact of research activities is the important message. Consulting with people with disabilities as partners in the research process is a good first step.

The continuing presence of research “silos” remains a concern. Multidisciplinary research and coordination or efforts across researchers who focus on the medical interventions who strive to cure, on rehabilitation to restore function, and on supportive services for disabilities is crucial. Little has changed in the decade since Andresen and colleagues published the supplemental issue on disability outcomes research, as evidenced by the ongoing lack of literature.

The most important goal might be to ensure collaborative efforts in disability outcome research and evaluation across the spectrum of research disciplines and approaches. Calls to action have been made by professionals who have dedicated their careers to disability-related research.218 Based on the evidence reviewed, we suggest a few avenues for action. Federal agencies can continue their current efforts to support full inclusion of disabled populations in research by hosting consensus conferences. Such conferences would gather researchers and stakeholders from broad medical fields as well as from disability research communities to explore measurement and research design issues that encourage inclusion and examination of disability as covariate and case mix. Professional organizations can encourage and organize joint interdisciplinary conferences to probe divergent views and explore areas of overlap that might lead to fruitful research, striving to expand beyond organizations that are professionally or paradigmatically close neighbors. Funders could engage stakeholders to identify priority areas of quality improvement, particularly related to basic medical services and prevention of secondary conditions for people with disabilities. For a given priority area, stakeholders could identify, for example, all the linkages along a path of care coordination and request proposals that include multidisciplinary teams that represent the linkages. In response, policymakers would need to examine the explicit and implicit incentive structures for removing barriers that could prevent wide dissemination of the findings from such studies.

The broad scope of the review was a useful endeavor because its findings, in particular the lack of published material for disability as a complicating condition, underscored the need for coordination and collaboration among the three overarching approaches to studying outcomes—medical, rehabilitative, and supportive services. However, the broad sweep also made it difficult to adequately drill down into the literature. Future efforts will likely need to go about “eating the elephant” differently. Outcomes for quality medical care for people with disabilities (whether it targets disabling condition or treats the disability as complicating condition) is a vast topic. The trick will be to strike a proper balance: Scopes must be constrained enough for successful search processes and broad enough for examining similarities and differences in outcome measures. Successful searches will need to be constrained along at least one dimension, for example, subpopulation, outcome domain, or outcome level. Developing further knowledge around populations and outcomes will make it more feasible to map the areas of overlap among the three theoretical approaches, and to identify areas specific to one theoretical approach.

## Limitations

The major limitation of this work is the lack of sensitivity and specificity of the search algorithms. This resulted from the project scope, as well as from the difficulty in creating key word search terms that adequately capture care coordination and outcome assessment. The literature search was extensive, with carefully designed search algorithms, numerous citations reviewed, and a reasonable coverage of the literature within the scope of the review. However, due to the limitations of search algorithms for diffused literature that necessarily rely on natural language terms rather than MeSH terms, the articles cited should be viewed as a sample of a small and dispersed literature. As stated above, the planned breadth of the review contributed to the search strategy difficulties. Each of the key questions is likely partially answerable if narrower, more focused searches are undertaken in future reviews.