# Care Coordination Evidence Tables

Appendix Table B1 Care coordination studies

Appendix Table B2 Outcomes used in care coordination studies

## References

1 Boult C, Reider L, Frey K, et al. Early effects of “Guided Care” on the quality of health care for multimorbid older persons: a cluster-randomized controlled trial. The journals of gerontology. Series A, Biological sciences and medical sciences. Mar. 2008;63(3):321-7. [pmid: 18375882].
2 Claiborne N. Effectiveness of a Care Coordination Model for Stroke Survivors: A Randomized Study. Health & Social Work. 2006;31(2):87-96. [pmid: 16776026].
3 Claiborne N. Efficiency of a Care Coordination Model: A Randomized Study with Stroke Patients. Research on Social Work Practice. 2006;16(1):57-66.
4 Cooley W, McAllister JW, Sherrieb K, et al. Improved outcomes associated with medical home implementation in pediatric primary care. Pediatrics. Jul. 2009;124(1):358-64. [pmid: 19564320].
5 Criscione T, et al. An Evaluation of Care Coordination in Controlling Inpatient Hospital Utilization of People with Developmental Disabilities. Mental Retardation. Dec. 1995;33(6):364-73. [pmid: 8569486].
6 Dicianno BE, Fairman AD, Juengst SB, et al. Using the spina bifida life course model in clinical practice: an interdisciplinary approach. Pediatric Clinics of North America. Aug. 2010;57(4):945-57. [pmid: 20883884].
7 Eklund K, Wilhelmson K. Outcomes of coordinated and integrated interventions targeting frail elderly people: a systematic review of randomised controlled trials. Health & Social Care in the Community. Sep. 2009;17(5):447-58. [pmid: 19245421].
8 Esposito D, Taylor EF, Andrews K, et al. Evaluation of the Medicaid Value Program: Health Supports for Consumers with Chronic Conditions: District of Columbia, Medical Assistance Administration Case Study. Mathematica Policy Research, Inc. 2007.
9 Fitzgibbon TM, Popalisky J, Myers K, et al. Care management for children with special needs: part I: the role of health plans. The Journal of ambulatory care management. Jul–Sep. 2009;32(3):197-204. [pmid: 19542809].
10 Fitzgibbon TM, Popalisky J, Myers K, et al. Care management for children with special needs: Part II: the role of primary care. Journal of Ambulatory Care Management. Jul–Sep. 2009;32(3):205-15. [pmid: 19542810].
11 Friedman B, Wamsley BR, Liebel DV, et al. Patient Satisfaction, Empowerment, and Health and Disability Status Effects of a Disease Management-Health Promotion Nurse Intervention among Medicare Beneficiaries with Disabilities. Gerontologist. Dec. 2009;49(6):778-92. [pmid: 19587109].
12 Hebert R, Raiche M, Dubois M-F, et al. Impact of PRISMA, a coordination-type integrated service delivery system for frail older people in Quebec (Canada): A quasi-experimental study. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. Jan. 2010;65B(1):107-18. [pmid: 19414866].
13 Hughes SL, Weaver FM, Giobbie-Hurder A, et al. Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA. Dec. 13. 2000;284(22):2877-85. [pmid: 11147984].
14 Judge KS, Bass DM, Snow AL, et al. Partners in Dementia Care: A Care Coordination Intervention for Individuals with Dementia and Their Family Caregivers. Gerontologist. Apr. 2011;51(2):261-72. [pmid: 21242317].
15 Marek KD, Popejoy L, Petroski G, et al. Nurse care coordination in community-based long-term care. Journal of nursing scholarship : an official publication of Sigma Theta Tau International Honor Society of Nursing/Sigma Theta Tau. 2006;38(1):80-6. [pmid: 16579328].
16 Mastal M, Susan P. Measuring the Effectiveness of Managed Care for Adults with Disabilities. CHCS Resource Paper. 2005.
17 McCusker J, Verdon J. Do geriatric interventions reduce emergency department visits? A systematic review. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Jan. 2006;61(1):53-62. [pmid: 16456194].
18 Melis RJF, van Eijken MIJ, Boon ME, et al. Process evaluation of a trial evaluating a multidisciplinary nurse-led home visiting programme for vulnerable older people. Disability & Rehabilitation. 2010;32(11):937-46. [pmid: 19860600].
19 Nishikawa BR, Daaleman TP, Nageswaran S. Association of provider scope of practice with successful transition for youth with special health care needs. Journal of Adolescent Health. Feb. 2011;48(2):209-11. [pmid: 21257122].
20 Oeseburg B, Wynia K, Middel B, et al. Effects of case management for frail older people or those with chronic illness: a systematic review. Nursing Research. May–Jun. 2009;58(3):201-10. [pmid: 19448524].
21 Ornstein K, Smith KL, Foer DH, et al. To the hospital and back home again: a nurse practitioner-based transitional care program for hospitalized homebound people. Journal of the American Geriatrics Society. Mar. 2011;59(3):544-51. [pmid: 21391944].
22 Palsbo SE, Ho PS. Consumer evaluation of a disability care coordination organization. Journal of health care for the poor and underserved. Nov. 2007;18(4):887-901. [pmid: 17982213].
23 Palsbo SE, Diao G. The business case for adult disability care coordination. Archives of Physical Medicine & Rehabilitation. Feb. 2010;91(2):178-83. [pmid: 20159118].
24 Raphael JL, Zhang Y, Liu H, et al. Association of medical home care and disparities in emergency care utilization among children with special health care needs. Academic pediatrics. Jul–Aug. 2009;9(4):242-8. [pmid: 19608125].
25 Schuster CR, Mitchell JM, Gaskin DJ. Partially capitated managed care versus FFS for special needs children. Health care financing review. Summer. 2007;28(4):109-23. [pmid: 17722755].
26 Singh GK, Strickland BB, Ghandour RM, et al. Geographic disparities in access to the medical home among US CSHCN. Pediatrics. Dec. 2009;124(6, Suppl 4):S352-60. [pmid: 19948599].
27 Stewart D. Transition to adult services for young people with disabilities: current evidence to guide future research. Developmental Medicine & Child Neurology. Oct. Suppl 4. 2009;51:169-73. [pmid: 19740226].
28 Strickland BB, Singh GK, Kogan MD, et al. Access to the medical home: new findings from the 2005–2006 National Survey of Children with Special Health Care Needs. Pediatrics. Jun. 2009;123(6):e996-1004. [pmid: 19482751].
29 Tourigny A, Durand PJ, Bonin L, et al. Quasi-Experimental Study of the Effectiveness of an Integrated Service Delivery Network for the Frail Elderly. Canadian Journal on Aging. Fall. 2004;23(3):231-46. [pmid: 15660297].
30 Turchi RM, Berhane Z, Bethell C, et al. Care coordination for CSHCN: associations with family-provider relations and family/child outcomes. Pediatrics. Dec. Suppl 4. 2009;124:S428-34. [pmid: 19948609].
31 Van Achterberg T, Stevens FC, Crebolder HF, et al. Coordination of care: Effects on the continuity and quality of care. International Journal of Nursing Studies. Dec. 1996;33(6):638-50. [pmid: 8970861].
32 Wise PH, Huffman LC, Brat G. A Critical Analysis of Care Coordination Strategies for Children With Special Health Care Needs. Agency for Healthcare Research and Quality. Rockville (MD). Quality AfHRa. 2007. http://www.ncbi.nlm.nih.gov/pubmed/20734510.
33 Wolff JL, Giovannetti ER, Boyd CM, et al. Effects of Guided Care on Family Caregivers. Gerontologist. Aug. 2010;50(4):459-70. [pmid: 19710354].
34 Wood D, Winterbauer N, Sloyer P, et al. A longitudinal study of a pediatric practice-based versus an agency-based model of care coordination for children and youth with special health care needs. Maternal & Child Health Journal. Sep. 2009;13(5):667-76. [pmid: 18766431].
35 Wood DL, McCaskill QE, Winterbauer N, et al. A multi-method assessment of satisfaction with services in the Medical Home by parents of children and youth with special health care needs (CYSHCN). Maternal and Child Health Journal. Jan. 2009;13(1):5-17. [pmid: 18274884].
36 Danzer E, Gerdes M, D’Agostino JA, et al. Prospective, interdisciplinary follow-up of children with prenatally diagnosed giant omphalocele: short-term neurodevelopmental outcome. Journal of Pediatric Surgery. Apr. 2010;45(4):718-23. [pmid: 20385277].
37 Temkin-Greener H, Bajorska A, Mukamel DB. Variations in service use in the program of all-inclusive care for the elderly (PACE): Is more better?. The Journals of Gerontology: Series A: Biological Sciences and Medical Sciences. Jul. 2008;63A(7):731-8.
38 Boisclair-Fahey A. Can individualized health care plans help increase continence in children with dysfunctional elimination syndrome?. Journal of School Nursing. Oct. 2009;25(5):333-41. [pmid: 19342536].
39 Dise-Lewis JE, Lewis HC, Reichardt CS. BrainSTARS: pilot data on a team-based intervention program for students who have acquired brain injury. Journal of Head Trauma Rehabilitation. May–Jun. 2009;24(3):166-77. [pmid: 19461364].
40 Douglas SL, Daly BJ, Kelley CG, et al. Chronically critically ill patients: Health-related quality of life and resource use after a disease management intervention. American Journal of Critical Care. Sep. 2007;16(5):447-57. [pmid: 17724242].
41 Nolan KW, Orlando M, Liptak GS. Care coordination services for children with special health care needs: Are we family-centered yet?. Families, Systems, & Health. Sep. 2007;25(3):293-306.
42 Wade SL, Oberjohn K, Burkhardt A, et al. Feasibility and preliminary efficacy of a web-based parenting skills program for young children with traumatic brain injury. Journal of Head Trauma Rehabilitation. Jul–Aug. 2009;24(4):239-47. [pmid: 19625863].
43 Xenakis N, Goldberg J. The Young Women’s Program: A health and wellness model to empower adolescents with physical disabilities. Disability & Health Journal. Apr. 2010;3(2):125-9. [pmid: 21122778].
44 Ziviani J, Darlington Y, Feeney R, et al. From policy to practice: A program logic approach to describing the implementation of early intervention services for children with physical disability. Evaluation & Program Planning. Feb. 2011;34(1):60-8. [pmid: 20546894].
45 Ziviani J, Feeney R, Rodger S, et al. Systematic review of early intervention programmes for children from birth to nine years who have a physical disability. Australian Occupational Therapy Journal. Aug. 2010;57(4):210-23. [pmid: 20854595].
46 Raphael D, Brown I, Renwick R. Psychometric properties of the full and short versions of the Quality of Life Instrument Package: Results from the Ontario province-wide study. International Journal of Disability, Development and Education. Jun. 1999;46(2):157-68.
47 Wade DT, Legh-Smith J, Langton Hewer R. Social activities after stroke: measurement and natural history using the Frenchay Activities Index. Int Rehabil Med. 1985;7(4):176-81. [pmid: 4093249].
48 Wade DT. Measuring arm impairment and disability after stroke. International Disability Studies. Apr–Jun. 1989;11(2):89-92. [pmid: 2698395].