# Search Sources and Algorithms

## Key Question 1

### Medline

1 exp Disabled Persons/
2 exp mental disorders diagnosed in childhood/or developmental disabilities/
3 exp child development disorders/
4 limit 3 to yr=“1990 – 1995”
5 exp Homebound Persons/
6 exp cognition disorders/
7 exp mental retardation/
8 intellectual disab$.mp.
9 1 or 2 or 4 or 5 or 6 or 7 or 8
10 exp Disability Evaluation/
11 exp factor analysis, statistical/
12 exp Psychometrics/mt, st [Methods, Standards]
13 10 or 11 or 12
15 9 and 13
16 limit 14 to english language
17 limit 16 to yr=“1990 -Current”

### PsycInfo

1. exp disabilities/ or exp developmental disabilities/ or exp learning disabilities/ or exp multiple disabilities/ or exp reading disabilities/
2. exp Homebound/
3. elderly.mp.
4. disabled person.mp.
5. exp Cognitive Impairment/ or cognition disorder.mp.
6. 1 or 2 or 3 or 4 or 5 177691
7. exp Disability Evaluation/ 34094
8. exp Factor Analysis/ 17649
9. exp Psychometrics/ 46844
10. 7 or 8 or 9 93277
11. 6 and 10 4042
12. limit 11 to (english language and yr=“1990 -Current”)

## ICF Update Search

### Medline

1. International classification of function$.mp.
2. ICF.mp.
3. 1 or 2
4. limit 3 to (english language and yr=“2008 –Current”)

### PsycInfo

1. international classification of function.mp.
2. icf.mp.
3. 1 or 2
4. limit 3 to yr=“2008 –current”
5. limit 4 to english language

## Key Question 1b

### Medline

The basic search algorithm is presented first, using the diabetes secondary conditions as the condition of interest. For brevity, the basic search algorithm is followed by the specific search terms for the other basic medical service needs and secondary conditions.

1. exp Disabled Persons/
2. exp mental disorders diagnosed in childhood/ or developmental disabilities.mp.
3. exp child development disorders/
4. limit 3 to yr=“1990 – 1995”
5. exp homebound persons/
6. exp cognition disorders/
7. exp mental retardation/
8. intellectual disab$.mp.
9. 1 or 2 or 4 or 5 or 6 or 7 or 8
10. exp frail elderly/
11. 9 or 10
12. (randomized controlled trial or clinical trial).pt.
13. (randomized controlled trials or random allocation or clinical trial or double blind method or single blind method).sh.
14. exp clinical trial/
15. (clin$ adj25 trial$).ti,ab.
16. ((singl$ or doubl$ or trebl$ or trip$) adj25 (blind$ or mask$)).ti,ab.
17. (research design or placebos).sh.
18. (placebo$ or random$).ti,ab.
19. cohort studies/ or comparative study/ or follow-up studies/ or prospective studies/ or risk factors/ or cohort.mp. or compared.mp. or groups.mp. or multivariate.mp.
20. 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19
21. 11 and 20
22. exp diabetes mellitus/
23. (uncontrolled or noncontrolled).mp.
24. 22 and 23
25. 21 and 24
26. exp diabetes complications/
27. exp diabetes mellitus/co
28. 26 or 27
29. 21 and 28
30. 25 or 29
31. limit 30 to (english language and yr=“1990 –Current”)

#### Pneumonia

22 exp Pneumonia, Bacterial/
23 exp pneumonia/
24 exp bacterial infections/

#### Asthma

22 exp asthma/

#### Gastroenteritis

22 exp gastroenteritis/

#### Hypertension

22 exp hypertension/

#### Obesity

22 exp obesity/

#### Pressure Ulcers

22 exp pressure ulcer/

#### Preventive Dental

22 exp Preventive Dentistry/
23 exp dental care/
24 exp bacterial infections/

#### Preventive Health

22 exp Preventive Health Services/
23 exp Preventive Medicine/

All of the above searches were repeated with frail elderly replaced by elderly and ADL terms:

21 exp elderly/
22 (ADL or Activities of Daily Living).mp.
23 function.mp.
24 21 and 22 and 23

### PsychInfo

1 exp disabilities/ or exp developmental disabilities/ or exp learning disabilities/ or exp multiple disabilities/ or exp reading disabilities/
2 exp Homebound/
3 elderly.mp.
4 1 or 2 or 3
5 disabled person.mp.
6 exp Cognitive Impairment/ or cognition disorder.mp.
7 4 or 5 or 6
8 exp Asthma/
9 7 and 8
13 limit 9 to “2000 treatment outcome/randomized clinical trial”
14 exp “Activities of Daily Living”/
15 8 and 14
16 preventive dental.mp.
17 exp Pneumonia/
18 7 and 17
19 exp Diabetes Insipidus/ or exp Diabetes/ or exp Diabetes Mellitus/
20 7 and 19
21 limit 20 to “2000 treatment outcome/randomized clinical trial”
22 gastroenteritis.mp.
23 7 and 22
24 exp Hypertension/ or hypertension.mp.
25 7 and 24
26 limit 25 to “2000 treatment outcome/randomized clinical trial”
27 exp Obesity/ or obesity.mp.
28 7 and 27
29 limit 28 to “2000 treatment outcome/randomized clinical trial”
30 pressure ulcer.mp.
31 7 and 30
32 preventive medical.mp.
33 7 and 32
34 urinary tract infection.mp.
35 7 and 34

## Key Question 2 and 3

### Medline

1. exp Disabled Persons/
2. exp mental disorders diagnosed in childhood/ or developmental disabilities.mp.
3. exp child development disorders/
4. limit 3 to yr=“1990 – 1995”
5. exp homebound persons/
6. exp cognition disorders/
7. exp mental retardation/
8. intellectual disab$.mp.
9. 1 or 2 or 4 or 5 or 6 or 7 or 8
10. exp frail elderly/
11. 9 or 10
12. exp Disease Management/
13. exp Patient Care Planning/
14. exp Patient-Centered Care/
15. exp primary health care/
16. exp progressive patient care/
17. exp critical pathways/
18. exp “delivery of health care, integrated”/
19. exp health services accessibility/
20. exp managed care programs/
21. exp product line management/
22. exp patient care team/
23. exp behavior control/
24. exp counseling/
25. exp health promotion/
26. exp patient compliance/
27. exp after-hours care/
28. ((coordination or coordinated or Multifactorial or multi-factorial or multicomponent or multi-component or multidisciplinary or multi-disciplinary or interdisciplinary or inter-disciplinary or integrated or community-based or organized) and (care or approach or intervention or strategy or strategies or management or managing or center$ or clinic$)).ti.
29. exp “organization and administration”/
30. 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29
31. 11 and 30
32. limit 31 to (english language and humans)
33. (randomized controlled trial or clinical trial).pt.
34. (randomized controlled trials or random allocation or clinical trial or double blind method or single blind method).sh.
35. exp clinical trial/
36. (clin$ adj25 trial$).ti,ab.
37. ((singl$ or doubl$ or trebl$ or trip$) adj25 (blind$ or mask$)).ti,ab.
38. (research design or placebos).sh.
39. (placebo$ or random$).ti,ab.
40. cohort studies/ or comparative study/ or follow-up studies/ or prospective studies/ or risk factors/ or cohort.mp. or compared.mp. or groups.mp. or multivariate.mp.
41. 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40
42. 31 and 41
43. limit 42 to english language
44. limit 43 to yr=“2000 –Current”

### PsycInfo

1. exp Disease Management/ (2338)
2. exp Treatment Planning/ (3373)
3. Patient-Centered Care.mp. (280)
4. progressive patient care.mp. (1)
5. critical pathways.mp. (24)
6. health services accessibility.mp. (2)
7. product line management.mp. (6)
8. patient care team.mp. (15)
9. medical home.mp. (160)
10. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 (6148)
11. coordination of care.mp. (202)
12. care coordination.mp. (267)
13. 11 or 12 (442)
14. 10 and 13 (53)
15. exp “Quality of Care”/ (6442)
16. exp “Quality of Services”/ (9682)
17. 15 or 16 (9682)
18. 13 and 17 (69)
19. 10 and 17 (186)
20. 14 or 18 or 19 (286)

### ERIC

The ERIC database has limited search function. All searches were run and results imported into one bibliography from which duplicates were deleted. Articles were limited to 2000 forward.

“Coordination of care” OR “care coordination” OR “quality gap” OR “disease management” OR “medical home”

“access to health care” AND (“program effectiveness” OR “program evaluation” or “Integrated Services”)

“access to health care” or “integrated services” AND quality

“integrated services” AND (Health OR Medical)

## Sources of Grey Literature

Appendix Table A1 Sources of grey literature

Federal and state agencies | Administration on Aging (AoA) Agency for Healthcare Research and Quality (AHRQ) Centers for Medicare and Medicaid Service (CMS) Congressional Research Service (CRS) Office of the Assistant Secretary for Planning and Evaluation (ASPE) U.S. Government Accountability Office (GAO) State Departments of Health or Health & Human Services Veterans Administration
Research organizations, foundations, and advocacy groups | AARP Abt Associates Alliance for Health Reform American Public Human Services Association Health Services Division Center for Excellence in Assisted Living Institute for Community Integration Kaiser Family Foundation LeadingAge Mathematica Policy Research Milbank Memorial Fund National Academy for State Health Policy National Association of Area Agencies on Aging National Association of Medicaid Directors National Center for Assisted Living National Conference of State Legislatures National Governors Association National Investment Center National PACE Association PAS Center for Personal Assistance Services, UCSF Robert Wood Johnson Foundation RTI International Scripps Gerontology Center The Clearinghouse for Home and Community Based Services The Commonwealth Fund The Hilltop Institute The John A. Hartford Foundation The Lewin Group The SCAN Foundation Urban Institute Visiting Nurse Service of New York