# Acronyms and Abbreviations

AAP: Adelaide Activities Profile
ADL: Activities of daily living
AHRQ: Agency for Healthcare Research and Quality
BDI: Beck Depression Inventory
CAHPS: Consumer Assessment of Healthcare Providers and Systems
CDC: Centers for Disease Control
BASC: Behavior Assessment System for Children
BRIEF: Behavior Rating Inventory of Executive Functions
CES-D: Center for Epidemiologic Studies—Depression Scale
CHIP-AE: Child Health and Illness Profile—Adolescent Edition
CHQ: Child Health Questionnaire
CIQ: Community Integration Questionnaire
CQG Series: Closing the Quality Gap Series
CVD: Cardiovascular disease
DACL: Depression Adjective Check List
DALY: Disability-Adjusted Life Years
EADL: Extended Activities of Daily Living Scale
ECBI: Eyberg Child Behavior Inventory
EPC: Evidence-based Practice Center
EQ-5D: EuroQol 5 dimensions
ER: Emergency room
ES: Executive summary
FACT: Functional Assessment of Cancer Therapy
FAI: Frenchay Activities Questionnaire
FIM: Functional Independence Measure
FS II-R: Functional Status II-R
GMFM: Gross Motor Function Measure
GSDS-II: Groningen Social Disabilities Schedule
Hb: Hemoglobin
HEI: Health Environmental Integration
HMSC: Rand Health Status Measure for Children
HRQOL: Health-Related Quality of Life
HSRI: Human Services Research Institute
IADL: Instrumental Activities of Daily Living
ICD: International Classification of Diseases
ICF: International Classification of Functioning, Disability, and Health
ICIDH: International Classification of Impairments, Disabilities, and Handicaps
IL: Independent living
IoM: Institute of Medicine
Katz R2: Katz Patient Adjustment Scale R2
KQ: Key Question
LHS: London Handicap Scale
LIFE-H: Assessment of Life Habits
MeSH: Medical subject headings
MOS: Medical Outcomes Study
MPAI: Mayo-Portland Adaptability Inventory
MPOC: Measure of Process of Care
MSL: Menopause Symptom List
NASDDDS: National Association of State Directors of Developmental Disabilities Services
NIH: National Institutes of Health
NCI: National Core Indicators
Nottingham: Nottingham Extended Activities of Daily Living
PACIC: Patient Assessment of Care for Chronic Conditions
PAIS-SR: Psychological Adjustment to Illness Scale—Self Report
PEDI: Pediatric Evaluation of Disability Inventory
POMS: Profile of Mood States
POSNA: POSNA Pediatric Musculoskeletal Functional Health Questionnaire
PROMIS: Patient-Reported Outcome Measurement Information System
QALY: Quality-adjusted life year
QoL: Quality of life
QUICCC: Questionnaire for Identifying Children with Chronic Conditions
QWB: Quality of Well-Being Scale
RCT: Randomized controlled trial
RRC: Radner Reading Charts
SAS-SR: Social Adjustment Scale—Self Report
SDS: Zung Elf-rating Depression Scale
SF-36: Medical outcomes short-form health survey
SFA: School Function Assessment
SIP: Abbreviated Sickness Impact Profile
SMI: Severe and persistent mental illness
TBI: Traumatic brain injury
TEP: Technical Expert Panel
WHOQOL: World Health Organization Quality of Life Scale
YQOL-S: Youth Quality of Life Instrument