# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Charles Lakin, Brian Abery, and Lynda Anderson for generously sharing the Institute for Community Integration’s resources and accumulated knowledge and experience, and Mike Grove and Andrea Wysocki for their search and screening assistance.