# Results

The literature review yielded 8,362 abstracts. One-hundred and thirty-six articles from the literature search met all selection criteria for inclusion in this review. An additional four articles were identified from a review of article reference lists. Articles from the 2007 report were screened: nine met selection criteria and controlled for confounding or secular trend. See the Preferred Reporting Items of Systematic reviews and Meta-Analyses (PRISMA) diagram in Figure 3 for additional details.

Figure 3 Search results and article triage

^a^ Ranji SR, Shetty K, Posley KA, Lewis R, Sundaram V, Galvin CM, Winston LG. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies (Vol. 6: Prevention of Healthcare-Associated Infections). AHRQ Publication No. 04(07)-0051-6. Rockville, MD: Agency for Healthcare Research and Quality; 2007. www.ncbi.nlm.nih.gov/pubmed/20734530.

^b^ Eight of these studies reported on two infections and one, on three infections.

^c^ Five of these articles reported on two infections; three, on three infections; and one, on four infections.

^d^ One of these articles has an updated publication one year later. In the PRISMA diagram these studies were cited as a single study.

Figure 3 is a PRISMA diagram illustrating the review of articles for this systematic review. 8,366 records were identified in the initial database search and screened; an additional 4 records were identified through a hand search, and 9 records from the 2007 report met selection criteria and were added to the report (total 8,379 records screened). Of these, 7,462 were excluded. 919 unique, full-text articles were reviewed. 767 full-text articles were excluded and 152 articles were included in the final report.

The 149 articles (generating 173 analyses at the infection level) were divided into two groups. The first group consisted of 61 articles, most of which were quasi-experimental studies that controlled for confounding or secular trend. Eight of these articles reported on two types of infection and one article reported on three infections; each infection reported is treated as a separate study from this point forward. These 71 analyses—26 on CLABSI, 19 on VAP, 15 on SSI, and 11 on CAUTI—form the basis of this report. The words ‘analysis’ and ‘study’ are used interchangeably and refer to the infection-level results.

The other 88 articles (generating 102 analyses) did not account for the many potential sources of confounding and for secular trend. Therefore, as discussed in the Methods chapter, their results are at high risk of bias. These were simple before-after studies or controlled before-after studies (2 of 88) with two group tests, for example, t-tests and chi-square tests. The two controlled before-after studies were demoted due to lack of between group comparisons. Of these 88 articles, five reported on two types of infection and three articles reported on three infections, and one article reported on four infections; each infection is treated as a separate study from this point forward. The characteristics of this second group of 102 studies are summarized in tables for each infection in Appendix F, but they were excluded from the analysis in this report. Despite concerted efforts to identify studies from nursing homes, dialysis centers, and outpatient surgical centers, only one study, which did not control for confounding or secular trend, met inclusion criteria and took place in a nonhospital setting (See Appendix A for search strategy details).

The distribution of the 71 studies (61 articles) analyzed in this report across other dimensions is also presented in Table 4 with the exception of the study quality category, which includes all 173 studies (149 articles). These articles are also cited and discussed in further detail in their respective infection sections below.

Table 4 Number of studies in each category by infection type and overall

Study Characteristic | Category | CLABSI | VAP | SSI | CAUTI | All
Design | Cluster RCT | 2 | 2 | 1 | 0 | 5
Design | Individual RCT | 0 | 0 | 1 | 1 | 2
Design | Stepped wedge | 1 | 1 | 1 | 1 | 4
Design | Controlled studies | 4 | 2 | 1 | 1 | 8
Design | Interrupted time series | 3 | 5 | 1 | 2 | 11
Design | Simple before-after | 16 | 9 | 10 | 6 | 41
Design | TOTAL | 26 | 19 | 15 | 11 | 71
Number of QI Strategies | 5 QI strategies | 2 | 0 | 0 | 0 | 2
Number of QI Strategies | 4 QI strategies | 8 | 7 | 2 | 2 | 19
Number of QI Strategies | 3 QI strategies | 7 | 5 | 5 | 2 | 19
Number of QI Strategies | 2 QI strategies | 5 | 7 | 4 | 4 | 20
Number of QI Strategies | 1 QI strategies | 4 | 0 | 4 | 3 | 11
Outcomes Reported | Adherence only | 1 | 1 | 2 | 3 | 7
Outcomes Reported | Infection rates only | 16 | 9 | 5 | 2 | 32
Outcomes Reported | Both adherence and infection rates | 9 | 9^a^ | 8 | 6^a^ | 32
Sample Size (Range Across Studies When Reported)^b^ | Patients postintervention | 50 to 4,671 | 81 to 4,761 | 115 to 10,617 | 93 to 1,794 | NA
Sample Size (Range Across Studies When Reported)^b^ | Postintervention infection rate | 0 to 7.7 per 1,000 catheter days | 0.7 to 22.5 per 1,000 ventilator-days | 0% to 7.7% | 1.8 to 12.9 per 1,000 catheter days | NA
Sample Size (Range Across Studies When Reported)^b^ | Baseline infection rate | 1.84 to 17 per 1,000 catheter days | 1.9 to 39.7 infections per 1,000 ventilator-days | 1.1% to 15% | 1.7 to 21.5 per 1,000 catheter days | NA
Length of Followup (Months) | Mean | 20 | 22 | 14.4 | 23 | 20
Length of Followup (Months) | Median | 23 | 17 | 12 | 17 | 18
Length of Followup (Months) | Range | 3.5 to 46^c^ | 4 to 54 | 1 to 30^d^ | 3 to 61 | 1 to 61
Location | United States | 18 | 9 | 11 | 2 | 40
Location | Other | 8 | 10 | 4 | 9 | 31
Multisite or Single Site | Multisite | 12 | 4 | 7 | 3 | 26
Multisite or Single Site | Single site | 14 | 15 | 8 | 8 | 45
Study Quality | Higher | 1 | 3 | 2 | 1 | 7
Study Quality | Medium | 9 | 4 | 3 | 3 | 19
Study Quality | Lower | 16 | 12 | 10 | 7 | 45
Study Quality | Did not control for confounding or secular trend | 27 | 25 | 34 | 16 | 102

Abbreviations: CAUTI = catheter-associated urinary tract infection; CLABSI = central line–associated bloodstream infection; NA = not applicable; QI = quality improvement; RCT = randomized controlled trial; VAP = ventilator-associated pneumonia; SSI = surgical site infection.

a One study compared two sets of QI strategies, and another compared early and later infection rates.

b Patients may be defined differently across studies within a given infection category—for example, patients on ventilator or patients on ventilator for at least 48 hours.

c Four studies did not report length of followup.

d One study did not report length of followup.

Adherence rates measured adherence with evidence-based preventive interventions identified by Healthcare Infection Control Practices Advisory Committee (HICPAC), Infectious Diseases Society of America (IDSA), Society for Healthcare Epidemiology of America (SHEA), or members of the Technical Expert Panel. These interventions were supported by studies that linked their increased use to lower infection rates. Therefore, they are considered direct outcomes in the strength of evidence tables. Lowering infection rates is the primary objective of the patient safety initiatives, but many factors may affect these rates besides the interventions themselves, especially in an environment of heightened attention to the risks posed by HAI. Therefore, the strongest evidence of the effect of a QI intervention is to see changes in adherence to the targeted preventive interventions and a change in the infection rate. Because infections are, fortunately, relatively rare, in some cases changes in adherence rates may not be associated with a change in infection rates because of a lack of power to detect a significant change in the latter, rather than due to a lack of impact on infection rates. The majority of studies relied on CDC NHSN/NNIS criteria for identifying infections. These are generally accepted in the United States as the standard definition, although they have some limitations, including possible differences in how they are applied from one setting to another. However, this report focuses on changes in infection rates over time, so as long as the method of identifying infections is stable over time, the results should be fairly reliable.

Analyzing the impact of QI strategies, the objective of this report, is complicated by the fact that more than one QI strategy was used in most studies (60 of 71). Disentangling the effect of a single QI strategy is not possible with the available body of evidence. With 71 studies, 16 different combinations of QI strategies were used. The following approaches were considered for evaluating the effectiveness of the QI strategies, but all had limitations and were rejected.

- Considering each QI strategy individually within each study. The effect of a strategy cannot be disentangled from the impact of other strategies.
- Using the number of QI strategies. This option was not viable as the types of strategies included may have confounded the effect.
- Identifying the incremental impact of a single QI strategy. This approach could be measured only by comparing two combinations of QI strategies in the same clinical context, in which one combination contained the QI strategy of interest and the other did not. None of the studies identified for this report had such a design.

Therefore, in this report, QI strategies are grouped together based on the combinations of strategies used in our included studies (Table 5). This approach mirrors common practice, which relies on combinations of QI strategies, and can therefore potentially yield practical insights.

Table 5 QI strategy combinations across infections

Combination of QI Strategies | Organizational Change | Provider Education | Audit and Feedback | Provider Reminder Systems | Patient Education | Financial Incentives | CLABSI^a^ | VAP^a^ | SSI^a^ | CAUTI^a^ | All^a^
Variants of Base Strategies (Organizational Change and Provider Education) | • | • | | | | | 3^b^ | 3^b^ | 1 | 0 | 7
Variants of Base Strategies (Organizational Change and Provider Education) | • | | | | | | 0 | 0 | 2^b^ | 0 | 2
Variants of Base Strategies (Organizational Change and Provider Education) | | • | | | | | 3 | 1 | 0 | 0 | 4
Variants of Base Strategies With Audit and Feedback | • | • | • | | (c) | | 4 | 4^c^ | 3^d^ | 1 | 12
Variants of Base Strategies With Audit and Feedback | • | | • | | | | 0 | 1 | 1 | 0 | 2
Variants of Base Strategies With Audit and Feedback | | • | • | | | | 0 | 0 | 1 | 1 | 2
Variants of Base Strategies With Audit and Feedback | | | • | | • | | 1 | 1 | 0 | 1 | 3
Variants of Base Strategies With Provider Reminder System | • | • | | • | | | 2 | 1 | 2 | 1 | 6
Variants of Base Strategies With Provider Reminder System | • | | | • | | | 0 | 0 | 1 | 2 | 3
Variants of Base Strategies With Provider Reminder System | | | | • | | | 1 | 0 | 2 | 3 | 6
Variants of Base Strategies With Audit and Feedback and Provider Reminder System | • | • | • | • | | (c) | 10^b,e^ | 6^b^ | 2 | 2^b^ | 20
Variants of Base Strategies With Audit and Feedback and Provider Reminder System | • | | • | • | | | 1 | 1 | 0 | 0 | 2
Variants of Base Strategies With Audit and Feedback and Provider Reminder System | | • | • | • | | | 1 | 1 | 0 | 0 | 2

Abbreviations: CAUTI = catheter-associated urinary tract infection; CLABSI = central line–associated bloodstream infection; HAI = healthcare-associated infection; QI = quality improvement; VAP = ventilator-associated pneumonia; SSI = surgical site infection.

a These columns indicate the number of studies for each HAI or for all HAI that use the variant of QI strategies indicated in each row.

b Comparator for one article is low-intensity intervention.

c These two strategies did not define the combinations; therefore, a dot is not included in the definition of the combinations.

d One study also includes patient education.

e Two studies also include financial incentives.

To develop a workable classification of QI strategy combinations for the purposes of this report, we hypothesized that organizational change and provider education constitute base strategies. Face validity is the initial rationale for the hypothesis as 90 percent of the included studies used at least one of these two strategies. While this hypothesis is open to debate, the use of these strategies was ubiquitous, so in practical terms, little distinction could be made between those studies that used these two strategies and those that did not. In addition, it is difficult to imagine how any preventive intervention or QI effort could be implemented without at least some level of organizational change and/or provider education. Further, it is plausible that those studies that did not report using organizational change or provider education may simply have taken these elements for granted. Analyzing the effectiveness of specific components of organizational change would be useful, but the heterogeneity of organizational change across studies and variations in thoroughness of reporting preclude such an analysis based on current evidence. Scant information is available in this literature comparing different educational strategies.

So, for simplicity, from here we refer to organizational change, provider education, or both as base strategies. This concept allowed us to organize our data into categories of strategies used in combination with the base strategies. These additional strategies are: (1) audit and feedback plus provider reminder systems; (2) audit and feedback only; (3) provider reminder systems only. Only two45,46 studies reported the use of financial incentives, regulation, or policy, and two47,48 reported on patient education, so these QI strategies were not treated separately despite their potential importance. The main variation across QI strategy combinations, therefore, is in the use of audit and feedback and/or provider reminder systems. For each infection, the QI strategy combinations were grouped into two or three categories in developing the strength-of-evidence tables. The composition of these groups varies to some degree from infection to infection, based on which combinations were reported in the included studies.

The quality of the studies and the strength of evidence for the QI strategy combinations should be viewed in the context of the clinical issue being addressed. Because these studies measure effectiveness, not efficacy, and are implemented in actual health care settings, many factors cannot be controlled for as they would be in a traditional, individual–level randomized, controlled trial. Some health care facilities would not participate in these studies if they could not undertake a QI intervention while the study was underway. This position was the reason that a number of the comparative studies launched multiple interventions simultaneously, even though the presence of any active QI activity in a control group may increase adherence rates even for other types of infections. Because of the challenges inherent in studying this field, the highest rating for strength of evidence was limited to moderate, reflected in the available study designs.

Due to the heterogeneity of studies and the qualitative nature of the evidence synthesis, magnitude of effect was not considered quantitatively in evaluating the strength of evidence. We did not attempt to compare the magnitude across studies, taking into account confidence intervals, because of the differences in baseline rates, statistical analysis, et cetera. However, magnitude is sometimes considered qualitatively in judging whether the changes overall appear large enough to have clinical benefit. Furthermore, some studies appeared to manifest a “ceiling” or “floor” effect. For example, some sites began the studies with low infection rates and brought them down to zero for months at a time. The change might not be statistically significant, yet there was not room for further improvement. In other cases, there were large differences in the baseline adherence rates. These issues were considered qualitatively in assigning strength of evidence.

Within each study, the intervention period was compared with a period of no intervention (usual care), which refers to the absence of additional QI efforts other than the standard of care already in place. Thirteen studies implemented QI strategies in a stepwise fashion and did not report rates before any intervention was implemented.45,49-60 The comparator for these studies was defined as a low-intensity intervention. Also, a separate strength-of-evidence evaluation was conducted for studies reporting both adherence and infection rates, because studies that report both outcomes have more reliable results than those that do not. This evaluation reported results for each QI combination across all four types of infections.

The strength-of-evidence conclusion relies both on the underlying effect of different QI combinations on outcomes and on the availability of studies to assess the relationship. A low strength of evidence, therefore, means that the current body of evidence does not support a stronger conclusion. Whether or not the strength of evidence will change as additional evidence accumulates cannot be determined at this time.

In the study summaries that follow, standard deviations, 95% confidence intervals, and p values are included when they are reported in the article.

## Key Questions 1 and 1a Which QI strategies are effective in improving HAI and adherence to evidence-based preventive interventions?

### Central Line-Associated Bloodstream Infection (CLABSI)

#### Overview

The literature search identified 26 studies,45,46,48,53,58-75 and there were four from the 2007 report,49,76-78 that addressed the prevention of central line-associated bloodstream infections (CLABSI) and controlled for confounding factors or secular trend (Table 6).

Table 6 Overview of CLABSI articles that control for confounding or secular trend

Author, location-year | Study type | Analysis for infection rates | Sample size (infections) | Organizational change | Provider education | Audit and feedback | Provider reminder systems | Patient education | Financial incentives
Scales, Canada - 2011^58^ | Cluster RCT | Generalized linear mixed model | | | • | • | •
Speroff, United States - 2011^60^ | Cluster RCT | Hierarchical negative binomial regression | | • | •
Lilly, United States - 2011^53^ | Nonrandomized stepped wedge | Logistic regression | pre: 1529 (19) post: 4761 (29) | • | | •
Berenholtz, United States - 2004^49^ | Controlled interrupted time series | Poisson regression | | • | • | • | •
Khouli, United States - 2011^61^ | Controlled before-after | Generalized linear model with Poisson distribution | control pre: (12) control post: (8) study pre: (20) study post: (5) | | •
Perez Parra, Spain - 2010^62^ | Controlled before-after | Poisson regression | control pre: (118) control post: (91) study pre: (45) study post: (34) | | •
Barsuk, United States - 2009^63^ | Controlled before-after | Poisson regression | control pre: (22) control post: (17) study pre: (25) study post: (4) | | •
Apisarnthanarak, Thailand - 2010^64^ | Interrupted time series | Segmented regression | pre: 1115 (88) post: 1204 (7) | • | • | •
Costello, United States - 2008^45^ | Interrupted time series | Segmented regression | pre: 911 (26) post: 936 (11) | • | • | • | • | | •
Miller, United States - 2010^65^/105 | Interrupted time series | Generalized linear model | | • | • | • | •
McKee, United States - 2008^66^ | Simple before-after | Statistical process control chart | | • | • | • | •
Frankel, United States - 2005^76^ | Simple before-after | Statistical process control chart | | • | • | •
Wall, United States - 2005^77^ | Simple before-after | Statistical process control chart | | • | • | • | •
DePalo, United States - 2010^67^ | Simple before-after | Mixed model with Poisson distribution | | • | • | •
Pronovost, United States - 2010^46^ | Simple before-after | Generalized linear latent and mixed model with Poisson distribution | | • | • | • | • | | •
Render, United States - 2011^71^ | Simple before-after | Poisson GEE regression | 2006: (681) 2007: (683) 2008: (543) 2009: (404) | • | • | • | •
Zingg, Switzerland - 2009^68^ | Simple before-after | Cox proportional hazards model | pre: 499 (24) post: 500 (7) | • | •
Barrera, Colombia - 2011^48^ | Simple before-after | Poisson regression | total: 14,516 (total # HAI: 2,398) | | | • | | •
Kim, United States - 2011^72^ | Simple before-after | Poisson regression | pre: (275) post: (50) | • | • | • | •
Harris, United States - 2011^74^ | Simple before-after | Logistic regression | pre: 817 (31) intervention: 601 (19) post: 961 (15) | • | • | • | •
Seguin, France - 2010^69^ | Simple before-after | Poisson regression | pre: 676 (12) post: 595 (2) | | | | •
Duane, United States - 2009^70^ | Simple before-after | Poisson regression | pre: 135 (19) post: 213 (13) | • | • | | •
Yoo, Korea - 2001^78^ | Simple before-after | Logistic regression | pre: 100 post: 148 | • | • | • | •
Taylor, United States - 2011^73^ | Simple before-after | Cox regression | pre: 100 (23) post: 100 (24) | • | •
Schulman, United States - 2011^59^ | Simple before-after | Stepwise Poisson regression | | • | • | | •
Burrell, Australia - 2011^75^ | Simple before-after | Logistic regression | | • | | • | •

There was 2 cluster randomized, controlled trials,58,60 1 nonrandomized stepped-wedge study,53 3 controlled before-after studies,61-63 1 controlled interrupted time series,49 3 interrupted time series,45,64,65 and 16 simple before-after studies.46,48,59,66-78 One study implemented five quality improvement (QI) strategies,45 10 studies implemented four QI strategies,46,49,65,66,71,72,74,75,77,78 6 studies implemented three QI strategies,58,59,64,67,70,76, 5 studies implemented two QI strategies,48,53,60,68,73 and 4 studies implemented one QI strategy.61-63,69 Twenty two of 26 studies implemented provider education.45,46,49,58-68,70-74,76-78 Organizational change was implemented in 20 studies.45,46,49,53,59,60,64-68,70-78Table 7 shows the specific attributes of organizational change that were implemented for each study. Fifteen studies implemented a provider reminder system.45,46,49,58,59,65,66,69-72,74,75,77,78 Audit and feedback was implemented in 17 studies.45,46,48,49,53,58,64-67,71,72,74-78 Two studies45,46 were subject to financial incentives, regulation, and policy and another study implemented patient education.48

Table 7 Specific attributes of organizational change implemented in CLABSI articles that control for confounding or secular trend

Author, Country-Publication Year | Multidisciplinary Team | Team Responsibilities | Hospital Executives on Team | New Protocol or Standards Implemented | Designate Staff Member Responsible for Implementation
Speroff, United States - 2011^60^ | | | | •
Lilly, United States - 2011^53^ | | | | •
Apisarnthanarak, Thailand - 2010^64^ | • | Conduct education program, track patients with CVC, monitor adherence with new protocol | | •
Costello, United States - 2008^45^ | • | Track nosocomial infections prospectively, to increase awareness of nosocomial infections, to provide education for staff members, and to implement practices changes when indicated | • | • | •
Miller, United States - 2010^65^/105 | • | Test and implement QI changes to their care practices commensurate with the National Association of Children's Hospitals and Related Institutions (NACHRI) collaborative's recommended CVC guidelines | • | • | •
McKee, United States - 2008^66^ | • | Lead team rounds on all PICU patients daily to review patient information and develop a daily care plan | • | • | •
DePalo, United States - 2010^67^ | • | Educate staff on evidence-based practices and help implement CLABSI and VAP bundle | | •
Pronovost, United States - 2010^46^ | • | Ensure accurate reporting of CLABSI within the ICU and implementation of conceptual model stressing CDC guidelines for reduction in BSI. Education of physicians and creation on central line cart. | • | • | •
Render, United States - 2011^71^ | | | | •
Zingg, Switzerland - 2009^68^ | | | | • | •
Kim, United States - 2011^72^ | | | | •
Harris, United States - 2011^74^ | • | Led the development of the interventions through the Six Sigma method
Duane, United States - 2009^70^ | | | | • | •
Taylor, United States - 2011^73^ | • | The team placed and managed all central lines in the hospital. | | • | •
Schulman, United States - 2011^59^ | • | To identify bundle elements that were pertinent for the NICU to prevent CLABSI and to implement these items. | • | • | •

One study58 analyzed adherence rates only, 16 studies46,49,53,60-63,66,67,71-74,76-78 analyzed infection rates only, and 9 studies analyzed both adherence and infection rates.45,48,59,64,65,68-70,75

Eight studies46,58-60,65,67,71,75 were conducted in multiple sites while the other 18^45,48,49,53,61-64,66,68-70,72-74,76-78^ took place in a single tertiary and/or university affiliated hospital. Number of ICUs involved in each study ranged from one to 103. Three studies were statewide initiatives.46,65,67 Eighteen studies45,46,49,53,59-61,63,65-67,70-74,76,77 were conducted in the United States, 3^62,68,69^ in Europe, 1^58^ in Canada, 1^78^ in Korea, 1^64^ in Thailand, 1 in Colombia,48 and 1^75^ in Australia.

The sample size for the postintervention period ranged from 50 patients to 4,671 patients, with many studies not reporting sample size. Infection rates during the postintervention period ranged from 0 to 7.7 infections per 1,000 catheter-days. Baseline infection rates ranged from 1.84 to 17 infections per 1,000 catheter-days.

The search also identified 27 studies that addressed prevention of CLABSI, but did not control for confounding or secular trend (Appendix Table F2).54,79-104 These studies are not included in the analysis due to their weak designs and potential for biased results.

#### Methodological Quality of Included Studies

As displayed in Table 8, 1 study60 was rated of higher quality, 9 studies45,49,53,58,61-65 were rated medium quality, and 16^46,48,59,66-78^ lower quality. Seventeen studies had data for longer than 1 year after the intervention.45,46,48,49,60,63-67,71-77 Twenty studies were considered to have adequate control for confounding or secular trend.45,46,48,53,58-60,63-74,78 Six studies45,48,53,64,68,69 analyzed both adherence rates and infection rates. Only 2 studies46,62 explicitly report being independent of other QI efforts; this dimension was not applicable for the randomized, controlled trials.58,60

Table 8 Methodological quality for CLABSI articles that control for confounding or secular trend

Author, Location-Year | Study Type | Sufficient followup^a^ | Adequate control for confounding or secular trend^b^ | Change in adherence was analyzed^c^ | Change in infection rate was analyzed^d^ | Independent of other QI effort^e^ | Overall quality rating | Comments
Scales, Canada - 2011^58^ | Cluster RCT | - | + | + | - | N/A | Medium | Infection rates were not reported.
Speroff, United States - 2011^60^ | Cluster RCT | + | + | - | + | N/A | Higher | Adherence rates were calculated by followup survey, no baseline data.
Lilly, United States - 2011^53^ | Nonrandomized Stepped wedge | - | + | + | + | ? | Medium | Only 3 of the 7 ICUs had followup one or more yrs
Berenholtz, United States - 2004^49^ | Controlled interrupted time series | + | - | - | + | ? | Medium | The control group received education. Did not compare patient characteristics between the intervention and control ICU or the baseline and postintervention periods.
Khouli, United States - 2011^61^ | Controlled before-after | - | - | - | + | ? | Medium | Adherence rates were not reported.
Perez Parra, Spain - 2010^62^ | Controlled before-after | - | - | - | + | + | Medium | Adherence rates were not reported.
Barsuk, United States - 2009^63^ | Controlled before-after | + | + | - | + | - | Medium | Adherence rates were not reported.
Apisarnthanarak, Thailand - 2010^64^ | Interrupted time series | + | + | + | + | - | Medium
Costello, United States - 2008^45^ | Interrupted time series | + | + | + | + | ? | Medium
Miller, United States - 2010^65^/105 | Interrupted time series | + | + | - | + | ? | Medium | Adherence rates were reported, but no pre/post statistical comparisons were made.
McKee, United States - 2008^66^ | Simple before-after | + | + | - | + | ? | Lower | Adherence rates were reported, but no pre/post statistical comparisons were made.
Frankel, United States - 2005^76^ | Simple before-after | + | - | - | + | ? | Lower | Used antibiotic-coated catheters in a subset of high risk patients roughly 1 year after starting the Six Sigma program. Did not compare patient characteristics between the baseline and postintervention periods.
Wall, United States - 2005^77^ | Simple before-after | + | - | - | + | ? | Lower | Did not compare patient characteristics between the baseline and postintervention periods.
DePalo, United States - 2010^67^ | Simple before-after | + | + | - | + | - | Lower | Adherence rates were not reported.
Pronovost, United States - 2010^46^ | Simple before-after | + | + | - | + | + | Lower | Adherence rates were not reported.
Render, United States - 2011^71^ | Simple before-after | + | + | - | + | ? | Lower | Adherence rates were reported, but no pre/post statistical comparisons were made, but there was an observed inverse correlation between CLABSI rate and overall bundle compliance.
Zingg, Switzerland - 2009^68^ | Simple before-after | - | + | + | + | ? | Lower
Barrera, Colombia – 2011^48^ | Simple before-after | + | + | + | + | ? | Lower | simple before-after study that controlled for potential confounders
Kim, United States - 2011^72^ | Simple before-after | + | + | - | + | ? | Lower
Harris, United States - 2011^74^ | Simple before-after | + | + | - | + | ? | Lower
Seguin, France - 2010^69^ | Simple before-after | - | + | + | + | ? | Lower
Duane, United States - 2009^70^ | Simple before-after | ? | + | - | + | - | Lower | Adherence rates were reported, but no pre/post statistical comparisons were made.
Yoo, Korea - 2001^78^ | Simple before-after | - | + | - | + | ? | Lower | Followup was only 3.5 months.
Taylor, United States - 2011^73^ | Simple before-after | + | + | - | + | ? | Lower | No adherence rates reported. Infection risk was reported rather than infection rates.
Schulman, United States - 2011^59^ | Simple before-after | - | + | - | + | ? | Lower | Adherence rates were reported, but no pre/post statistical comparisons were made.
Burrell, Australia – 2011^75^ | Simple before-after | + | - | - | - | ? | Lower | Study uses a ‘lead in period’, 1 year from start of intervention, in place of baseline data. This data is compared to last 6 months of followup. Analysis did -t control for patient factors across the 37 ICUs.

Note: All studies used standard and consistent infection definitions. CDC methodology was used in all studies except Seguin et al. (2010).68

Infection rates were adjusted for device utilization in all studies.

Independence from other QI efforts was not applicable for randomized controlled trials

a Is the length of followup sufficient (at least 12 months) to support the evaluation of primary outcomes and harms?

b Were adequate measures taken to control for confounding or secular trend?

c Was change in adherence analyzed?

d Was change in infection rate analyzed?

e Was the intervention performed independent of other QI efforts or other changes?

‘+’ means ‘yes’

‘-’ means ‘no’

‘?’ means ‘uncertain’

#### Descriptions of Studies That Control for Confounding and Secular Trend

##### Controlled Studies

###### Scales et al. (2011)58

###### Summary

In a cluster randomized controlled trial, Scales et al. used audit and feedback, provider education, and provider reminder systems to change adherence to six preventive interventions.58 Control ICUs implemented a preventive intervention for a different condition. The study was conducted in 15 community hospital ICUs in Canada, and the duration of the each intervention period was 4 months. This cluster randomized, controlled trial found a significant improvement in adherence to a central line insertion bundle. This study did not report infection rates.

###### Description

The objective of this study was to increase delivery of six practices to improve ICU outcomes for five clinical conditions, including preventive interventions to reduce CLABSI. The five conditions were CLABSI, VAP, deep venous thrombosis, early enteral feeding, and decubitus ulcers. The ICUs were randomized into two groups. Each group was assigned an active intervention targeting a new preventive intervention every 4 months, while serving as control for another, unrelated practice. Thus, one group of ICUs received the intervention to improve adherence to a central line insertion bundle, while another ICU was receiving the intervention for spontaneous breathing trials. The ICU receiving the active intervention for spontaneous breathing trials served as the control unit for central line insertion bundle. After the 12-month study period, control ICUs received the interventions they served as controls for in 3-month blocks. This period was called the decay monitoring period.

Adherence was analyzed as the odds ratio (OR) for improvement in adoption of the preventive intervention by comparing rates in the first month to the fourth month; the two groups were then compared using the summary ratio of ORs.

###### Results and Limitations

Considering all six preventive interventions, patients in ICUs receiving the active intervention were more likely to receive the preventive interventions than those in the control ICUs; summary ratio of odds ratios 2.79 (95% CI: 1.00 to 7.74; p=0.05; Table 9). Adherence to the central line insertion bundle was the only preventive intervention that had a significant improvement. In the intervention ICUs, adherence significantly improved from 10 percent in the first month of the study period to 70.6 percent in the last month of the study period (OR: 30.1; 95% CI: 11.0 to 82.2; p<0.001). The control ICUs had a nonsignificant change in rates of adherence from the first to last month of the study period with adherence rates of 31.0 percent and 51.7 percent, respectively (OR: 1.71; 95% CI: 0.74 to 3.99; p=0.21). When comparing intervention ICUs with control ICUs, the intervention ICUs had a significant improvement in adherence to the central line insertion bundle (summary OR: 17.55; 95% CI: 4.72 to 65.26; p<0.001).

Table 9 Outcomes for CLABSI articles that control for confounding or secular trend

Author, country-year | Intervention/ Comparator | Type of outcome | Specific measure | Improve | Worsen | NS | Change in specific measure | Comments
Scales, Canada - 2011^58^ | Telemedicine Knowledge Translation program/ Active Control Group | Adherence | Overall insertion bundle | ⋄ | | | Control: 30.0% → 51.7% Intervention: 10.0% → 70.6% (p=0.02) Ratio of ORs: 17.55 (95% CI: 4.72 to 65.26; p<0.001) | Reflects ratio of odds ratio.
Scales, Canada - 2011^58^ | Telemedicine Knowledge Translation program/ Active Control Group | Infection Rate | | | | | | Reflects ratio of odds ratio.
Scales, Canada - 2011^58^ | Telemedicine Knowledge Translation program/ Active Control Group | Costs/Savings | | | | | | Reflects ratio of odds ratio.
Speroff, United States - 2011^60^ | Virtual Collaborative Group/Toolkit Group | Adherence | Prevention Strategy Use | ⋄ | | | Virtual Collaborative: 69% Toolkit Group: 54% (p=0.017) | Use of tools and strategies was accomplished by followup survey. Clinical tools were used 61% by the Virtual Collaborative group and 49% by the Toolkit group (p=0.23). Data tools were used 56% by the Virtual Collaborative group and 30% by the Toolkit group (p=0.004).
Speroff, United States - 2011^60^ | Virtual Collaborative Group/Toolkit Group | Infection | Overall | | | • | Median Virtual Collaborative: 1.84 (IQR, 0.00 to 3.83) → 2.76 (IQR, 0.00 to 4.67) Median Toolkit: 2.42 (IQR, 0.65 to 6.80) → 1.16 (IQR, 0.00 to 5.46)
Speroff, United States - 2011^60^ | Virtual Collaborative Group/Toolkit Group | Cost/Savings
Lilly, United States - 2011^53^ | Tele-ICU (providing care from a remote location)/ Provider education and checklist for best practices | Adherence | | | | | | The tele-ICU group was significantly older, sicker, and was not mechanically ventilated or a postoperative case as often as the baseline group. It is unclear if these covariates were taken into account for the outcomes of interest.
Lilly, United States - 2011^53^ | Tele-ICU (providing care from a remote location)/ Provider education and checklist for best practices | Infection | Overall | • | | | 1% → 0.6% (OR=0.50; 95% CI: 0.27 to 0.93; p=0.005)
Lilly, United States - 2011^53^ | Tele-ICU (providing care from a remote location)/ Provider education and checklist for best practices | Cost/Savings
Berenholtz, United States - 2004^49^ | Education, CVC cart, nurse empowerment, checklist, and daily assessment of need/ Education only | Adherence | | | | | | During the first month, 32% (12/38) of the checklists used required a nurse intervention. There was no significant difference in the slopes before the interventions were implemented (p=0.80). There does not seem to be a comparison of the slopes after the initiation of the initiative.
Berenholtz, United States - 2004^49^ | Education, CVC cart, nurse empowerment, checklist, and daily assessment of need/ Education only | Infection Rate | Overall | • | | | Control: 5.7 → 1.6 (slope p=0.56) Intervention: 11.3 → 0 (slope p<0.001)
Berenholtz, United States - 2004^49^ | Education, CVC cart, nurse empowerment, checklist, and daily assessment of need/ Education only | Costs/Savings | Annual additional cost savings | | | | $1,945,922 ($1,483,844-$2,408,000)
Khouli, United States - 2011^61^ | Simulation-based sterile technique training/ Video-based training (usual care) | Adherence
Khouli, United States - 2011^61^ | Simulation-based sterile technique training/ Video-based training (usual care) | Infection Rate | Overall MICU | • | | | Mean: 3.5 → 1.0
Khouli, United States - 2011^61^ | Simulation-based sterile technique training/ Video-based training (usual care) | Infection Rate | Overall SICU (Control) | | | • | Mean: 3.6 → 3.4
Khouli, United States - 2011^61^ | Simulation-based sterile technique training/ Video-based training (usual care) | Infection Rate | MICU vs. SICU | • | | | IRR: 0.30 (95% CI: 0.10 to 0.91, p=0.03)
Khouli, United States - 2011^61^ | Simulation-based sterile technique training/ Video-based training (usual care) | Costs/Savings
Perez Parra, Spain - 2010^62^ | Educational Intervention/ No Intervention (usual care) | Adherence | | | | | | VAP rates were used as a control. P-value for overall CLABSI rate reflects Poisson regression findings. VAP rates were not analyzed, but incidence did increase.
Perez Parra, Spain - 2010^62^ | Educational Intervention/ No Intervention (usual care) | Infection Rate | Overall CLABSI | | | • | Mean: 4.22 → 2.94 (p=0.11) | VAP rates were used as a control. P-value for overall CLABSI rate reflects Poisson regression findings. VAP rates were not analyzed, but incidence did increase.
Perez Parra, Spain - 2010^62^ | Educational Intervention/ No Intervention (usual care) | Infection Rate | General surgery ICU CLABSI | • | | | Mean: 5.3 → 3.4 (p=0.05) | VAP rates were used as a control. P-value for overall CLABSI rate reflects Poisson regression findings. VAP rates were not analyzed, but incidence did increase.
Perez Parra, Spain - 2010^62^ | Educational Intervention/ No Intervention (usual care) | Infection Rate | Cardiac surgery ICU CLABSI | | | • | Mean: 4.2 → 2.7 (p=0.12) | VAP rates were used as a control. P-value for overall CLABSI rate reflects Poisson regression findings. VAP rates were not analyzed, but incidence did increase.
Perez Parra, Spain - 2010^62^ | Educational Intervention/ No Intervention (usual care) | Infection Rate | Medical ICU CLABSI | | | • | Mean: 3.4 → 2.6 (p=0.31) | VAP rates were used as a control. P-value for overall CLABSI rate reflects Poisson regression findings. VAP rates were not analyzed, but incidence did increase.
Perez Parra, Spain - 2010^62^ | Educational Intervention/ No Intervention (usual care) | Infection Rate | Overall VAP (Control)^a^ | | | | Mean: 13.34 → 15.82 | VAP rates were used as a control. P-value for overall CLABSI rate reflects Poisson regression findings. VAP rates were not analyzed, but incidence did increase.
Perez Parra, Spain - 2010^62^ | Educational Intervention/ No Intervention (usual care) | Costs/Savings | | | | | | VAP rates were used as a control. P-value for overall CLABSI rate reflects Poisson regression findings. VAP rates were not analyzed, but incidence did increase.
Barsuk, United States - 2009^63^ | Simulation Training in CLABSI reduction/No Intervention (usual care) | Adherence | | | | | | SICU served as control unit.
Barsuk, United States - 2009^63^ | Simulation Training in CLABSI reduction/No Intervention (usual care) | Infection Rate | Overall MICU | • | | | Mean: 3.20 → 0.5 | SICU served as control unit.
Barsuk, United States - 2009^63^ | Simulation Training in CLABSI reduction/No Intervention (usual care) | Infection Rate | Overall SICU (Control) | | | • | Mean: 4.86 → 5.26 | SICU served as control unit.
Barsuk, United States - 2009^63^ | Simulation Training in CLABSI reduction/No Intervention (usual care) | Infection Rate | MICU vs. SICU | • | | | IRR: 0.16 (95% CI: 0.05 to0.44; p=0.001) | SICU served as control unit.
Barsuk, United States - 2009^63^ | Simulation Training in CLABSI reduction/No Intervention (usual care) | Costs/Savings | | | | | | SICU served as control unit.
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Adherence | Period 2 and 3 vs. period 1 maximal sterile barrier | ⋄ | | | Period 1 vs. Period 2: 45% → 80% (p<0.05) Period 1 vs. Period 3: 45% → 81% (p<0.05) | Period 1=12 mos (baseline period), Period 2=12 mos (bundle implementation), Period 3=12 mos (bundle implementation + intensified hand hygiene promotion). Level of significance reflects the change in level, not change in slope from segmented regression. Other units included orthopedics, obstetrics/gynecology, and general practice.
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Adherence | Period 2 and 3 vs. period 1 chlorhexidine skin prep | ⋄ | | | Period 1 vs. Period 2: 42% → 75% (p<0.05) Period 1 vs. Period 3: 42% → 77% (p<0.05)
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Adherence | Period 2 and 3 vs. period 1 avoid femoral vein insertion | ⋄ | | | Period 1 vs. Period 2: 50% → 64% (p<0.05) Period 1 vs. Period 3: 50% → 66% (p<0.05)
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Adherence | Period 2 and 3 vs. period 1 overall hand hygiene | ⋄ | | | Period 1 vs. Period 2: 8% → 24% (p<0.05) Period 1 vs. Period 3: 8% → 53% (p<0.05)
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Infection Rate | Medical Ward period 1 vs. period 2 | • | | | Mean: 16 → 6.8 (p=0.03)
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Infection Rate | Medical Ward period 2 vs. period 3 | • | | | Mean: 6.8 → 1.5 (p=0.02)
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Infection Rate | Surgical Ward period 1 vs. period 2 | • | | | Mean: 11 → 5.5 (p=0.001)
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Infection Rate | Surgical Ward period 2 vs. period 3 | • | | | Mean: 5.5 → 0.8 (p=0.05)
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Infection Rate | ICU period 1 vs. period 2 | • | | | Mean: 17 → 7.1 (p=0.005)
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Infection Rate | ICU period 2 vs. period 3 | • | | | Mean: 7.1 → 2.1 (p=0.001)
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Infection Rate | Other Units period 1 vs. period 2 | • | | | Mean: 9 → 5.2 (p=0.04)
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Infection Rate | Other Units period 2 vs. period 3 | | | • | Mean: 5.2 → 0.9 (p=0.14)
Apisarnthanarak, Thailand - 2010^64^ | Period 3: CLABSI bundle + intensified hand hygiene promotion/ Period 1: No Intervention (usual care) Period 2: Bundle - CLABSI | Costs/Savings
Costello, United States - 2008^45^ | Full Intervention: Pediatric Multidisciplinary CLABSI Bundle/ Baseline: Low intensity intervention Partial Intervention: Central venous line (CVL) insertion bundle, CVL access bundle, and CVL maintenance bundle | Adherence | Partial vs. Full Intervention CVL Insertion Bundle | ⋄ | | | 87% → 94% (p<0.001)
Costello, United States - 2008^45^ | | Adherence | Partial vs. Full Intervention CVL Maintenance Bundle | ⋄ | | | 85% → 99% (p=0.004)
Costello, United States - 2008^45^ | | Adherence | Baseline vs. Full Intervention Hand Hygiene | ⋄ | | | 38% → 85.5% (p<0.001)
Costello, United States - 2008^45^ | | Infection Rate | Partial Intervention | • | | | Mean: 7.8 → 4.7 (p=0.029)
Costello, United States - 2008^45^ | | Infection Rate | Full Intervention | • | | | Mean: 7.8 → 2.3 (p=0.0002)
Costello, United States - 2008^45^ | | Costs/Savings | Annual attributable cost savings^a^ | | | | $236,000 to $782,000
Miller, United States - 2010^65^/105 | Bundle - CLABSI/ No Intervention (usual care) | Adherence | Insertion bundle^a^ | | | | 80% → 89%^b^ | After adjusting for region and PICU demographics, the maintenance bundle adherence was the only significant predictor for CLABSI, p=0.017.
Miller, United States - 2010^65^/105 | Bundle - CLABSI/ No Intervention (usual care) | Adherence | Maintenance bundle^a^ | | | | 65% → 85%^b^ | After adjusting for region and PICU demographics, the maintenance bundle adherence was the only significant predictor for CLABSI, p=0.017.
Miller, United States - 2010^65^/105 | Bundle - CLABSI/ No Intervention (usual care) | Infection Rate | Overall | • | | | Mean: 5.4 → 3.1 (p<0.0001) | After adjusting for region and PICU demographics, the maintenance bundle adherence was the only significant predictor for CLABSI, p=0.017.
Miller, United States - 2010^65^/105 | Bundle - CLABSI/ No Intervention (usual care) | Costs/Savings | | | | | | After adjusting for region and PICU demographics, the maintenance bundle adherence was the only significant predictor for CLABSI, p=0.017.
McKee, United States - 2008^66^ | CLABSI education, cart, checklist, and nurse empowerment/No Intervention (usual care) | Adherence | Catheter insertion checklist^a^ | | | | | Percent of cases that needed prompting from a nurse was reported. Using statistical process control chart, infection rates marginally improve over the study period, p=0.07. Poisson regression showed significant improvement in infection rates in the post-intervention phase.
McKee, United States - 2008^66^ | CLABSI education, cart, checklist, and nurse empowerment/No Intervention (usual care) | Infection Rate | Overall | | | • | Mean: 5.2 → 2.7 (p<0.05)
McKee, United States - 2008^66^ | CLABSI education, cart, checklist, and nurse empowerment/No Intervention (usual care) | Costs/Savings
Frankel, United States - 2005^76^ | Six Sigma Performance Improvement/No Intervention (usual care) | Adherence | | | | | | Used a statistical process control chart to evaluate the effectiveness of the intervention.
Frankel, United States - 2005^76^ | Six Sigma Performance Improvement/No Intervention (usual care) | Infection Rate | Overall | • | | | 11 → 1.7 (p<0.0001) | Used a statistical process control chart to evaluate the effectiveness of the intervention.
Frankel, United States - 2005^76^ | Six Sigma Performance Improvement/No Intervention (usual care) | Infection Rate | Catheters placed between infections | | | | 27 → 175 | Used a statistical process control chart to evaluate the effectiveness of the intervention.
Frankel, United States - 2005^76^ | Six Sigma Performance Improvement/No Intervention (usual care) | Costs/Savings | Annual cost reduction minus cost of insertion kits and antibiotic coated catheters | | | | $61,000 | Used a statistical process control chart to evaluate the effectiveness of the intervention.
Wall, United States - 2005^77^ | Continuous quality improvement (CQI) methodology with nurse checklist, provider education, and progress reports/No Intervention (usual care) | Adherence | Hand hygiene | | | | 72% → 89%^b^ | Used a statistical process control chart to evaluate the effectiveness of the intervention. Points above the upper control limit occurred 3 of 6 times after the intervention.
Wall, United States - 2005^77^ | Continuous quality improvement (CQI) methodology with nurse checklist, provider education, and progress reports/No Intervention (usual care) | Adherence | Chlorhexidine prep | | | | 58% → 100%^b^ | Used a statistical process control chart to evaluate the effectiveness of the intervention. Points above the upper control limit occurred 3 of 6 times after the intervention.
Wall, United States - 2005^77^ | Continuous quality improvement (CQI) methodology with nurse checklist, provider education, and progress reports/No Intervention (usual care) | Adherence | Maximal sterile barriers | | | | 68% → 87%^b^ | Used a statistical process control chart to evaluate the effectiveness of the intervention. Points above the upper control limit occurred 3 of 6 times after the intervention.
Wall, United States - 2005^77^ | Continuous quality improvement (CQI) methodology with nurse checklist, provider education, and progress reports/No Intervention (usual care) | Adherence | Guidewire exchange | | | | 19% → 19%^b^ | Used a statistical process control chart to evaluate the effectiveness of the intervention. Points above the upper control limit occurred 3 of 6 times after the intervention.
Wall, United States - 2005^77^ | Continuous quality improvement (CQI) methodology with nurse checklist, provider education, and progress reports/No Intervention (usual care) | Infection Rate | Overall | • | | | 7.0 → 3.8 | Used a statistical process control chart to evaluate the effectiveness of the intervention. Points above the upper control limit occurred 3 of 6 times after the intervention.
Wall, United States - 2005^77^ | Continuous quality improvement (CQI) methodology with nurse checklist, provider education, and progress reports/No Intervention (usual care) | Costs/Savings | | | | | | Used a statistical process control chart to evaluate the effectiveness of the intervention. Points above the upper control limit occurred 3 of 6 times after the intervention.
DePalo, United States - 2010^67^ | CLABSI education program and bundle/ No Intervention (usual care) | Adherence | | | | | | Infection rate was adjusted for hospital size, teaching status, and device-days. Cost savings was calculated using number of lives saved and reduction in ICU days.
DePalo, United States - 2010^67^ | CLABSI education program and bundle/ No Intervention (usual care) | Infection Rate | Overall | • | | | Mean: 3.73 → 0.97 (p=0.003) | Infection rate was adjusted for hospital size, teaching status, and device-days. Cost savings was calculated using number of lives saved and reduction in ICU days.
DePalo, United States - 2010^67^ | CLABSI education program and bundle/ No Intervention (usual care) | Costs/Savings | Cumulative cost savings^a^ | | | | $2,016,592 | Infection rate was adjusted for hospital size, teaching status, and device-days. Cost savings was calculated using number of lives saved and reduction in ICU days.
Pronovost, United States - 2010^46^ | Keystone ICU Project/ No Intervention (usual care) | Adherence | | | | | | Evaluation period=0-18 mos after implementation, Sustainability period=19-36 mos after implementation. Adjusted for clustering within ICUs, hospitals, and regions as well as teaching status and hospital size.
Pronovost, United States - 2010^46^ | Keystone ICU Project/ No Intervention (usual care) | Infection Rate | Evaluation Period vs. baseline | • | | | Mean: 7.7 → 1.3 IRR: 0.38 (95% CI: 0.26 to 0.56, p<0.05)
Pronovost, United States - 2010^46^ | Keystone ICU Project/ No Intervention (usual care) | Infection Rate | Sustainability Period vs. baseline | • | | | Mean: 7.7 → 1.1 IRR: 0.34 (95% CI: 0.24 to 0.48, p<0.05)
Pronovost, United States - 2010^46^ | Keystone ICU Project/ No Intervention (usual care) | Costs/Savings
Render, United States - 2011^71^ | CLABSI Bundle collaboration among VA hospitals/ No Intervention (usual care) | Adherence | Complete bundle | | | | 85% → 98% | Adherence to the CLABSI bundle had a strong inverse correlation with CLABSI rates (R2=-0.81). Rates for each bundle item were also reported, but adherence was not analyzed. All results compared to 2006 group. 2007: IRR=0.83; 95% CI: 0.73 to 0.94; p=0.0033 2008: IRR=0.65; 95% CI: 0.56 to 0.76; p<0.0001 2009: IRR=0.47; 95% CI: 0.40 to 0.55; p<0.0001 Four of six hospitals with highest rates took part in mentoring and reduced rates by 53% from 2007 to 2008.
Render, United States - 2011^71^ | CLABSI Bundle collaboration among VA hospitals/ No Intervention (usual care) | Infection | Overall | • | | | Mean: 3.84 → 3.19 → 2.44 → 1.85 (all p<0.004)
Render, United States - 2011^71^ | CLABSI Bundle collaboration among VA hospitals/ No Intervention (usual care) | Cost/Savings
Zingg, Switzerland - 2009^68^ | Educational Program for catheter care and hand hygiene/ No Intervention (usual care) | Adherence | Overall hand hygiene | | | ⋄ | 59.1% → 65% (p=0.466) | Patients in the baseline period were significantly more at risk of CLASBI than those in the postintervention period.
Zingg, Switzerland - 2009^68^ | Educational Program for catheter care and hand hygiene/ No Intervention (usual care) | Adherence | Proper hand disinfection before and after patient contact | ⋄ | | | 22.5% → 42.6% (p=0.003) | Patients in the baseline period were significantly more at risk of CLASBI than those in the postintervention period.
Zingg, Switzerland - 2009^68^ | Educational Program for catheter care and hand hygiene/ No Intervention (usual care) | Infection Rate | Risk of CLABSI | • | | | 3.9 → 1.0 HR: 4.47 (95% CI: 1.86 to 10.2, p<0.001) | Patients in the baseline period were significantly more at risk of CLASBI than those in the postintervention period.
Zingg, Switzerland - 2009^68^ | Educational Program for catheter care and hand hygiene/ No Intervention (usual care) | Infection Rate | Time to CLABSI | • | | | 6.5 days → 9 days (p=0.02) | Patients in the baseline period were significantly more at risk of CLASBI than those in the postintervention period.
Zingg, Switzerland - 2009^68^ | Educational Program for catheter care and hand hygiene/ No Intervention (usual care) | Costs/Savings | | | | | | Patients in the baseline period were significantly more at risk of CLASBI than those in the postintervention period.
Barrera, Colombia - 2011^48^ | Hand hygiene promotion/ No Intervention (usual care) | Adherence | ABHR use | ⋄ | | | 9.2% annual increase (p<0.001) | CLABSI significantly decreased 12.7% annually. ABHR use is an indirect measure of hand hygiene. Infection rates were controlled for temporary workers and nurse-to-patient ratio. Nurse-to-patient ratio was an independent risk factor for CLABSI (IRR=1.11; 95% CI: 1.07 to 1.16; p<0.001).
Barrera, Colombia - 2011^48^ | Hand hygiene promotion/ No Intervention (usual care) | Infection | Overall | • | | | 12 → 7 (IRR=0.89; 95% CI: 0.80 to 0.98; p=0.015)^a^
Barrera, Colombia - 2011^48^ | Hand hygiene promotion/ No Intervention (usual care) | Cost/Savings
Kim, United States - 2011^72^ | CLABSI bundle with cart/ No Intervention (usual care) | Adherence | | | | | | Total excess cost of CLABSI, regardless of organism, was estimated to be $32,254 (excess LOS + replacement CVL + drug admin cost + drug cost) Authors felt cost of CLABSI bundle was negligible since cart cost $100 for each unit, and staff and equipment already in place.
Kim, United States - 2011^72^ | CLABSI bundle with cart/ No Intervention (usual care) | Infection | Total | • | | | 9 → 2.7 (RRR=0.70; 95% CI: 0.59 to 0.77; p<0.00001)
Kim, United States - 2011^72^ | CLABSI bundle with cart/ No Intervention (usual care) | | MICU | • | | | 13.9 → 3.1 (RRR=0.78; 95% CI: 0.66 to 0.85; p<0.0001)
Kim, United States - 2011^72^ | CLABSI bundle with cart/ No Intervention (usual care) | | SICU | • | | | 4.5 → 1.9 (RRR=0.59; 95% CI: 0.11 to 0.81; p=0.01)
Kim, United States - 2011^72^ | CLABSI bundle with cart/ No Intervention (usual care) | | CTICU | | | • | 1.8 → 1.4 (RRR=0.28; 95% CI: -3.3 to 0.88; p=0.36)
Kim, United States - 2011^72^ | CLABSI bundle with cart/ No Intervention (usual care) | | Burn ICU | • | | | 5.2 → 1.2 (RRR=0.76; 95% CI: -0.01 to 0.94; p=0.02)
Kim, United States - 2011^72^ | CLABSI bundle with cart/ No Intervention (usual care) | | Neuro ICU | | | • | 7 → 3.8 (RRR=0.45; 95% CI: -0.30 to 0.77; p=0.08)
Kim, United States - 2011^72^ | CLABSI bundle with cart/ No Intervention (usual care) | | CCU | | | • | 8.5 → 5.4 (RRR=0.36; 95% CI: -0.65 to 0.75; p=0.18)
Kim, United States - 2011^72^ | CLABSI bundle with cart/ No Intervention (usual care) | Cost/Savings
Harris, United States - 2011^74^ | Hand hygiene, VAP bundle, standardizing central line care/ No Intervention (usual care) | Adherence | | | | | | Outcomes were adjusted for patient's age, sex, and race as well as insurance coverage, comorbidities, and specialty of treating physician. The adjusted average PICU cost during the intervention period was -$3,948 (95% CI: -$10,678 to $2,782). The adjusted average PICU cost during the postintervention period was -$8,826 (95% CI: -$13,950 to -$3,702). The adjusted average cost per hospital stay during the postintervention period was -$12,136 (95% CI: -$19,058 to -$5,214).
Harris, United States - 2011^74^ | Hand hygiene, VAP bundle, standardizing central line care/ No Intervention (usual care) | Infection | Overall | • | | | 3.8 → 3.1 → 1.6 (OR=0.86; 95% CI: 0.48 to 1.53; OR=0.42; 95% CI: 0.22 to 0.80; p<0.001; compared to baseline)
Harris, United States - 2011^74^ | Hand hygiene, VAP bundle, standardizing central line care/ No Intervention (usual care) | Cost/Savings | Average PICU cost | ⋄ | | | $34,365 (SD $2,446) → $30,175 (SD $2,139) → $25,938 (SD $1,146) (compared to baseline p<0.01)
Harris, United States - 2011^74^ | Hand hygiene, VAP bundle, standardizing central line care/ No Intervention (usual care) | | Average hospital cost of stay | ⋄ | | | $54,323 (SD $3,217) → $46,773 (SD $2727) → $42,071 (SD $1,700) (compared to baseline p<0.01)
Harris, United States - 2011^74^ | Hand hygiene, VAP bundle, standardizing central line care/ No Intervention (usual care) | | Projected annual cost savings | | | | $12 million
Seguin, France - 2010^69^ | Physician reminder of catheter duration/ No Intervention (usual care) | Adherence | Median CVC duration | ⋄ | | | 5 → 4 (p<0.001) | After adjustment for age, SAPS II, and admission diagnosis, change in infection rate is marginally significant, p=0.051.
Seguin, France - 2010^69^ | Physician reminder of catheter duration/ No Intervention (usual care) | Adherence | Median time to CVC removal | ⋄ | | | 9 → 2 (p=0.002) | After adjustment for age, SAPS II, and admission diagnosis, change in infection rate is marginally significant, p=0.051.
Seguin, France - 2010^69^ | Physician reminder of catheter duration/ No Intervention (usual care) | Infection Rate | Overall | | | • | Median: 2.8 → 0.7 (p=0.051) | After adjustment for age, SAPS II, and admission diagnosis, change in infection rate is marginally significant, p=0.051.
Seguin, France - 2010^69^ | Physician reminder of catheter duration/ No Intervention (usual care) | Costs/Savings | | | | | | After adjustment for age, SAPS II, and admission diagnosis, change in infection rate is marginally significant, p=0.051.
Duane, United States - 2009^70^ | Group 3: Central venous line (CVL) protocol + CVL supply cart + nurse education + nurse checklist and nurse empowerment/ Group 1: No Intervention (usual care) Group 2: CVL protocol to reduce catheterization duration + resident education | Adherence | Use of checklist^a^ | | | | 97.6% → 98% → 100% | Lack of CVL protocol and ISS showed to be independent risk factors for CLABSI.
Duane, United States - 2009^70^ | | Infection Rate | Overall | • | | | Mean: 16.5 → 15.0 → 7.7 Group 1 vs. Group 2: (p=0.08) Group 1 vs. Group 3: (p<0.0001) Group 2 vs. Group 3 (p<0.0044) | Lack of CVL protocol and ISS showed to be independent risk factors for CLABSI.
Duane, United States - 2009^70^ | | Costs/Savings | Hospital admissions cost per patient^a^ | | | | Group 2: $19,615.70 decrease compared with Group 1 Group 3: $28,391.87 decrease compared with Group 1 | Lack of CVL protocol and ISS showed to be independent risk factors for CLABSI.
Yoo, Korea - 2001^78^ | Infection control week, daily surveillance with checklist, and suggested correction of catheter care by infection control staff/No Intervention (usual care) | Adherence | | | | | | During the postintervention period, those who had a CLABSI had significantly longer mean duration of catheterization (15 vs. 9.5 days, p<0.01). Duration of ICU admission was found to be a risk factor for CLABSI (OR: 1.05; 95% CI: 1.01 to 1.08; P=0.0008). The intervention period was not found to be associated to CLABSI. There were only 6 infections, 4 during baseline and 2 during postintervention.
Yoo, Korea - 2001^78^ | Infection control week, daily surveillance with checklist, and suggested correction of catheter care by infection control staff/No Intervention (usual care) | Infection Rate | Overall | | | • | 4.2 → 1.3 (p=0.14)
Yoo, Korea - 2001^78^ | Infection control week, daily surveillance with checklist, and suggested correction of catheter care by infection control staff/No Intervention (usual care) | Costs/Savings
Taylor, United States - 2011^73^ | Percutaneously inserted central catheters (PICC) team formed/ No Intervention (usual care) | Adherence | | | | | | In a stratified analysis by tertiles of central line duration patients with a CV for ≥ 30 days had a reduced risk of CLABSI during the intervention period (HR=0.48; 95% CI: 0.25 to 0.91; p=0.025). Other covariates that were associated with decreased CLABSI were postmenstrual age (HR=0.85; 95% CI: 0.25 to 0.91; p=0.025) and fewer respiratory support days (HR=1.01; 95% CI: 1.004 to 1.021; p=0.005).
Taylor, United States - 2011^73^ | Percutaneously inserted central catheters (PICC) team formed/ No Intervention (usual care) | Infection | | | | • | 24% → 23% (p=0.87)
Taylor, United States - 2011^73^ | Percutaneously inserted central catheters (PICC) team formed/ No Intervention (usual care) | Cost/Savings
Schulman, United States - 2011^59^ | Bundle - CLABSI Insertion and Maintenance/ Low Intensity Intervention | Adherence | | | | | | Utilization of maintenance checklist was significantly associated to decrease in CLABSI rate.
Schulman, United States - 2011^59^ | Bundle - CLABSI Insertion and Maintenance/ Low Intensity Intervention | Infection Rate | Overall | • | | | 3.5 → 2.1 (p<0.0005) | Utilization of maintenance checklist was significantly associated to decrease in CLABSI rate.
Schulman, United States - 2011^59^ | Bundle - CLABSI Insertion and Maintenance/ Low Intensity Intervention | Costs/Savings | | | | | | Utilization of maintenance checklist was significantly associated to decrease in CLABSI rate.
Burrell, Australia - 2011^75^ | CLABSI Physician + Patient Bundles/ No Intervention (usual care) | Adherence | Physician bundle | ⋄ | | | 74% → 81% (p<0.0001) | Outcomes were controlled for patient bundle, physician bundle and line-days. Line days (RR=1.05; 95% CI: 1.02 to 1.07; p=0.001) and noncompliance with clinician bundle (RR=2.04; 95% CI: 1.1 to 3.6; p=0.016) were found to be significant risk factors for CLABSI. Risk of CLABSI significantly reduced in patients with CVLs inserted by clinicians compliant with both bundles (RR=0.5; 95% CI: 0.4 to 0.8; p=0.004). CVLs inserted by clinicians that did not adhere to the clinician bundle were more likely to be associated with CLABSI (RR=1.62; 95%CI 1.1 to 2.4 p=0.018).
Burrell, Australia - 2011^75^ | CLABSI Physician + Patient Bundles/ No Intervention (usual care) | Adherence | Patient bundle | ⋄ | | | 81% → 92% (p<0.001)
Burrell, Australia - 2011^75^ | CLABSI Physician + Patient Bundles/ No Intervention (usual care) | Infection | Overall | • | | | 3.0 (95% CI: 2.0 to 4.3) → 1.2 (95% CI: 0.6 to 2.2) (p=0.0006)
Burrell, Australia - 2011^75^ | CLABSI Physician + Patient Bundles/ No Intervention (usual care) | Cost/Savings

Abbreviations: OR = odds ratio; MICU = medical intensive care unit; SICU = surgical intensive care unit; IRR = incidence rate ratio; PICU = pediatric intensive care unit; HR = hazard ratio; SAPS II = simplified acute physiology score II; ISS = Injury Severity Score

• was used for infection rate outcomes

⋄ was used for adherence and costs/savings outcomes

a Reported, but not analyzed

b Numbers were extrapolated from a graph

During the decay monitoring period, the control ICUs did not see a significant improvement in adherence with the insertion bundle. The first month of the decay monitoring period had an adherence rate of 54.3 percent and the last month had 69.2 percent (OR: 2.05; 95% CI: 0.69 to 6.07; p=0.19).

Even though there were over 4,000 admissions in each group of ICUs, there were only 64 catheter insertions analyzed in the intervention group and 61 in the control group. The authors did find a significant result, but there is large variability in the estimate, most likely due to the small number of insertions analyzed.

###### Speroff et al. (2011)60

###### Summary

Speroff et al. conducted a cluster randomized controlled trial comparing the use of a virtual collaborative to a toolkit approach.60 The QI strategies involved were organizational change and provider education. This study was conducted in 60 hospitals across the United States. After 18 months, there was no significant difference in infection rates between the two groups or over time within either group. There were some tools that were used significantly more in the virtual collaborative group compared with the toolkit group.

###### Description

The objective of this study was to prevent CLABSI and VAP in the ICU by improving adherence to evidence-based practices. The authors compared the use of a virtual collaborative approach to a toolkit approach. The toolkit approach entailed access to evidence-based guidelines and fact sheets for preventing CLABSI and VAP, a review of QI and teamwork methods, standardized data collection tools, standardized charting tools, access to a website that contained educational seminars, clinical tools, and QI tools. In addition, the ICU was allowed to implement other changes to prevent CLABSI and VAP. The collaborative group was given everything the toolkit group was given plus the use of web seminars, teleconferences, individual coaching, monthly educational and troubleshooting conference calls, and an email list-serve to encourage communication among teams.

Data were reported in 3-month intervals and analyzed using hierarchical negative binomial regression models in order to account for change over time, clustering of ICUs within hospitals, and baseline characteristics.

###### Results and Limitations

During the baseline period, median CLABSI rates were 1.84 (IQR: 0 to 3.83) and 2.42 (IQR: 0.65 to 6.8) infections per 1,000 catheter-days in the virtual collaborative group and the toolkit group, respectively. After 18 months, the rate in the virtual collaborative group increased to 2.76 (IQR: 0 to 4.67) while the rate in the toolkit group decreased to 1.16 (IQR: 0 to 5.46) infections per 1,000 catheter-days. The regression model found that neither the virtual collaborative group nor the toolkit group improved CLABSI rates (p=0.75 and p=0.83, respectively) and there was no difference between the two groups (p=0.71). However, the virtual collaborative group did use data tools significantly more (p=0.004) and implemented the VAP checklist more than the toolkit group (p=0.007).

The floor effect may have limited the possible improvement among the ICUs in this study. The authors list some contextual factors that may have led to the lack of improvement in the study: slow uptake of data driven quality improvement, lack of infrastructure to implement data driven improvement, and differential uptake of general knowledge and implementation knowledge. Also, giving the toolkit group the ability to implement additional changes at their discretion introduced some bias into the comparison being made.

###### Lilly et al. (2011)53

###### Summary

Lilly et al. conducted a nonrandomized stepped wedge design study in seven ICUs within an academic medical center in the United States.53 Organizational change, provider education, and audit and feedback were implemented. After 15 months of implementation, infection rates significantly improved.

###### Description

Before the initiation of this study the following factors were established: critical care governance, team structure (including intensivist-led closed model), call schedules, interdisciplinary rounds, and staffing models. The focus was on processes of care. Best practices for venous thrombosis, cardiovascular complications, ventilator-associated pneumonia, and stress ulcers were standardized. ICU daily goals and an educational program were initiated before the start of the study.

The study period consisted of initiating the use of a tele-ICU team. The offsite team participated in key critical care delivery 24 hours a day. The team reviewed the care for each patient, conducted real time audit of best practices, performed workstation-assisted care plan reviews, monitored system-generated electronic alerts, audited bedside staff responses to in-room alarms, and intervened when the responses of the bedside staff were delayed and the patient was deemed physiologically unstable. Logistic regression was used to analyze dichotomous outcomes and general linear mixed models were used for continuous outcomes.

###### Results and Limitations

Adherence rates were not analyzed. During the baseline period, the CLABSI rate was 1 percent while in the postintervention period it was 0.6 percent (OR: 0.50; 95% CI: 0.27 to 0.93; p=0.005). The tele-ICU group was significantly older, sicker, and was not mechanically ventilated or a postoperative case as often as the baseline group. Hospital mortality was the primary outcomes for this study and was rigorously analyzed. It does not seem the same level of analysis was applied to the outcomes that this report is interested in.

###### Berenholtz et al. (2004)49

Berenholtz et al.49 conducted a controlled interrupted time series to test the efficacy of a QI strategy including audit and feedback, organizational change, provider education, and provider reminder systems compared to education alone on reducing hospital infection rate. Details of this study are found in the 2007 report.

###### Khouli et al. (2011)61

###### Summary

Khouli et al61 conducted a controlled before-after study to determine the efficacy of simulation-based training with video training versus video training alone of residents. This provider education intervention took place at a university-affiliated hospital in the United States and was followed for 18 months postintervention. Sterile technique improved significantly in the simulation-trained group versus the nonsimulation group. Following this observed improvement, all medical intensive care unit (MICU) residents were trained with this intervention. A comparison of the MICU with the surgical intensive care unit (SICU), which had no video or simulation-based training, showed a significant reduction in the MICU CLABSI rate.

###### Description

After a baseline evaluation of preparedness in central line sterile technique within a simulation laboratory, residents were randomized to receive either video-based training or simulation-based and video-based training. The training focused on current CDC sterile technique recommendations in the categories of: nonsterile preparation, hand washing, sterile field/supply preparation, sterile gowning, sterile gloving and sterile draping. The simulation-based group showed a statistically significant improvement and subsequently all internal medicine residents in the MICU adopted this training. Sample sizes were not provided. Infection rates were analyzed using a generalized linear model and Poisson regression controlling for ICU type and study period.

###### Results and Limitations

After randomization, baseline sterile technique test results were not significantly different in any category. A statistically significant improvement in median post-test score in the categories of nonsterile preparation (p<0.001), hand washing steps (p=0.007), sterile field/supply preparation (p=0.05), sterile gowning (p<0.001), and sterile draping (p=0.005) was observed for the simulation-based and video-based training group compared with the video-based training group (Table 9). An all-or-nothing analysis comparing the number of residents with perfect scores in each of the sterile technique categories showed an identical pattern of statistically significant improvement for the simulation-based training group compared with video training alone. The results of the randomized controlled trial led to the use of combined simulation and video-based training in the medical ICU. All medical ICU residents were trained in this manner while surgical ICU residents received no extra training. Eighteen months after the study intervention, the medical ICU had a CLABSI rate of 1.0 infections per 1,000 catheter-days, which was a significantly lower rate of CLABSI than the surgical ICU with a rate of 3.4 infections per 1,000 catheter-days (IRR: 0.30; 95% CI: 0.10 to 0.91; p=0.03) when analyzed with a Poisson regression model. A limitation of this study is adherence rates were not measured during the post-randomized, controlled trial period of the study.

###### Perez Parra et al. (2010)62

###### Summary

In a controlled before-after study, Perez Parra et al. reported a month-long educational intervention for all ICU staff in three units at a tertiary care university-affiliated hospital in Spain.62 Adherence rates were not reported and overall infection rates did not change significantly. VAP rates were used as a control in this study and increased over the study period.

###### Description

The educational intervention was a 15-minute lecture that covered Infectious Disease Society of America and Center for Disease Control and Prevention guidelines for CLABSI prevention. The lecture was given to all ICU workers, physicians, residents, nurses, and students, on all shifts. There was a test before the lecture and a subsequent test 6 months later. Poisson regression was used to analyze infection rates. VAP rates were used as a control, but analysis was not performed on the VAP rates, therefore lessening the effectiveness of the control. Also, there was no analysis done on patient characteristics and no patient characteristics were included in the final regression model.

###### Results and Limitations

The overall CLABSI rates were nonsignificantly different from the baseline period to the postintervention period (4.22 vs. 2.94 infections per 1,000 catheter-days, p=0.11, (Table 9). While the cardiac surgery (p=0.12) and medical ICUs (p=0.31) did not undergo a significant change, the general surgery ICU did see a significant improvement in infection rates (p=0.05). In comparison, VAP rates were 13.34 infections per 1,000 ventilator-days in the baseline period and 15.82 in the postintervention period.

###### Barsuk et al. (2009)63

###### Summary

Barsuk et al.63 compared a simulation-based educational program to a traditional educational program for central line insertion at a tertiary care facility over a 32-month period. A baseline period and a concurrent control group (surgical ICU) served as the comparators for this study. Adherence rates were not reported. The medical ICU received the simulation-based intervention and had significantly lower infection rates than the surgical ICU and the medical ICU during the baseline period.

###### Description

Residents of both the medical and the surgical ICUs were trained using the traditional method for the first 16 months of the study, serving as the baseline period. Then the residents in the MICU received a baseline test. Thereafter, the residents watched a training video and were given an opportunity for deliberate practice with focused feedback. A post-test was administered and a minimum score was needed to pass. Further training was given to those who did not pass. Poisson regression was used to analyze the infection rates. ICU, period, and catheter-days were also included in the regression model. There was no analysis presented for patient characteristics and no patient characteristics were included in the final model, but there is mention that a significant increase in Charlson score was observed in the postintervention period in the MICU (p=0.009). The diagnosis of sepsis also significantly increased over the study (p=0.02).

###### Results and Limitations

Infection rates in the medical ICU dropped significantly from 3.2 infections per 1,000 catheter-days to 0.5 (p=0.001, Table 9). The infection rate in the surgical ICU was similar in both periods, 4.86 infections per 1,000 catheter-days versus 5.26. The postintervention medical ICU infection rate was also significantly lower than the surgical ICU rate (IRR: 0.16; 95% CI: 0.05 to 0.44). Residents were aware of their involvement in the study, which may have led to a Hawthorne effect in the medical ICU.

##### Interrupted Time Series

###### Apisarnthanarak et al. (2010)64

###### Summary

Apisarnthanarak et al. implemented an audit and feedback, organizational change, and provider education intervention over a period of 3 years in a university affiliated, tertiary care hospital in Thailand.64 The authors found that adherence to maximal sterile barriers, hand hygiene, use of chlorhexidine skin antisepsis at central venous catheter (CVC) insertion site, and avoiding femoral catheterization increased significantly between the baseline and intervention periods. A significant reduction in CLABSI rate was observed in the postintervention period.

###### Description

A multidisciplinary team from the hospital was created to conduct an education program, track patients with CVC, and monitor adherence to the quality improvement protocol. The study design was broken into three periods. The first period (July 2005 to June 2006) comprised the baseline; period two (July 2006 to June 2007) introduced alcohol dispensers at the patient's bedside and a CLABSI bundle, and period three (July 2007 to June 2008) introduced an intensified hand hygiene intervention. The CLABSI bundle implemented in period two consisted of hospital health care worker education on proper hand hygiene, education on maximal sterile barrier precautions, use of chlorhexidine-based skin preparation, optimization of CVC practices and daily review of catheter necessity. The education component of this intervention was a onetime 45-minute lecture administered to hospital staff. Period three replaced this single education experience with continued education every four months and promoted adherence with posters and newsletters.

###### Results and Limitations

Overall hand hygiene adherence significantly improved from 8 percent at baseline compared with period two (24%, p<0.001) and period three (53%, p<0.001, Table 9). Adherence to all components of maximal sterile barrier precautions increased from 45 percent during the baseline period compared with 80 percent (p<0.05, compared to baseline) during period two and 81 percent during period three (p<0.05, compared to baseline). Correct use of chlorhexidine skin antisepsis increased from a baseline of 42 percent compared with 75 percent (p<0.05, compared to baseline) and 77 percent (p<0.05, compared to baseline) in periods two and three, respectively. Lastly, adherence to avoiding femoral catheter insertion increased from 50 percent in period one compared with 64 percent (p<0.05) in period two and 66 percent (p<0.05) in period three.

During period one the overall CLABSI rate per 1,000 catheter-days was 14 compared with 6.4 (p<0.001) and 1.4 (p<0.001) CLABSI per 1,000 catheter-days in periods two and three respectively. In addition, the mean catheter-days was significantly reduced during period two (4.9 ± 1.5 days, p<0.001) and period three (4.1 ± 1.1 days, p<0.001) compared with baseline duration of 5.6 ± 2.4 days (Appendix Table G2).

###### Costello et al. (2008)45

###### Summary

Costello et al. compared full and partial intervention with baseline data on CLABSI at a dedicated pediatric cardiac ICU.45 The intervention consisted of audit and feedback, financial incentives, regulations, and policy, organizational change, provider education, and a provider reminder system. The duration of both baseline and full intervention periods was 9 months, while the partial intervention period was 15 months. Adherence rates significantly improved between partial and full intervention for adherence to central venous line (CVL) insertion and maintenance bundles. Additionally, hand hygiene showed significant improvement from baseline compared with full intervention. CLABSI rates in the cardiac ICU significantly improved from baseline after both partial and full interventions. The authors estimate an annual attributable savings between $236,000 and $782,000 using previously published cost analysis.

###### Description

A multidisciplinary team was created to track nosocomial infections, educate staff members, and implement the intervention practice changes. Central venous line insertion, access and practices were reviewed and a pretest was administered to all cardiac ICU members to identify weaknesses. Educational tools were developed with a focus on developing optimal CVL insertion, access, and maintenance technique. Processes for diagnosing patients with possible nosocomial infections were standardized during the study period. Staggered intervention implementation occurred between January 2005 and March 2006 and included: CVL insertion bundle, chlorhexidine based skin preparation, chlorhexidine eluting disk applied to percutaneous insertion sites, real time feedback on infection rates to cardiac ICU staff, mandatory nurse education, creation of cardiac ICU based infection control nurse position, CVL access and maintenance bundle, mandatory physician education, daily goal sheets during rounds, CVL insertion kit, needleless connector system. The sample size during the baseline period, partial implementation period and full implementation period was 911 patients, 1,472 patients, and 936 patients, respectively. A chi-square test or Fisher's exact test was used to analyze adherence with hand hygiene, CVL insertion and maintenance bundles. Segmented regression was used to analyze infection rates.

###### Results and Limitations

Mean CLABSI rates in the cardiac ICU significantly decreased from 7.8 (95% CI: 5.6 to 10.5) infections per 1,000 catheter-days during the baseline period (April 2004 to December 2004) to 4.7 (95% CI: 3.4 to 6.3) infections per 1,000 catheter-days (p=0.029, Table 9) during the partial intervention period (January 2005 to March 2006). The full intervention (April 2006 to December 2006) had a further reduced CLABSI rate of 2.3 (95% CI: 1.2 to 3.8; p=0.0002). Adherence with the CVL insertion bundle improved from a partial intervention value of 87 percent to 94 percent in the full intervention period (p<0.001). Adherence with the CVL maintenance bundle also improved from a partial intervention value of 85 percent versus 99 percent in the full intervention period (p<0.004). Hand hygiene adherence was also improved from a baseline value of 38 percent to 85.5 percent in the full intervention period (p<0.001).

The authors discuss several limitations of this study. First, is the use of NHSN surveillance definitions for CLABSI which are subject to adjudication bias. Second, there is no existing, validated severity of illness score for pediatric cardiac ICU patients, but indicators of patient acuity tended to increase over the study duration. Lastly, the adherence rates were collected intermittently, rather than systematically.

###### Miller et al. (2010)65,105

###### Summary

Miller et al. compared a central venous catheter insertion and maintenance bundle intervention to baseline practices among 29 pediatric ICUs in 27 hospitals in the United States.65,105 Each hospital was a participant in the National Association of Children's Hospitals and Related Institutions quality improvement collaborative and implemented interventions consisting of audit and feedback, organizational change, provider education and provider reminder systems. The authors demonstrated a significant improvement in overall infection rates between the baseline and stable effect periods. An analysis to determine the importance of adherence to insertion and maintenance intervention bundles found that only maintenance bundle adherence was a significant predictor of CLABSI rate decrease.

###### Description

Baseline data were collected for each ICU from January 2004 to August 2006. A ramp-up period of the first 3 months of the collaborative occurred from October 2006 to December 2006 and there was variation in the intervention bundle element implementation. Following this was a 9-month stable effect period from January 2007 to September 2007, when CLABSI efforts were consistent between ICUs. No sample sizes were reported.

Each ICU selected a multidisciplinary team responsible for testing and implementing CVC insertion and maintenance bundles. The insertion bundle consisted of appropriate hand washing before procedure, use of chlorhexidine gluconate, scrubbing of insertion site for children 2 months of age or older, no iodine skin preparation at insertion site, prepackaged insertion cart, insertion checklist, staff empowerment to stop nonsterile procedures, use of only polyurethane or Teflon catheters, and slide and video based training for all care providers. The maintenance bundle consisted of daily catheter needs assessment, catheter site care, and hub cap and tubing care. While adherence rates were not analyzed, marginal generalized linear models were used to analyze infection rates.

###### Results and Limitations

The mean baseline CLABSI rate for all pediatric ICUs was 5.4 infections per 1,000 catheter-days. During the ramp up period the mean CLABSI rate decreased to 4.3 infections per 1,000 catheter-days (95% CI: 3.1 to 6.4) which further decreased to a stable effect rate of 3.1 infections per 1,000 catheter-days (95% CI: 2.4 to 4.0; Table 9). Compared with baseline, the stable effect period CLABSI rate significantly decreased (p<0.0001). This observed association remained after a more rigorous sensitivity analysis. Miller et al. (2010) also used a hierarchical cluster regression model to determine significant predictors of the observed decrease in CLABSI rate. After adjustment for region and pediatric ICU demographics, the only significant predictor of decreased CLABSI rate was adherence with the CLABSI maintenance bundle (RR: 0.41; 95% CI: 0.20 to 0.85; p=0.017).

###### Update Publication

In 2011, Miller et al. published an update of this study that included another year of data as well as cost savings estimates.105 In addition to what was reported above, a nested nonrandomized factorial design study was also implemented comparing standard protocols for the use of the following items: (1) chlorhexidine scrub on central line caps and access points, (2) chlorhexidine-impregnated sponges with all central line care, (3) both 1 and 2, or (4) control. There was no significant difference in infection rates between any of the groups. Overall CLABSI rates fell significantly from 5.2 infections per 1,000 catheter-days in the baseline period to 2.3 in the postintervention period (RR: 0.44; 95% CI: 0.37 to 0.53; p<0.0001). There was only one time period, the ramp-up period (October 2006 to December 2006), that had a significant change in slope, 11 percent decrease per month (95% CI: -3% to -18%; p=0.006). The authors estimated that these 29 PICUs saved more than $31 million in CLABSI-attributable health care costs. This is discussed in more detail in key question 1c.

##### Simple Before-After

###### McKee et al. (2008)66

McKee et al. implemented a 30-month QI initiative through audit and feedback, organizational change, provider education, and provider reminder systems in a tertiary care facility in the United States.66 Sample size was not reported. Adherence rates were not analyzed, but a statistical process control chart was used to analyze infection rates. A nonsignificant change in infection rates was observed (Table 9) using statistical process control chart methodology and a comparison of incidence rate ratios. During the postintervention period, 10 weeks of zero infections was followed by a dramatic spike in infection rates. An epidemiological investigation occurred and found that a faulty positive displacement mechanical valve was associated with the increased infection rates. As soon as the faulty valves were removed from the hospital, the infection rates decreased dramatically.

###### Frankel et al. (2005)76

Frankel et al.76 conducted a simple before after study to test the efficacy of six sigma performance improvement strategy on reducing hospital infection rates. Details of this study are found in the 2007 report.

###### Wall et al. (2005)77

Wall et al.77 conducted a simple before after study to determine the efficacy of a continuous QI strategy on reducing hospital infection rate and increasing compliance with hand hygiene, use of chlorhexidine antisepsis, maximal sterile barriers, and guidewire exchange. Details of this study are found in the 2007 report.

###### DePalo et al. (2010)67

DePalo et al. implemented a 27-month statewide initiative that included audit and feedback, organizational change, and provider education in 11 acute care hospitals in the United States.67 This initiative targeted both CLABSI and VAP. All adult ICUs in Rhode Island participated in this QI collaborative. Improving patient safety culture and adoption of CLABSI and VAP preventive interventions was the focus of the collaborative. Adherence to CLABSI preventive interventions was not reported. Generalized linear latent and mixed models were used to analyze infection rates. The median CLABSI rate dropped from 1.95 infections per 1,000 catheter-days in the first quarter to 0 in the last quarter of the study period (Table 9). There was a significant decrease in trend over time for CLABSI (p=0.003). The authors reported an estimated $2,016,592 savings due to the QI collaborative.

###### Pronovost et al. (2010)46

Pronovost et al. invited all hospitals in Michigan to participate in a QI collaborative, the Keystone ICU project.46 Data were collected on an initial 18-month evaluation period and a subsequent 18-month sustainability period. A total of 103 ICUs from 67 hospitals participated in this study, although baseline data were only available for 55 ICUs. In addition, 13 ICUs elected not to participate during the sustainability period. Generalized linear latent and mixed models were used to analyze infection rates. Adjustment for hospital teaching status and bed size also occurred.

Over a 12-month period, audit and feedback, organizational change, provider education, provider reminder systems, and financial incentives were implemented in three month intervals. A multidisciplinary team was responsible for ensuring accurate reporting of CLABSI in the ICU, implementing CDC guideline conceptual model for reducing CLABSI, and educating physicians on the creation of a central line cart. The median infection rate decreased from 2.7 infections per 1,000 catheter-days (IQR, 0.6 to 4.8) at baseline to 0, which was sustained for every quarter throughout the study's 36-month followup period (Table 9). Mean CLABSI rate decreased significantly from baseline to 18 months postintervention by 12 percent (95% CI: 9% to 15%). The mean CLABSI rate 18 months postintervention versus 36 months postintervention decreased only 1 percent (95% CI: 9% decrease to 7% increase) and was not statistically significant. Forty three ICUs reported data from baseline to the end of the 36-month postintervention period without missing data and were included in a sensitivity analysis. The results of the sensitivity analysis demonstrated a similar 13 percent (95% CI: 9% to 16%) reduction in the mean CLABSI rate comparing baseline to 18 months postintervention and a 1 percent decrease between 18 and 36 months.

Some limitations of this study are the lack of uniformity in surveillance across sites or information pertaining to other contemporaneous QI efforts in the hospitals, and the variability in the sample provided. The hospitals that provided baseline data were not the same as those that provided postintervention data. However, a subgroup analysis was provided of hospitals with complete data and the authors found similar results. In addition to the limitations noted above, the following strengths are worth noting: (1) extensive hospital participation across the state and surrounding area, (2) sustained reductions in majority of the settings, and (3) similar results reported in the subgroup analysis of hospitals with complete data.

###### Render et al. (2011)71

Render et al. reported on a 4-year intervention to reduce CLABSI by implementing organizational change, provider education, audit feedback, and provider reminder systems in 174 VA ICUs in the United States.71 Overall bundle adherence rose from 85 percent to 98 percent over the study period, but was not analyzed. Sample size was not reported. Poisson (repeat measures GEE) regression was used to analyze infection rates. Pearson's correlation coefficient was used to assess bundle adherence with CLABSI rates. There was a strong inverse correlation between CLABSI rates and bundle adherence (r2 = -0.81). Mean infection rates (per 1000 catheter-days) were 3.84 in 2006, 3.19 in 2007, 2.44 in 2008 and 1.85 in 2009 which were all statistically significant. The IRRs for CLABSI were calculated for 2007 (IRR: 0.83; 95% CI: 0.73 to 0.84), 2008 (IRR: 0.065; 95% CI: 0.56 to 0.76) and 2009 (IRR: 0.47; 95% CI: 0.40 to 0.55) using 2006 as the reference group.

###### Zingg et al. (2009)68

Over a 5-month period, Zingg et al. implemented organizational change and provider education in five ICUs in a university hospital in Switzerland.68 In four teaching phases using multiple modalities, nurses and physicians were educated on proper hand hygiene and catheter care. Adherence with hand hygiene was analyzed using a chi-square test, while infection rates were analyzed using Cox proportional hazards model. During the baseline and postintervention periods, 499 patients and 500 patients were included, respectively. Overall hand hygiene was nonsignificantly different from baseline to the postintervention period (59.1% vs. 65%, p=0.47, Table 9), while correct hand disinfection did improve significantly (22.5% vs. 42.6%, p=0.003). The infection rate improved from 3.9 infections per 1,000 catheter-days in the baseline period to 1.0 (p<0.001). Male sex and residence in the medical ICU were independent risk factors for CLABSI.

###### Barrera et al. (2011)48

Barrera et al. described a 4-year study in six ICUs (general, trauma, neurosurgery, burn, pediatric and neonatology) in Colombia investigating organizational change and provider education.48 There were 14,516 patients included over the entire study, of which 2,398 acquired a HAI. Risks for CLABSI and HAI were compared using Poisson regression. Alcohol based hand rub was used as an indirect measure of hand hygiene. Use of the hand rub significantly improved 9.2 percent annually (p<0.001). Infection rates for CLABSI significantly decreased 12.5 percent annually (IRR: 0.89; 95% CI: 0.80 to 0.96; p=0.015). Multivariable analysis adjusted for temporary workers and nurse-to-patient ratios. The nurse-to-patient ratio was an independent risk factor for CLABSI (IRR: 1.11, CI: 1.07 to 1.16).

###### Kim et al. (2011)72

Kim et al. assessed CLABSI rates within ICUs when implementing organizational change, provider education, audit and feedback and provider reminder systems.72 The study assessed a 600 bed public hospital in the United States. Sample size was not reported. A Poisson regression was used to generate relative risk reduction and also to compare study rates with baseline rates. Adherence rates were not reported. Overall infection rates (per 1000 catheter-days) decreased significantly from 9 to 2.7 (RRR: 0.70; 95% CI: 0.59 to 0.77; p<0.00001). Kim et al. (2011) found that total excess cost of any CLABSI, regardless of organism, (excess LOS, replacement CVL, drug administration cost and drug cost) to be $32,254.

###### Harris et al. (2011)74

Harris et al. reported on CLABSI rates in pediatric ICUs within the United States assessing the impact of organizational change, provider education, audit and feedback and provider reminder systems.74 There were a total of 2,379 patients within this 3-year study. The study was broken up into baseline, intervention and postintervention periods. Infection rates were analyzed using logistic regression. Adherence to intervention was not assessed. Outcomes were adjusted for patient's age, sex, race, insurance coverage, comorbidities, and specialty of treating physician. Overall infection rate (per 1000 catheter days) decreased from 3.8 to 3.1 to 1.6. The odds ratios for the intervention (OR: 0.86; 95% CI: 0.48 to 1.53) and post-intervention (OR: 0.42; 95% CI: 0.22 to 0.80) were compared to baseline. Average costs of stay decreased from $34,365 to $30,175 to $25,938 during the three study periods and were statistically significant when compared to baseline. Average costs of hospital stay decreased from $54,323 to $46,773 to $42,071 during the study periods and were also statistically significant when compared to baseline. Adjusted costs were also reported.

###### Seguin et al. (2010)69

Seguin et al. reported on a 9-month intervention in a university-affiliated hospital in France.69 The intervention included a provider reminder system to reduce the duration of central venous catheterization, as well as indwelling urinary catheterization. During the baseline period, 676 patients were included, and during the postintervention period, 595 patients were included. One-way analysis of variance (ANOVA) was used to analyze duration of catheterization, while Poisson regression was used to analyze the infection rates. Due to group imbalances both outcomes were adjusted for age, Simplified Acute Physiology Score II (SAPS II), and admission diagnosis. A significant change in median duration of central venous catheterization (5 vs. 4 days, p<0.001, Table 9) and median time to central venous catheter removal (9 vs. 7 days, p=0.002) was observed, but after adjustment for patient characteristics, the difference in infection rates was nonsignificant (2.8 vs. 0.7 infections per 1,000 catheter-days, p=0.051).

###### Duane et al. (2009)70

In a 2-phase process over 29 months, Duane et al. implemented organizational change, provider education, and provider reminder systems at a Level 1 trauma center in the United States.70 One-hundred thirty-five patients were included in the baseline period, 194 in the first phase of the intervention, and 213 patients were included in the last phase of the intervention. Poisson regression was used to compare the infection rates while logistic regression was used to assess independent predictors of CLABSI. Infection rates improved from 16.5 infections per 1,000 catheter-days during the baseline to 15.0 in the first phase to 7.7 infections per 1,000 catheter-days in the last phase of the intervention (Table 9). The baseline period was not significantly different than the first phase of the intervention (p=0.08), but the last phase was significantly better than the baseline period (p<0.0001) and the first phase (p<0.004). Injury severity scores (ISS) and lack of central line protocols were independent predictors of CLABSI (p=0.04 and p=0.01, respectively). Average hospital charges per patient decreased by $28,391.87 in the last phase of the intervention, and by $19,615.70 in the first phase when compared with the baseline period.

###### Yoo et al. (2001)78

Yoo et al.78 conducted a simple before after study to determine the efficacy of an audit and feedback, organizational change, provider education and provider reminder system QI strategy on reducing the CLABSI rate within a medical-surgical ICU in Korea. Details of this study are found in the 2007 report.

###### Taylor et al. (2011)73

Taylor et al. analyzed the effect of organizational change and provider education on CLABSI risk in extremely low birth-weight infants in NICUs in the United States.73 The total sample size for the 1-year study was 200 infants. Adherence was not reported. The risk for CLABSI was assessed using Cox regression adjusting for gestational age, central line days, daily census, respiratory support days and premenstrual age at admission. The intervention group had similar risk as the control group (24% versus 23%, respectively; p=0.87). A stratified analysis by tertiles indicated that patients who have had a central line for at least 30 days had a reduced risk of CLABSI during the intervention period (HR: 0.48, CI: 0.25 to 0.91). Postmenstrual age (HR: 0.85; 95% CI: 0.25 to 0.91; p=0.025) and fewer respiratory support days (HR: 1.01, CI: 1.004 to 1.021; p=0.005) were found to be associated with decreased CLABSI risk.

###### Schulman et al. (2011)59

Schulman et al. implemented organizational change, provider education, and provider reminder systems at 18 New York State neonatal ICUs over a 10-month period.59 While adherence rates were not reported, Poisson regression was used to analyze infection rates. Overall, statewide CLABSI rates in the neonatal ICUs decreased from a baseline rate of 3.5 to 2.1 infections per 1,000 catheter-days (p<0.0005, Table 9). In a risk factor analysis, checklist utilization was found to decrease CLABSI rate by 16.5 percent (p=0.04).

###### Burrell et al. (2011)75

Burrell et al. assessed the impact of organizational change, audit and feedback and provider reminder systems on CLABSI rates in public hospital ICUs in Australia.75 There were ten tertiary, 12 metropolitan and two pediatric ICUs within this 18 month study. A sample size was not reported. Adherence was assessed using a chi-square test. Logistic regression was used to assess the CLABSI rates adjusting for patient bundle, physician bundle and catheter-days. Physician bundle adherence increased significantly from 74 percent to 81 percent (p<0.0001). Patient bundle adherence also significantly increased from 81 percent to 92 percent (p<0.001). The overall infection rate (per 1,000 catheter-days) decreased from 3.0 (95% CI: 2.0 to 4.3) to 1.2 (95% CI: 0.6 to 2.2) and was also statistically significant (p=0.0006). Burrell et al. (2011) found that catheter-days (RR: 1.05; 95% CI: 1.02 to 1.07; p=0.001) and nonadherence with the physician bundle (RR: 2.04; 95% CI: 1.1 to 3.6; p=0.016) were significant risk factors for CLABSI. The risk of CLABSI was significantly reduced in patients with CVLs inserted by physicians adherent with both bundles (RR: 0.5; 95% CI: 0.4 to 0.8; p=0.004). Patients had a higher risk for CLABSI when a CVL was inserted by a clinician that did not adhere to the clinician bundle (RR: 1.62; 95% CI: 1.1 to 2.4; p=0.018).

#### Studies That Do Not Control for Confounding or Secular Trend

Twenty- seven studies were also identified in the literature search that addressed prevention of central line-associated bloodstream infections and use a simple two sample test to analyze outcomes (Appendix Table F2).54,79-104 One79 was a controlled before-after study (as explained in the results overview, this study was demoted due to lack of between group comparisons), while the other 26 were simple before-after studies. Three studies implemented four QI strategies.80,86,104 Thirteen implemented three QI strategies.54,79,84,85,87,88,93-96,98,100,101 Six implemented two QI strategies.81,89,92,97,99,102 Five studies implemented one QI strategy.82,83,90,91,103 Twenty-one studies used provider education.79-81,83-96,99,102-104 Seventeen studies used audit and feedback in their QI initiative.54,79,80,82,84,86-88,93,94,96-101,104 Twenty used organizational change54,79-81,84-87,89,92-98,100-102,104 Eight implemented a provider reminder system.54,79,88,95,98,100,101,104

#### Strength of Evidence

##### Audit and Feedback and Provider Reminder Systems With the Base Strategies Compared With Usual Care

The strength of the evidence for the use of audit and feedback and provider reminder systems with the base strategies, compared with usual care is summarized in Table 10. Twelve of the 26 studies reported using this combination of QI strategies.45,46,49,58,65,66,71,72,74,75,77,78

Table 10 Audit and feedback and provider reminder systems with the base strategies compared with usual care in CLABSI

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: insertion bundle | 1 controlled study58 1 interrupted time series45 1 simple before-after75 | Medium | Consistent | Direct | Precise | Low
Adherence: maintenance bundle | 1 interrupted time series45 | Medium | Unknown | Direct | Imprecise | Insufficient
Adherence: hand hygiene | 1 interrupted time series45 | Medium | Unknown | Direct | Imprecise | Insufficient
Infection rate | 1 controlled study49 2 interrupted time series45,65 8 simple before-after46,66,71,72,74,75,77,78 | Medium | Consistent | Direct | Precise | Moderate
Adherence and infection rates | 2 interrupted time series45,65 1 simple before-after75 | Medium | Consistent | Direct | Precise | Low

Abbreviation: CLABSI = central line–associated bloodstream infection.

###### Insertion Bundle

Three of the 12 studies reported adherence to an insertion bundle.45,58,75 As shown in Table 8, two45,58 of the studies are of medium quality while the third is of lower quality.75 Because of overall study quality for these two studies, risk of bias was determined to be medium. All 3 studies reported a significant improvement in adherence with the insertion bundle, rising from 10 percent to 70.1 percent (p<0.005) in one,45 87 percent to 94 percent (p<0.001) in another,58 and 74 percent to 81 percent (p<0.0001) in the last study.75 With similar direction and level of significance, the evidence was judged as consistent. This is a direct measure of adherence to the insertion bundle. The evidence was said to be precise. The quality rating for the cluster randomized, controlled trial58 was lowered from higher to medium because of several limitations, including short intervention and followup, lack of significant improvement when the initial control group implemented the intervention, and high variability in the estimate. The interrupted time series study45 adherence results were analyzed using two group tests; only infection rates were analyzed using segmented regression. The strength of the evidence for the use of audit and feedback and provider reminder systems with the base strategies, compared with usual care, to improve adherence to an insertion bundle was determined to be low (Table 10).

###### Maintenance Bundle

One of the 12 studies reported data on adherence to a maintenance bundle.45 As seen in Table 8, the overall study quality was judged to be medium. With only 1 study, consistency is unknown and adherence to the maintenance bundle is a direct measure of adherence. Precision was judged to be imprecise since only 1 medium quality article reported adherence to a maintenance bundle. The strength of the evidence for the use of audit and feedback and provider reminder systems with the base strategies, compared with usual care, to improve adherence to a maintenance bundle was deemed to be insufficient (Table 10).

###### Hand Hygiene

One of the 12 studies reported data on adherence to hand hygiene practices.45 As seen in Table 8, the overall study quality was judged to be medium. With only 1 study, consistency is unknown and adherence to the hand hygiene practices is a direct measure of adherence. Precision was judged to be imprecise since only 1 medium quality article reported adherence to hand hygiene. The strength of the evidence for the use of audit and feedback and provider reminder systems with the base strategies, compared with usual care, to improve adherence to hand hygiene was deemed to be insufficient (Table 10).

###### Infection Rate

Eleven of the 12 studies reported data on infection rates.45,46,49,65,66,71,74,75,77,78,106 Three studies45,49,65 were of medium quality and 8 were of lower quality46,66,71,72,74,75,77,78 providing a medium risk of bias (Table 8). Nine of 11 studies45,46,49,65,71,72,74,75,77 found a significant improvement in infection rates and the tenth study66 reported a nonsignificant reduction in infection rates from the baseline period to the postintervention period. One study reported a nonsignificant decrease in CLABSI rate but included only six cases, four in the preintervention period and two in the postintervention period (p=0.14).78 The baseline infection rates ranged from 3.0 to 11.3 infections per 1,000 catheter-days and dropped to 0 to 3.8 infections per 1,000 catheter-days in the postintervention period. The outcome was judged to be direct and precise. With 9 studies addressing this outcome and improved design and analytical techniques used for infection rather than adherence rates in some studies, the strength of the evidence for the use of audit and feedback and provider reminder systems with the base strategies, compared with usual care, to improve infection rates was determined to be moderate (Table 10).

###### Adherence and Infection Rate

Three of 12 studies reported data on adherence rates and infection rates.45,65,75 The adherence rates reported were not analyzed separately for 1 study, but were included in the model for infection rates.65 In the second study,45 adherence rates were analyzed using two-group tests. As shown in Table 8, 2 studies were of medium quality while the third was of lower quality.75 Risk of bias was determined to be medium. Adherence to an insertion and maintenance bundle were reported in 2 studies while the other only reported on an insertion bundle. All three reported significant improvements in adherence rates. One study65 found a significant association between adherence to the maintenance bundle and improved infection rates. Significant improvements in infection rates were reported in all three studies as well. Based on this, the evidence was determined to be consistent and precise. The outcome is a direct measure. The strength of the evidence for the use of organizational change with or without provider education and audit and feedback and provider reminder systems, compared with usual care, to improve adherence and infection rates was determined to be low (Table 10).

##### Audit and Feedback or Provider Reminder Systems With the Base Strategies Compared With Usual Care

The strength of the evidence for the use of audit and feedback or provider reminder systems with the base strategies, compared with usual care is summarized in Table 11. Seven of the 26 studies reported using this combination of QI strategies.48,59,64,67,69,70,76

Table 11 Audit and feedback or provider reminder systems with the base strategies compared with usual care in CLABSI

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: multiple measures | 1 interrupted time series64 | Medium | Unknown | Direct | Imprecise | Insufficient
Adherence: hand hygiene | 1 simple before after48 | High | Unknown | Direct | Imprecise | Insufficient
Infection rate | 1 interrupted time series64 6 simple before-after studies48,59,67,69,70,76 | Medium | Consistent | Direct | Precise | Moderate
Adherence and infection rates | 1 interrupted time series64 4 simple before-after studies48,59,69,70 | Medium | Consistent | Direct | Precise | Low

Abbreviation: CLABSI = central line–associated bloodstream infection.

###### Adherence to Multiple Measures

One of 7 studies reported adherence to multiple measures as an outcome.64 The preventive interventions included maximal sterile barrier, chlorhexidine skin preparation, avoidance of femoral artery, and overall hand hygiene. As shown in Table 8, the quality of this study was judged to be medium and the risk of bias was also determined to be medium. With 1 study the consistency is unknown and the outcome is considered a direct measure of the adherence. The outcome was deemed imprecise. The strength of the evidence for the use of audit and feedback or provider reminder systems with the base strategies, compared with usual care, to improve adherence rates was determined to be insufficient (Table 11).

###### Hand Hygiene

Only one study reported on this outcome.48 Thus, strength of evidence is insufficient.

###### Infection Rate

All 7 studies reported infection rate as an outcome.48,59,64,67,69,70,76 One64 was considered of medium quality and 6^48,59,67,69,70,76^ were of lower quality (Table 8). The risk of bias was judged to be medium due to the medium quality study and 1^67^ of the lower quality studies is a statewide initiative with extended followup time. All 7 studies reported a significant improvement in infection rates leading to a determination of consistent evidence. The outcome is a direct measure and the evidence was judged to be precise. Baseline infection rates ranged from 3.5 to 17.5 infections per 1,000 catheter-days while postintervention infection rates ranged from 0.8 to 7.7 infections per 1,000 catheter-days. In the medium quality study,64 CLABSI rates fell from 14 to 1.4 per 1,000 catheter days (p<0.001) over a 3 year period. The strength of the evidence for the use of audit and feedback or provider reminder systems with the base strategies, compared with usual care, to improve infection rates was determined to be moderate (Table 11).

###### Adherence and Infection Rate

Five of 7 studies reported data on adherence rates and infection rates.48,59,64,69,70 The adherence rates reported were not analyzed separately for 2 studies, but were included in the model for infection rates.59,70 As shown in Table 8, one study64 is of medium quality and 4 of lower quality.48,59,69,70 The risk of bias was considered to be medium. One study59 found a significant association between utilization of the insertion and maintenance bundle checklists and improved infection rates, while another70 found the lack of a central venous line was an independent risk factor for CLABSI. A third study 64 reported a significant improvement in adherence to multiple preventive interventions; the fourth reported a significantly greater use of antiseptic rub; and the fifth reported significant improvements in central line duration and time to removal. Four of the 5 studies reported improvements in infection rate, while the change in the fifth was not statistically significant (2.8 to 0.7; p=0.051).69 Based on this, the evidence was determined to be consistent and precise. The outcome is a direct measure. The strength of the evidence for the use of audit and feedback or provider reminder systems with the base strategies, compared with usual care, to improve adherence and infection rates was determined to be low (Table 11).

##### Base Strategies Compared With Usual Care

The strength of the evidence for the use of base strategies, compared with usual care is summarized in Table 12. Five of the 26 studies reported using provider education with or without organizational change.61-63,68,73

Table 12 Base strategies compared with usual care in CLABSI

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: multiple measures | 1 simple before-after 68 | High | Unknown | Indirect | Imprecise | Insufficient
Infection rate | 3 controlled studies61-63 1 simple before-after 73 | Medium | Consistent | Direct | Precise | Moderate
Risk of infection | 1 simple before-after 68 | High | Unknown | Indirect | Imprecise | Insufficient
Adherence rate and risk of infection | 1 simple before-after 68 | High | Unknown | Indirect | Imprecise | Insufficient

Abbreviation: CLABSI = central line–associated bloodstream infection.

###### Adherence to Multiple Measures

One of 5 studies reported adherence rates as an outcome.68 The preventive interventions included hand hygiene and catheter care. As shown in Table 8, the quality of this study was judged to be lower and the risk of bias was determined to be high. With one study, the consistency is unknown and the outcome is considered a direct measure of the adherence. The outcome was deemed imprecise. The strength of the evidence for the use of base strategies, compared with usual care, to improve adherence rates was determined to be insufficient (Table 12).

###### Infection Rate

Four of 5 studies reported infection rates as an outcome.61-63,73 Three studies were of medium quality, and 1 study73 was of lower quality (Table 8). The risk of bias was judged to be medium. Two61,63 of 5 studies found a significant improvement in infection rates and the third62 reported a trend toward significant improvement. One study found no discernible trend in infection rates.73 The evidence was deemed consistent. The outcome is a direct measure of infection rates. Overall baseline infection rates ranged from 1.84 to 4.2 infections per 1,000 catheter-days while postintervention infection rates ranged from 0.5 to 2.94 infections per 1,000 catheter-days. The evidence was determined to be precise. The strength of the evidence for the use of base strategies, compared with usual care, to improve infection rates was determined to be moderate (Table 12).

Two61,63 of the 5 studies used a simulation-based provider education strategy. Each of these studies had separate ICUs serve as a contemporaneous control. The intervention ICUs had low infection rates to start with, 3.5 and 3.2 infections per 1,000 catheter-days, but were able to yield a significant improvement, while the nonsimulation-based study did not report a significant change. Both controls had similar infection rates in the baseline and postintervention periods. The evidence for the use of simulation-based provider education compared with traditional provider education strategies suggests that simulations may be more effective at educating clinicians on CLABSI preventive interventions.

###### Risk of Infection

One of 5 studies reported risk of infection as an outcome.68 The study looked at change in the risk of infection and not specifically at changes in infection rate. As shown in Table 8, the quality of this study was judged to be lower and the risk of bias was determined to be high. With 1 study the consistency is unknown and the outcome is considered an indirect measure of infection rates. The outcome was deemed imprecise. The strength of the evidence for the use of base strategies, compared with usual care, to improve risk of infection was determined to be insufficient (Table 12).

###### Adherence and Risk of Infection

One of 6 studies reported adherence rates and a measure of change in infections as an outcome.68 The strength of the evidence for the use of provider education with or without organizational change compared with usual care to improve adherence and risk of infection separately was determined to be insufficient. Therefore, the strength of the evidence for the use of base strategies, compared with usual care, to improve adherence and risk of infection was also deemed insufficient (Table 12).

##### Audit and Feedback With the Base Strategies Compared With a Low Intensity Intervention

One study compared the use of audit and feedback with the base strategies versus provider education and a provider reminder system.53

###### Infection Rate

Lilly et al. (2011) compared a tele-ICU health care delivery system to the use of provider education and a paper checklist. The study showed a 50 percent decrease in odds of developing an infection in the postintervention period (p=0.005). The risk of bias was judged to be medium due to the medium study quality rating. With one study the consistency is unknown and the evidence is imprecise (Table 13).

Table 13 Audit and feedback with the base strategies within CLABSI compared with low intensity intervention

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Infection rate | 1 nonrandomized stepped wedge53 | Medium | Unknown | Direct | Imprecise | Insufficient

Abbreviation: CLABSI = central line–associated bloodstream infection.

##### Base Strategies Compared With a Low intensity Intervention

One study used a combination of organizational change and provider education compared with a low intensity intervention.60

###### Infection Rate

Speroff et al. (2011) compared the use of a virtual collaborative to the use of a toolkit. The study was of higher quality and involved 60 hospitals.60 Due to the quality of the study, the risk of bias was rated as medium. With only 1 study, the consistency is unknown. Infection rate is a direct measure and the evidence was deemed imprecise. The study showed no differential effect on infection rates (p=0.80). The strength of evidence was considered to be insufficient that the base strategies improve CLABSI rates compared with a low intensity intervention (Table 14).

Table 14 Base strategies within CLABSI compared with low intensity intervention

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Infection rate | 1 controlled study60 | Medium | Unknown | Direct | Imprecise | Insufficient

Abbreviation: CLABSI = central line–associated bloodstream infection.

### Ventilator-Associated Pneumonia (VAP)

#### Overview

Nineteen studies were identified in the literature search to reduce rates of ventilator-associated pneumonia (VAP) that met the inclusion criteria and also controlled for confounding or secular trend.47,48,50,51,53,55-58,60,67,74,107-113 These 19 studies are summarized in Table 15. Four were controlled studies:58,60,107,108 2 were cluster randomized, controlled trials58,60 and 2 were interrupted time series with a control. One used a nonrandomized stepped wedge design.53 Five others used an interrupted time series design.50,51,55,57,109 Nine were simple before-after studies that included multivariable analysis.47,48,56,67,74,110-113

Table 15 Overview of VAP articles that control for confounding and secular trend

Author, Location-Year | Study Type | Analysis for Infection Rates | Sample Size (Infections) | Organizational Change | Provider Education | Audit and Feedback | Provider Reminder Systems | Patient Education | Financial Incentives
Scales, Canada - 2011^58^ | Cluster RCT | Generalized linear mixed model | | | • | • | •
Speroff, United States - 2011^60^ | Cluster RCT | Hierarchical negative binomial regression | | • | •
Lilly, United States - 2011^53^ | Nonrandomized stepped wedge | Logistic regression | pre: 1529 (76) post: 4761 (32) | • | | •
Zaydfudim, United States - 2009^107^ | Controlled interrupted time series | Segmented linear regression | study pre: (121) study post: (31) | • | | • | •
Apisarnthanarak, Thailand - 2007^108^ | Controlled interrupted time series | Segmented regression | control: (20) study pre: 470 (45) study post: 952 (18)^a^ | • | •
Bouadma, France - 2010^109^ | Interrupted time series | Segmented regression with Poisson distribution | pre: 856 (270) post: 835 (142) | • | • | • | •
Marra, Brazil - 2009^55^ | Interrupted time series | Segmented regression | pre: (91) post: (62) | • | • | •
Papadimos, United States - 2008^57^ | Interrupted time series | ARIMA model | pre: 1315 (50) post: 1653 (11) | • | | •
Hawe, United Kingdom - 2009^51^ | Interrupted time series | Statistical process control chart | pre: 374 (49) post: 215 (10) | • | • | • | •
Cheema, United States - 2011^50^ | Interrupted time series | u-chart, g-chart | | • | • | • | •
Berenholtz, United States - 2011^47^ | Simple before-after | Generalized linear latent and mixed models with Poisson distribution | | • | • | • | | •
DePalo, United States - 2010^67^ | Simple before-after | Mixed model with Poisson distribution | | • | • | •
Prospero, Italy - 2008^110^ | Simple before-after | Time-dependent Cox regression | pre: 104 (27) post: 81 (17) | • | •
Barrera, Colombia - 2011^48^ | Simple before-after | Poisson regression | total: 14,516 (total # HAI: 2,398) | | | • | | •
Morris, Scotland - 2011^56^ | Simple before-after | Poisson regression | pre: 1460 (216) post: 501 (43) | • | • | • | •
Omrane, Canada - 2007^111^ | Simple before-after | Poisson regression | pre: 349 (23) post: 360 (22) | • | • | | •
Harris, United States - 2011^74^ | Simple before-after | Logistic regression | pre: 817 (16) intervention: 601 (16) post: 961 (7) | • | • | • | •
Dubose, United States - 2010^112^ | Simple before-after | Logistic regression | pre: 577 (33) post: 570 (25) | • | • | • | •
Kulvatunyou, Thailand - 2007^113^ | Simple before-after | Logistic regression | pre: 85 (42) post: 89 (11) | • | •

a These numbers correspond to the last study period

A variety of QI strategies were used. Seventeen used organizational change;47,50,51,53,55-57,60,67,74,107-113 15 used provider education;47,50,51,55,56,58,60,67,74,108-113 14 used audit and feedback;47,48,50,51,53,55-58,67,74,107,109,112 9 used provider reminder systems;50,51,56,58,74,107,109,111,112 and 2 used patient (family) education.47,48 The specific attributes of organizational change that were implemented for these studies are shown in Table 16.

Table 16 Specific attributes of organizational change that were implemented for VAP articles that control for confounding and secular trend

Author, Country-Publication Year | Multidisciplinary Team | Team Responsibilities | Hospital Executives on Team | New Protocol or Standards Implemented | Designate Staff Member Responsible for Implementation
Speroff, United States - 2011^60^ | | | | •
Lilly, United States - 2011^53^ | | | | •
Zaydfudim, United States – 2009^107^ | | | | • | •
Apisarnthanarak, Thailand – 2007^108^ | • | Supply feedback from baseline period, design action plan, and monitor educational program | • | | •
Bouadma, France – 2010^109^ | • | Design education program, select evidence-based recommendations to be implemented | | •
Hawe, United Kingdom – 2009^51^ | | | | •
Cheema, United States - 2011^50^ | • | Focused on the adaptation and implementation of a proven pediatric VAP bundle. | | •
Marra, Brazil – 2009^55^ | | | | • | •
Papadimos, United States – 2008^57^ | • | Implement FASTHUG program | | •
Berenholtz, United States – 2011^47^ | • | Implement CUSP program, assist with data collection, standardize protocol, engage and educate staff | • | •
DePalo, United States – 2010^67^ | • | Educate staff on evidence-based practices and help implement CLABSI and VAP bundle | | •
Morris, Scotland - 2011^56^ | | | | •
Omrane, Canada – 2007^111^ | • | Develop and implement the protocol | | •
Harris, United States - 2011^74^ | • | Led the development of the interventions through the Six Sigma method
Dubose, United States – 2010^112^ | • | Design checklist, audit data, design and implement process changes to address deficiencies | | • | •
Kulvatunyou, Thailand – 2007^113^ | | | | •

All of the studies used more than one QI strategy to promote change. Seven used four strategies;47,50,51,56,74,109,112 5 used three strategies;55,58,67,107,111 and 7 used two strategies.48,53,57,60,108,110,113

Infection and adherence rates were both analyzed in 8 studies.47,48,51,53,67,107-109 An additional study reported both but compared two different QI strategy combinations.60 Only adherence with preventive strategies to reduce VAP was reported in 1 study.58 VAP rates alone were analyzed in 10 studies.50,55-57,74,110-113 Two studies reported cost/savings information.74,108

Fifteen of the 19 were single-center studies48,50,51,53,55-57,74,107-113 and many of these are just one intensive care unit (ICU) in an academic center. One study47 was a statewide initiative involving data analysis from 112 ICUs, and another,67 a statewide project included 23 ICUs. One cluster randomized trial involved multiple ICUs and hospitals but did not specify the number.60 One of the cluster randomized, controlled trials58 involved 15 ICUs; the ICUs were randomized into one of two groups. Nine studies47,50,53,57,60,67,74,107,112 were from the United States, 2^58,111^ from Canada, 4^51,56,109,110^ from Europe, 2 from Thailand,108,113 1 from Colombia,48 and 1 from Brazil.55

The baseline VAP rate varied from 1.9 to 39.7 infections per 1,000 ventilator-days. For single center studies, postintervention sample size ranged from 81 to 4,761 patients and number of VAP infections ranged from 7 to 142. Postintervention infection rates ranged from 0.7 to 22.5 infections per 1,000 ventilator-days. For the four multicenter studies, more than 2 years of postintervention data were available for two of these studies.

The search also identified 25 studies that addressed prevention of VAP but did not control for confounding or secular trend (Appendix Table F1).80,82,89,91,94,97,103,114-131 These studies are not included in the summary above or in the following analysis due to their weak study designs and potential for biased results.

#### Methodological Quality of Included Studies

Fourteen studies had followup longer than 1 year after the intervention.47,48,50,55-57,60,67,74,107-109,112,113 Sixteen were considered to have adequate control for confounding and secular trend.47,48,53,56-58,60,67,74,107-113 Nine studies analyzed both adherence rates and infection rates.47,48,51,53,60,67,107-109 For the 17 quasi-experimental studies, only three108,109,111 explicitly reported being independent of other QI efforts; this dimension was not applicable for the randomized controlled trials.58,60 Additional information that was felt to impact study quality is noted as a “Comment” in Table 17. Three studies60,107,108 were ranked of higher quality, 4^53,57,58,109^ of medium quality, and 12 of lower quality.47,48,50,51,55,56,67,74,110-113

Table 17 Methodological quality for VAP articles that control for confounding and secular trend

Author, Location-Year | Study Type | Sufficient followup^a^ | Adequate control for confounding or secular trend^b^ | Change in adherence was analyzed^c^ | Change in infection rate was analyzed^d^ | Independent of other QI effort^e^ | Overall quality rating | Comments
Scales, Canada - 2011^58^ | Cluster RCT | - | + | + | - | N/A | Medium | Infection rates were not reported. High variability, small number of sites randomized, and there was an active control.
Speroff, United States - 2011^60^ | Cluster RCT | + | + | - | + | N/A | Higher | Adherence rates were calculated by followup survey, no baseline data. Took place in 59 hospitals.
Lilly, United States - 2011^53^ | Nonrandomized Stepped wedge | - | + | + | + | ? | Medium | Only 3 of the 7 ICUs had followup one or more years
Zaydfudim, United States - 2009^107^ | Controlled interrupted time series | + | + | + | + | ? | Higher | Used BSI as control. There was no baseline adherence rate.
Apisarnthanarak, Thailand - 2007^108^ | Controlled interrupted time series | + | + | + | + | + | Higher | 3-year intervention and followup
Bouadma, France - 2010^109^ | Interrupted time series | + | + | + | + | + | Medium
Marra, Brazil - 2009^55^ | Interrupted time series | + | - | - | + | - | Lower | Adherence rates were reported, but no pre/post statistical comparisons were made. No interrupted time series analysis was conducted.
Papadimos, United States - 2008^57^ | Interrupted time series | + | + | - | + | ? | Medium
Hawe, United Kingdom - 2009^51^ | Interrupted time series | - | - | + | + | - | Lower | No interrupted time series analysis was conducted.
Cheema, United States - 2011^50^ | Interrupted time series | + | - | - | + | ? | Lower | Patient characteristics were not assessed.
Berenholtz, United States - 2011^47^ | Simple before-after | + | + | + | + | - | Lower | Statewide QI initiative.
DePalo, United States - 2010^67^ | Simple before-after | + | + | + | + | - | Lower | Statewide QI initiative.
Prospero, Italy - 2008^110^ | Simple before-after | - | + | - | + | ? | Lower
Barrera, Colombia - 2011^48^ | Simple before-after | + | + | + | + | ? | Lower
Morris, Scotland - 2011^56^ | Simple before-after | + | + | - | + | ? | Lower | Adherence rates were reported, but no pre/post statistical comparisons were made.
Omrane, Canada - 2007^111^ | Simple before-after | - | + | - | + | + | Lower
Harris, United States - 2011^74^ | Simple before-after | + | + | - | + | ? | Lower
Dubose, United States - 2010^112^ | Simple before-after | + | + | - | + | ? | Lower | Adherence rates were reported, but no pre/post statistical comparisons were made.
Kulvatunyou, Thailand - 2007^113^ | Simple before-after | + | + | - | + | - | Lower

Note: All studies used standard and consistent infection definitions. CDC methodology was used in all studies except Bouadma et al. (2010),109 Hawe et al. (2009),51 and Omrane et al. (2007).111 Infection rates were adjusted for device utilization in all studies. Independence from other QI efforts was not applicable for randomized controlled trials.

a Is the length of followup sufficient (at least 12 months) to support the evaluation of primary outcomes and harms?

b Were adequate measures taken to control for confounding or secular trend?

c Was change in adherence analyzed?

d Was change in infection rate analyzed?

e Was the intervention performed independent of other QI efforts or other changes?

‘+’ means ‘yes.’ ‘-’ means ‘no.’ ‘?’ means ‘uncertain.

#### Description of VAP Studies That Control for Confounding and Secular Trend

##### Controlled Studies

###### Scales et al. (2011)58

###### Summary

In a cluster randomized, controlled trial, Scales et al. compared change in adherence to preventive interventions in a control ICU where a preventive intervention for a different condition was implemented to intervention ICUs receiving the preventive intervention of interest.58 Audit and feedback, provider education, and provider reminder systems were used. The study was in 15 community hospital ICUs in Canada and the duration of each intervention period was 4 months. This cluster randomized, controlled trial did not find significant improvements in adherence to head of bed elevation or spontaneous breathing trials. This study did not report infection rates.

###### Description

In 2011, Scales and colleagues reported on a pragmatic cluster randomized controlled trial among 15 community hospital ICUs in Canada. The objective was to increase delivery of six practices to improve ICU outcomes for five clinical conditions, including VAP (head of bed elevation and daily spontaneous breathing trials), deep venous thrombosis, catheter-related bloodstream infections, early enteral feeding, and decubitus ulcers. The ICUs were randomized into two groups. Each group was assigned an active intervention targeting a new preventive intervention every 4 months, while serving as control for another, unrelated practice. Thus, one group of ICUs received the intervention to improve adherence with head of bed elevation (VAP) while ICUs were receiving the intervention for deep venous thrombosis (DVT) prophylaxis. The ICU receiving the active intervention for DVT prophylaxis served as the control unit for head of bed elevation.

Adherence was analyzed as the odds ratio (OR) for improvement in adoption of the preventive intervention by comparing rates in the first month to the fourth month; the two groups were then compared using the summary ratio of ORs.

###### Results and Limitations

Considering all six targeted practices, patients in ICUs receiving active intervention were more likely to receive the targeted care practice than those in the control ICUs; summary ratio of ORs of 2.79 and 95% confidence interval (CI) 1.00 to 7.74; p=0.05; Table 18).

Table 18 Outcomes for VAP articles that control for confounding and secular trend

Author, Country-Year | Intervention/ Comparator | Type of Outcome | Specific Measure | Improve | Worsen | NS | Change in Specific Measure | Comments
Scales, Canada - 2011^58^ | Telemedicine Knowledge Translation program/ Active Control Group | Adherence | HOB elevation | | | ⋄ | Control: 80.1% → 90.2% Intervention: 49.8% → 89.6% (p=0.11) Ratio of ORs: 3.12 (95% CI: 0.79 to 12.41) | Reflects ratio of odds ratio. When all six preventive interventions are pooled together across conditions, a significant improvement in adherence is observed (p=0.05).
Scales, Canada - 2011^58^ | Telemedicine Knowledge Translation program/ Active Control Group | Adherence | Daily spontaneous breathing trials | | | ⋄ | Control: 90.9%→89.6% Intervention: 78.8%→85.1% (p=0.96) Ratio of ORs: 1.04 (95% CI: 0.21 to 5.03) | Reflects ratio of odds ratio. When all six preventive interventions are pooled together across conditions, a significant improvement in adherence is observed (p=0.05).
Scales, Canada - 2011^58^ | Telemedicine Knowledge Translation program/ Active Control Group | Infection | | | | | | Reflects ratio of odds ratio. When all six preventive interventions are pooled together across conditions, a significant improvement in adherence is observed (p=0.05).
Scales, Canada - 2011^58^ | Telemedicine Knowledge Translation program/ Active Control Group | Costs/Savings | | | | | | Reflects ratio of odds ratio. When all six preventive interventions are pooled together across conditions, a significant improvement in adherence is observed (p=0.05).
Speroff, United States - 2011^60^ | Virtual Collaborative Group/Toolkit Group | Adherence | Prevention Strategy Use | ⋄ | | | Virtual Collaborative: 69% Toolkit Group: 54% (p=0.017) | Use of tools and strategies was accomplished by followup survey. Clinical tools were used 61% by the Virtual Collaborative group and 49% by the Toolkit group (p=0.23). Data tools were used 56% by the Virtual Collaborative group and 30% by the Toolkit group (p=0.004). Collaborative hospitals reported significantly more use of VAP checklist (86% vs. 52%; p=0.007).
Speroff, United States - 2011^60^ | Virtual Collaborative Group/Toolkit Group | Infection | Overall | | | • | Median Virtual Collaborative: 2.14 (IQR, 0.00 to 6.09) → 2.93 (IQR, 0.00 to 7.63) Median Toolkit: 3.49 (IQR, 0.00 to 7.04) → 2.06 (IQR, 0.00 to 6.59)
Speroff, United States - 2011^60^ | Virtual Collaborative Group/Toolkit Group | Cost/Savings
Lilly, United States - 2011^53^ | Tele-ICU (providing care from a remote location)/ Provider education and checklist for best practices | Adherence | Overall | ⋄ | | | 33% → 52% (OR=2.20; 95% CI: 1.79 to 2.70; p<0.001) | The tele-ICU group was significantly older, sicker, were not mechanically ventilated or a postoperative case as often as the baseline group. It is unclear if these covariates were taken into account for the outcomes of interest.
Lilly, United States - 2011^53^ | Tele-ICU (providing care from a remote location)/ Provider education and checklist for best practices | Infection | Overall | • | | | 13% → 1.6% (OR= 0.15; 95% CI: 0.09 to 0.23; p<0.001)
Lilly, United States - 2011^53^ | Tele-ICU (providing care from a remote location)/ Provider education and checklist for best practices | Cost/Savings
Zaydfudim, United States - 2009^107^ | VAP electronic dashboard/ No Intervention (usual care) | Adherence | Overall | ⋄ | | | 39% → 89% (p<0.001) | BSI rates were measured as a control. Analysis with pre/post-test for VAP was significantly different, but time series was not.
Zaydfudim, United States - 2009^107^ | VAP electronic dashboard/ No Intervention (usual care) | Adherence | Spontaneous breathing trials | | | ⋄ | 86% (95% CI: 75% to 97%) → 97% (95% CI: 95% to 100%) | BSI rates were measured as a control. Analysis with pre/post-test for VAP was significantly different, but time series was not.
Zaydfudim, United States - 2009^107^ | VAP electronic dashboard/ No Intervention (usual care) | Adherence | HOB elevation | ⋄ | | | 92% (95% CI: 89% to 95%) → 98% (95% CI: 97% to 99%) | BSI rates were measured as a control. Analysis with pre/post-test for VAP was significantly different, but time series was not.
Zaydfudim, United States - 2009^107^ | VAP electronic dashboard/ No Intervention (usual care) | Adherence | Oral care | ⋄ | | | 84% (95% CI: 78% to 90%) → 98% (95% CI: 97% to 98%) | BSI rates were measured as a control. Analysis with pre/post-test for VAP was significantly different, but time series was not.
Zaydfudim, United States - 2009^107^ | VAP electronic dashboard/ No Intervention (usual care) | Infection | Overall VAP | | | • | Mean: 15.2 → 9.3 (p=0.37) | BSI rates were measured as a control. Analysis with pre/post-test for VAP was significantly different, but time series was not.
Zaydfudim, United States - 2009^107^ | VAP electronic dashboard/ No Intervention (usual care) | Infection | Overall BSI (Control) | | | • | Mean: 4.5 → 5.0 (p=0.98) | BSI rates were measured as a control. Analysis with pre/post-test for VAP was significantly different, but time series was not.
Zaydfudim, United States - 2009^107^ | VAP electronic dashboard/ No Intervention (usual care) | Costs/Savings | | | | | | BSI rates were measured as a control. Analysis with pre/post-test for VAP was significantly different, but time series was not.
Apisarnthanarak, Thailand - 2007^108^ | Educational program/ No Intervention (usual care) | Adherence | HOB elevation | ⋄ | | | 45% → 84% (p<0.05) | Period 1=12 mos (baseline period), Period 2=12 mos (intervention period), Period 3=24 mos (ongoing intervention and followup period). SICU and CCU served as controls. Level of significance reflects the change in slope, not change in level from time series analysis. Period 3 shows sustained change from period 1 even though it is nonsignificantly different than period 2.
Apisarnthanarak, Thailand - 2007^108^ | Educational program/ No Intervention (usual care) | Infection | MICU period 1 vs. period 2 | • | | | 20.6 → 8.5 (p=0.002)
Apisarnthanarak, Thailand - 2007^108^ | Educational program/ No Intervention (usual care) | Infection | MICU period 2 vs. period 3 | | | • | 8.5 → 4.2 (p=0.07)
Apisarnthanarak, Thailand - 2007^108^ | Educational program/ No Intervention (usual care) | Infection | SICU all periods (Control) | | | • | 5.4 → 5.6 → 5.5 (p=0.22,p=0.82)
Apisarnthanarak, Thailand - 2007^108^ | Educational program/ No Intervention (usual care) | Infection | CCU all periods (Control) | | | • | 4.4 → 4.8 → 4.6 (p=0.48, p=0.20)
Apisarnthanarak, Thailand - 2007^108^ | Educational program/ No Intervention (usual care) | Costs/Savings | MICU hospitalization costs per patient | ⋄ | | | $466 → $293 → $254 (p<0.001)
Apisarnthanarak, Thailand - 2007^108^ | Educational program/ No Intervention (usual care) | Costs/Savings | MICU monthly antibiotic cost for VAP | ⋄ | | | $4769 → $2622 → $2378 (p<0.001)
Apisarnthanarak, Thailand - 2007^108^ | Educational program/ No Intervention (usual care) | Costs/Savings | SICU hospitalization costs per patient (Control) | | | ⋄ | $399 → $384 → $395 (p=NS)
Apisarnthanarak, Thailand - 2007^108^ | Educational program/ No Intervention (usual care) | Costs/Savings | SICU monthly antibiotic cost for VAP (Control) | | | ⋄ | $2901 → $2884 → $2799 (p=NS)
Apisarnthanarak, Thailand - 2007^108^ | Educational program/ No Intervention (usual care) | Costs/Savings | CCU hospitalization costs per patient (Control) | | | ⋄ | $404 → $401 → $415 (p=NS)
Apisarnthanarak, Thailand - 2007^108^ | Educational program/ No Intervention (usual care) | Costs/Savings | CCU monthly antibiotic cost for VAP (Control) | | | ⋄ | $2876 → $2991 → $2994 (p=NS)
Bouadma, France - 2010^109^ | Multifaceted prevention program/ No Intervention (usual care) | Adherence^a^ | Complete bundle | ⋄ | | | 0% → 28.8% (p<0.0001)
Bouadma, France - 2010^109^ | Multifaceted prevention program/ No Intervention (usual care) | Adherence^a^ | Hand hygiene | | | ⋄ | 68% → 67% (p=0.07)
Bouadma, France - 2010^109^ | Multifaceted prevention program/ No Intervention (usual care) | Adherence^a^ | HOB elevation | ⋄ | | | 5% → 58% (p<0.0001)
Bouadma, France - 2010^109^ | Multifaceted prevention program/ No Intervention (usual care) | Adherence^a^ | Oral care | ⋄ | | | 47% → 90% (p<0.0001)
Bouadma, France - 2010^109^ | Multifaceted prevention program/ No Intervention (usual care) | Infection | Overall | • | | | 22.6 → 13.1 (p=0.001)
Bouadma, France - 2010^109^ | Multifaceted prevention program/ No Intervention (usual care) | Costs/Savings
Marra, Brazil - 2009^55^ | Phase 3: IHI VAP bundle, immediate correction of process measures, provider education, and feedback to providers/ Phase 1: CDC VAP bundle Phase 2: CDC VAP bundle + immediate correction of process measures | Adherence | HOB elevation^b^ | | | | 74.1% → 89.5% → 96.8%
Marra, Brazil - 2009^55^ | | Adherence | Daily sedation holiday^b^ | | | | ? → 98.9%
Marra, Brazil - 2009^55^ | | Infection | Overall | • | | | Mean: 16.4 → 15.0 → 10.4 (p=0.05, by ANOVA)
Marra, Brazil - 2009^55^ | | Costs/Savings
Papadimos, United States - 2008^57^ | FASTHUG protocol/ Procedural interventions | Adherence
Papadimos, United States - 2008^57^ | FASTHUG protocol/ Procedural interventions | Infection | Overall | • | | | 19.3 → 7.3 (p=0.0004)
Papadimos, United States - 2008^57^ | FASTHUG protocol/ Procedural interventions | Costs/Savings
Hawe, United Kingdom - 2009^51^ | Active implementation of VAP bundle/ Passive implementation of VAP bundle | Adherence | Overall | ⋄ | | | 0% → 54% (p<0.0001) | Level of significance reflects two samples tests not time series analysis. Statistical process control analysis also showed improvement during the implementation.
Hawe, United Kingdom - 2009^51^ | Active implementation of VAP bundle/ Passive implementation of VAP bundle | Adherence | HOB elevation | ⋄ | | | 54% → 94% (p<0.001) | Level of significance reflects two samples tests not time series analysis. Statistical process control analysis also showed improvement during the implementation.
Hawe, United Kingdom - 2009^51^ | Active implementation of VAP bundle/ Passive implementation of VAP bundle | Adherence | Oral care | ⋄ | | | 8% → 100% (p<0.001) | Level of significance reflects two samples tests not time series analysis. Statistical process control analysis also showed improvement during the implementation.
Hawe, United Kingdom - 2009^51^ | Active implementation of VAP bundle/ Passive implementation of VAP bundle | Adherence | Daily weaning plan | ⋄ | | | 52% → 72% (p=0.039) | Level of significance reflects two samples tests not time series analysis. Statistical process control analysis also showed improvement during the implementation.
Hawe, United Kingdom - 2009^51^ | Active implementation of VAP bundle/ Passive implementation of VAP bundle | Adherence | Daily sedation holiday | | | ⋄ | 72% → 82% (p=0.23) | Level of significance reflects two samples tests not time series analysis. Statistical process control analysis also showed improvement during the implementation.
Hawe, United Kingdom - 2009^51^ | Active implementation of VAP bundle/ Passive implementation of VAP bundle | Infection | Overall | • | | | 19.2 → 7.5 (p<0.01) Rate Ratio: 0.39 (99% CI, 0.16 to 0.96) | Level of significance reflects two samples tests not time series analysis. Statistical process control analysis also showed improvement during the implementation.
Hawe, United Kingdom - 2009^51^ | Active implementation of VAP bundle/ Passive implementation of VAP bundle | Costs/Savings | | | | | | Level of significance reflects two samples tests not time series analysis. Statistical process control analysis also showed improvement during the implementation.
Cheema, United States - 2011^50^ | Phase 3: VAP bundle with flow sheet/ Phase 1: Provider education on VAP bundle and VAP prevention; Phase 2: VAP bundle with checklist | Adherence | | | | | | During the first third of the VAP bundle implementation period, adherence with the VAP bundle ranged from 48% to 59%. During the last third of the VAP bundle implementation period, adherence with the VAP bundle ranged from 65% to 78%.
Cheema, United States - 2011^50^ | Phase 3: VAP bundle with flow sheet/ Phase 1: Provider education on VAP bundle and VAP prevention; Phase 2: VAP bundle with checklist | Infection | Overall | • | | | 4.2 → 0.7 → 4.8 → 0.8 (p=0.059, p=0.042, p=0.047 respectively compared to prior phase)
Cheema, United States - 2011^50^ | Phase 3: VAP bundle with flow sheet/ Phase 1: Provider education on VAP bundle and VAP prevention; Phase 2: VAP bundle with checklist | Cost/Savings
Berenholtz, United States - 2011^47^ | VAP bundle and daily goal sheets/No Intervention (usual care) | Adherence | Overall | ⋄ | | | 32% → 84% (p<0.001)
Berenholtz, United States - 2011^47^ | VAP bundle and daily goal sheets/No Intervention (usual care) | Infection | Overall | • | | | Median: 5.5 → 0 (p<0.001) Mean: 6.9 to 2.4
Berenholtz, United States - 2011^47^ | VAP bundle and daily goal sheets/No Intervention (usual care) | Costs/Savings
DePalo, United States - 2010^67^ | VAP bundle with daily assessment/ No Intervention (usual care) | Adherence | Complete bundle | ⋄ | | | 60% → 78% (p<0.0001) | Median VAP rate ranged from 0 to 2.76 during the study period. For infection rate, no significant time trend was noted (p=0.60).
DePalo, United States - 2010^67^ | VAP bundle with daily assessment/ No Intervention (usual care) | Infection | Overall | | | • | Median: 0.58 → 0 (p=0.075) | Median VAP rate ranged from 0 to 2.76 during the study period. For infection rate, no significant time trend was noted (p=0.60).
DePalo, United States - 2010^67^ | VAP bundle with daily assessment/ No Intervention (usual care) | Costs/Savings | | | | | | Median VAP rate ranged from 0 to 2.76 during the study period. For infection rate, no significant time trend was noted (p=0.60).
Prospero, Italy - 2008^110^ | Educational program/No Intervention (usual care) | Adherence | | | | | | P-value was adjusted for SAPS II, APACHE II, and trauma status.
Prospero, Italy - 2008^110^ | Educational program/No Intervention (usual care) | Infection | Overall | • | | | 36.9 → 22.5 (p=0.03) | P-value was adjusted for SAPS II, APACHE II, and trauma status.
Prospero, Italy - 2008^110^ | Educational program/No Intervention (usual care) | Costs/Savings | | | | | | P-value was adjusted for SAPS II, APACHE II, and trauma status.
Barrera, Colombia - 2011^48^ | Hand hygiene promotion/ No Intervention (usual care) | Adherence | ABHR use | ⋄ | | | 9.2% annual increase (p<0.001) | ABHR use is an indirect measure of hand hygiene.
Barrera, Colombia - 2011^48^ | Hand hygiene promotion/ No Intervention (usual care) | Infection | Overall | | | • | 9 → 14 (p=0.87)^a^ | ABHR use is an indirect measure of hand hygiene.
Barrera, Colombia - 2011^48^ | Hand hygiene promotion/ No Intervention (usual care) | Cost/Savings | | | | | | ABHR use is an indirect measure of hand hygiene.
Morris, Scotland - 2011^56^ | VAP bundle - sedation holiday, elevated bed, oral care, with checklist and feedback/ implemented protocols for bed elevation and weaning; intermittent audits with no recording or feedback | Adherence | Complete bundle | | | | ? → 70% | Adherence was measured through chart review. Overall relative risk reduction (RRR) was 40% (95% CI: 20% to 67%; p=0.001). RRR was greater for patients that required six or more days in the ICU (RRR=44%; 95% CI: 22% to 67%). RRR for patients that required 14 or more days in the ICU was 35% (95% CI: 13% to 56%).
Morris, Scotland - 2011^56^ | VAP bundle - sedation holiday, elevated bed, oral care, with checklist and feedback/ implemented protocols for bed elevation and weaning; intermittent audits with no recording or feedback | Adherence | HOB elevation and oral care | | | | ? → >95%
Morris, Scotland - 2011^56^ | VAP bundle - sedation holiday, elevated bed, oral care, with checklist and feedback/ implemented protocols for bed elevation and weaning; intermittent audits with no recording or feedback | Infection | Overall | • | | | 32 (95% CI: 27 to 35) → 12 (95% CI: 9 to 15) (p<0.001)
Morris, Scotland - 2011^56^ | VAP bundle - sedation holiday, elevated bed, oral care, with checklist and feedback/ implemented protocols for bed elevation and weaning; intermittent audits with no recording or feedback | Cost/Savings
Omrane, Canada - 2007^111^ | VAP prevention protocol/ No Intervention (usual care) | Adherence | | | | | | Pre-/post-test was significantly different, but adjusted rate ratio using regression analysis was not.
Omrane, Canada - 2007^111^ | VAP prevention protocol/ No Intervention (usual care) | Infection | Overall | | | • | 25.0 → 22.3 (p=NS) Adjusted rate ratio: 0.86 (95% CI: 0.71 to 1.05) | Pre-/post-test was significantly different, but adjusted rate ratio using regression analysis was not.
Omrane, Canada - 2007^111^ | VAP prevention protocol/ No Intervention (usual care) | Costs/Savings | | | | | | Pre-/post-test was significantly different, but adjusted rate ratio using regression analysis was not.
Harris, United States - 2011^74^ | Hand hygiene, VAP bundle, standardizing central line care/ No Intervention (usual care) | Adherence | | | | | | Outcomes were adjusted for patient's age, sex, and race as well as insurance coverage, comorbidities, and specialty of treating physician. The adjusted average PICU cost during the intervention period was -$3,948 (95% CI: -$10,678 to $2,782). The adjusted average PICU cost during the postintervention period was -$8,826 (95% CI: -$13,950 to -$3,702). The adjusted average cost per hospital stay during the postintervention period was -$12,136 (95% CI: -$19,058 to - $5,214).
Harris, United States - 2011^74^ | Hand hygiene, VAP bundle, standardizing central line care/ No Intervention (usual care) | Infection | Overall | • | | | 1.9 → 2.6 → 0.7 (OR=1.44; 95% CI: 0.71 to 2.92; OR=0.37; 95% CI: 0.15 to 0.97; p<0.05; compared to baseline)
Harris, United States - 2011^74^ | Hand hygiene, VAP bundle, standardizing central line care/ No Intervention (usual care) | Cost/Savings | Average PICU cost of stay | ⋄ | | | $34,365 (SD $2,446) → $30,175 (SD $2,139) → $25,938 (SD $1,146) (compared to baseline p<0.01)
Harris, United States - 2011^74^ | Hand hygiene, VAP bundle, standardizing central line care/ No Intervention (usual care) | | Average hospital cost of stay | ⋄ | | | $54,323 (SD $3,217) → $46,773 (SD $2727) → $42,071 (SD $1,700) (compared to baseline p<0.01)
Harris, United States - 2011^74^ | Hand hygiene, VAP bundle, standardizing central line care/ No Intervention (usual care) | | Projected annual cost savings | | | | $12 million
Dubose, United States - 2010^112^ | Quality Rounds Checklist (QRC)/ No Intervention (usual care) | Adherence | HOB elevation^b^ | | | | 35.2% → 93.2% | P-value was adjusted for age, mechanism of injury, Glasgow Coma Scale, and Injury Severity Score.
Dubose, United States - 2010^112^ | Quality Rounds Checklist (QRC)/ No Intervention (usual care) | Adherence | Sedation holiday^b^ | | | | 77.8% → 94% | P-value was adjusted for age, mechanism of injury, Glasgow Coma Scale, and Injury Severity Score.
Dubose, United States - 2010^112^ | Quality Rounds Checklist (QRC)/ No Intervention (usual care) | Infection | Overall | • | | | 12.41 → 8.74 (p=0.008) | P-value was adjusted for age, mechanism of injury, Glasgow Coma Scale, and Injury Severity Score.
Dubose, United States - 2010^112^ | Quality Rounds Checklist (QRC)/ No Intervention (usual care) | Costs/Savings | | | | | | P-value was adjusted for age, mechanism of injury, Glasgow Coma Scale, and Injury Severity Score.
Kulvatunyou, Thailand - 2007^113^ | Educational program/ No Intervention (usual care) | Adherence | | | | | | P-value was adjusted for age.
Kulvatunyou, Thailand - 2007^113^ | Educational program/ No Intervention (usual care) | Infection | Overall | • | | | 39.7 → 10.5 (p<0.001) | P-value was adjusted for age.
Kulvatunyou, Thailand - 2007^113^ | Educational program/ No Intervention (usual care) | Costs/Savings | | | | | | P-value was adjusted for age.

Abbreviations: APACHE II = Acute Physiological and Chronic Health Evaluation II; BSI = bloodstream infection; CCU = cardiac care unit; CDC = Centers for Disease Control; CI = confidence interval; FASTHUG = see Papadimos et al. (2008); HOB = head of bed; MICU = medical ICU; OR = odds ratio; SICU = surgical ICU; SAPS II = Simplified Acute Physiological Score II

• was used for infection rate outcomes

⋄ was used for adherence and costs/savings outcomes

a Adherence data are from Bouadma et al. Crit Care Med 2010; 38(3): 789-796132

b Reported, but not analyzed

Adherence with head of bed elevation in the intervention ICUs improved from 49.8 percent in the first month to 89.6 percent of patient-days in the last month (OR: 6.35; 95% CI: 1.85 to 21.79; p=0.007). In the control units, the rates increased from 80.1 percent to 90.2 percent (OR of 2.04, 95% CI: 0.82 to 5.07; p=0.12). The summary ratio of the two odds ratios was 3.12 (95% CI: 0.79 to 12.41; p=0.11); thus improvement in intervention ICUs was not different from control ICUs.

Adherence with the preventive intervention of daily spontaneous breathing trials in the intervention ICUs improved from 78.8 percent in the first month to 85.1 percent of patient-days in the last month (OR: 1.35; 95% CI: 0.44 to 4.12; p=0.57). In the control units, the rates changed from 90.9 percent to 89.6 percent with OR of 1.31, 95% CI: 0.34 to 4.97 (p=0.67). The ratio of the two ORs was 1.04 (95% CI: 0.21 to 5.03; p=0.96); thus, change in intervention ICUs were similar to control ICUs.

This randomized, controlled trial had a number of limitations. First, it was limited by the small number (n=15) of units randomized. Second, for head of bed elevation, it was limited by the high variability among units in both baseline adherence (∼15 to 100%) and also in final adherence (∼65 to 100%). This study also may have been underpowered given the high baseline rates in many of the units randomized. Regarding power, the authors note with a power of 80 percent and alpha of 0.05, the study had adequate power to detect a 30 percent increase when baseline adherence was 50 percent or a 22 percent increase when baseline adherence was 75 percent. For head of bed elevation, all but one control unit had an initial rate of at least 80 percent. For daily spontaneous breathing trials, nearly all ICUs randomized had baseline rates of at least 80 percent. Finally, the short duration of this trial, 4 months, may not have been sufficient to allow for change. An additional limitation includes spillover effect from the control intervention. Most of these limitations lead to an underpowered study or bias the study to accept the null hypothesis. The authors commented that longer intervention phases and inclusion of more centers would likely have narrowed the confidence intervals.

###### Speroff et al. (2011)60

###### Summary

Speroff et al. conducted a cluster randomized controlled trial comparing the use of a virtual collaborative with a toolkit approach.60 The QI strategies involved were organizational change and provider education. This study was conducted in 60 hospitals across the United States. After 18 months, there was no significant difference in infection rates between the two groups or over time within either group. There were some tools that were used significantly more in the virtual collaborative group than the toolkit group.

###### Description

The objective of this study was to prevent CLABSI and VAP in the ICU by improving adherence to evidence-based practices. The authors compared the use of a virtual collaborative approach to a toolkit approach. The toolkit approach entailed access to evidence-based guidelines and fact sheets for preventing CLABSI and VAP, a review of QI and teamwork methods, standardized data collection tools, standardized charting tools, access to a website that contained educational seminars, clinical tools, and QI tools. In addition, the ICU was allowed to implement other changes to prevent CLABSI and VAP. The collaborative group was given everything the toolkit group was given plus the use of web seminars, teleconferences, individual coaching, monthly educational and troubleshooting conference calls, and an email list-serve to encourage communication among teams.

Data were reported in 3-month intervals and analyzed using hierarchical negative binomial regression models in order to account for change over time, clustering of ICUs within hospitals, and baseline characteristics.

###### Results and Limitations

During the baseline period, median VAP rates were 2.14 (IQR: 0 to 6.09) and 3.49 (IQR: 0 to 7.04) infections per 1,000 ventilator-days in the virtual collaborative group and the toolkit group, respectively. After 18 months, the rate in the virtual collaborative group increased to 2.93 (IQR: 0 to 7.63) while the rate in the toolkit group decreased to 2.06 (IQR: 0 to 6.59) infections per 1,000 ventilator-days. The regression model found that neither the virtual collaborative group nor the toolkit group improved VAP rates (p=0.61 and 0.37, respectively) and there was no difference between the two groups (p=0.8). The virtual collaborative group did use data tools significantly more (p=0.004) and implemented the VAP checklist more than the toolkit group (p=0.007).

The authors list some contextual factors that may have led to the lack of improvement in the study: slow uptake of data driven quality improvement, lack of infrastructure to implement data driven improvement, and differential uptake of general knowledge and implementation knowledge. Also, giving the toolkit group the ability to implement additional changes at their discretion introduced some bias into the comparison being made.

###### Lilly et al. (2011)53

###### Summary

Lilly et al. conducted a nonrandomized stepped wedge design study in seven ICUs within an academic medical center in the United States.53 Organizational change, provider education, and audit and feedback were implemented. After 15 months of implementation, infection rates significantly improved.

###### Description

Before the initiation of this study the following factors were established: critical care governance, team structure (including intensivist-led closed model), call schedules, interdisciplinary rounds, and staffing models. The focus was on processes of care. Best practices for venous thrombosis, cardiovascular complications, ventilator-associated pneumonia, and stress ulcers were standardized. ICU daily goals and an educational program were initiated before the start of the study.

The study period consisted of initiating the use of a tele-ICU team. The offsite team participated in key critical care delivery 24 hours a day. The team reviewed the care for each patient, conducted real time audit of best practices, performed workstation-assisted care plan reviews, monitored system-generated electronic alerts, audited bedside staff responses to in-room alarms, and intervened when the responses of the bedside staff were delayed and the patient was deemed physiologically unstable. Logistic regression was used to analyze dichotomous outcomes and general linear mixed models were used for continuous outcomes.

###### Results and Limitations

From baseline to postintervention, adherence to “best practice” for prevention of VAP increased from 33% to 51% (OR: 2.2; 95% CI: 1.79 to 2.70; p<0.001). During the baseline period, the VAP rate was 13 percent while in the postintervention period it was 1.6 percent (OR: 0.15; 95% CI: 0.09 to 0.23; p<0.001). The tele-ICU group was significantly older, sicker, and was not mechanically ventilated or a postoperative case as often as the baseline group. Hospital mortality was the primary outcome for this study and was rigorously analyzed. It does not seem the same level of analysis was applied to the outcomes that this report is interested in.

###### Zaydfudim et al. (2009)107

###### Summary

Zaydfudim et al. evaluated a strategy of audit and feedback with organizational change and a provider reminder system.107 The setting was a United States surgical ICU, and duration of the intervention was 1 year. This controlled interrupted time series found a significant improvement in overall adherence but not in VAP rates. The rate of bloodstream infections (BSI), which did not change during the study, served as the control measure to detect secular trends.

###### Description

This study used an electronic dashboard system to monitor adherence with a ventilator bundle in a 21-bed surgical intensive care unit (SICU). The dashboard was the default screen saver for SICU clinical workstations that provided access to the electronic medical records. Adherence with the dashboard parameters was reviewed twice daily during interdisciplinary rounds and also in daily reports to physician and nurse leadership. This study was an interrupted time series analysis of VAP rates. Adherence was measured during each of the four quarters of the intervention, but there was no measurement during the baseline period. Quarterly individual parameter adherence was compared using 95% confidence intervals. The change in overall adherence was estimated with linear regression. The effects of the QI strategies on VAP rate were estimated using a segmented linear regression model. The rate of bloodstream infection was used as the control measure.

###### Results and Limitations

Overall adherence with all six ventilator bundle processes improved from 39 percent during the first quarter of the intervention to 89 percent at the end of 1 year (p<0.001). From the first quarter of the intervention to the final quarter, adherence with spontaneous breathing trials increased from 86 percent (95% CI: 75 to 97%) to 97 percent (95% CI: 95 to 100%); head of bed elevation increased from 92 percent (95% CI: 89 to 95%) to 98 percent (95% CI: 97 to 99%), and adherence with oral care improved from 84 percent (95% CI: 78 to 90%) to 98 percent (95% CI: 97 to 98%) as noted in Table 18. Thus, both head of bed elevation and oral care showed significant changes. The mean VAP rate decreased from a baseline of 15.2 (SD, 7.0) to 9.3 (SD, 4.9) per 1,000 ventilator-days in the intervention period (p=0.01). Analysis using time series data with segmented linear regression found that the change was not statistically significant (p=0.37; see Appendix Table G1). The authors noted there was no evidence of serial autocorrelation (see Methods section for further details). There were 121 cases of VAP during baseline and 31 postintervention. During the study, there was no change in the control measure of bloodstream infections; rates were 4.5 (SD, 3.8) at baseline and then 5.0 (SD, 2.4) per 1,000 catheter-days at postintervention (p=0.98). Patients in the postintervention period had higher APACHE II scores (p<0.002).

Limitations of this single-center study include the use of bloodstream infection rate as the single control measure and limited details from the time series analysis. The lack of a statistically significant finding on segmented linear regression may have been related to the small number of infections and limited duration of followup subsequent to implementation. Not measuring adherence during the baseline period is also a limitation.

###### Apisarnthanarak et al. (2007)108

###### Summary

Apisarnthanarak et al. evaluated a strategy of provider education and organizational change to usual care.108 The setting was a medical ICU (MICU) in Thailand and duration of the intervention was 3 years. This controlled interrupted time series found significant improvements in adherence to head of bed elevation, VAP rate, and hospitalization costs. The rate of VAP in two ICUs (surgical ICU [SICU] and cardiac care unit [CCU]) that served as control units did not change during the study.106

###### Description

In this study, the educational program was modeled after a successful program developed by Zack et al.;135 the intervention involved nurses and respiratory therapists and was continuously monitored and reinforced. The quality improvement action plan was designed by a multidisciplinary team; this team included hospital administration. The intervention unit was an 8-bed MICU; control units were an 8-bed SICU and 8-bed CCU.

Data were reported for the baseline period, for year 1 of the intervention, and then for followup during years 2 and 3. Categorical variables were compared using chi-square or Fisher's exact tests and continuous variables with Student's t-test. Trend analysis was performed using segmented regression. Hospital costs were estimated from the Thai insurance and hospital reimbursement systems; costs were converted to U.S. dollars.

###### Results and Limitations

Adherence improved during the study; maintaining head of bed elevation improved from 45 percent at baseline to 80 percent in year 1 and to 84 percent in years 2 and 3 (p<0.05 for each period, compared with baseline). The VAP rates were 20.6 (SD, 4.8) per 1,000 ventilator-days at baseline, 8.5 (SD, 4.2) in year 1, and 4.2 (SD, 3.1) in years 2 and 3; compared with baseline, rates improved (p<0.001 for each intervention period). Segmented regression analysis showed a statistically significant change in slope in the MICU VAP rate during the first year of implementation compared with baseline; change in slope of -1.171 (95% CI: -2.128 to -0.214, p=0.0018); change in slope for the final two years of followup compared with the year one was not statistically significant (β = -1.115, 95% CI: -5.867 to 1.643, p=0.07). Change in intercepts between time periods did not show a statistically significant difference, indicating that the initial improvements were sustained (Appendix Table G1). There were 470 patients (45 cases of VAP) during the baseline period and 952 patients (18 infections) in the 3 years postintervention. The authors found no significant differences in patient characteristics or severity of illness from one study period to the next. There were no changes in VAP rates in the two control units: VAP rates for the SICU were 5.4, 5.6, and 5.5 for the 3 periods (p=0.22, p=0.82, year 1 vs. baseline and year 1 vs. year 2 and 3, respectively); the CCU VAP rates were 4.4, 4.8, and 4.6 (p=0.48, p=0.20, year 1 vs. baseline and year 1 vs. year 2 and 3, respectively).

The authors reported a statistically significant decrease in mean hospital stay in MICU patients in periods 2 and 3 compared with the baseline: 5.5 days, 5.1 days, 14 days, respectively, p<0.001 for periods 2 and 3 versus baseline (period 1). The authors also report a significant decrease in hospitalization costs for each patient: $293, $254, $466, respectively, p<0.001 for periods 2 and 3 versus baseline (period 1).

This study was from a small (8-bed) ICU in a single center in Thailand.

##### Interrupted Time Series

###### Bouadma et al. (2010)109

###### Summary

Bouadma et al. evaluated organizational change, provider education, audit and feedback, and provider reminder systems. The setting was a European medical ICU and duration of the intervention was 30 months.109,132 The interrupted time series showed significant improvement in several adherence rates, including the complete bundle, and a decreased VAP rate.

###### Description

The QI initiatives in this study included use of technical improvements, such as use of a bicolored ribbon to indicate appropriate head of bed elevation. Adherence was determined using detailed definitions and was based on frequent observations.132 The Wilcoxon rank sum test was used to compare continuous data and Fisher's exact test for categorical data. The authors calculated both overall VAP rate as well the rate of first VAP episode. The risk of first VAP episode over time was evaluated using segmented regression analysis of quarterly rates using a Poisson model. Adherence was measured at baseline and then 4 times during the study at 1, 6, 12, and 24 months. Analysis with Cochran-Armitage test was used to determine statistical significance of linear trend for adherence rates.

###### Results and Limitations

Adherence at baseline and at 24 months to head of bed elevation increased from 5 percent to 58 percent (p<0.0001) and good oral hygiene from 47 percent to 90 percent (p<0.0001).132 Complete adherence to all six preventive interventions in the bundle increased from 0 to 28.8 percent (p<0.001). Hand hygiene was unchanged throughout the study (68% and 67%).

The VAP rates per 1,000 ventilator-days were 22.6 and 13.1, respectively, during baseline (45 month study period) and intervention (30 month study period). Segmented regression analysis was reported as showing a nonsignificant increase in first VAP episode rate during baseline (p=0.11) and a significant decrease in the rate during intervention (p=0.001)109 (Appendix Table G1). There were 270 episodes of VAP during the baseline period and 142 during the intervention period. Patients in the intervention period had a higher Simplified Acute Physiological Score II (SAPS II) (p=0.002) and greater severity of underlying disease (p=0.04).

###### Marra et al. (2009)55

###### Summary

Marra et al. reported the outcomes with use of a series of increasingly intense, QI interventions implemented in three phases over an 8-year period. The final phase included provider education, organizational change, and audit and feedback. The setting was a medical-surgical ICU in Brazil.55 This interrupted time series showed a decrease in the VAP rate.

###### Description

Organizational changes in this study included using new standards/protocols and having designated staff members responsible for implementation. This study was conducted in a 38-bed medical-surgical ICU. Phase 1 (baseline) involved implementing evidence-based measures to reduce VAP and twice yearly audit and feedback for a small number of ventilator patients. In Phase 2, performance monitoring to improve adherence was done at the patient's bedside; phase 1 activities were continued. Phase 3 occurred following the hospital CEO's statement indicating “zero tolerance for VAP.” Added interventions in this phase, which also included new preventive interventions of oral care and subglottic suction, included having an ICU nurse monitor the ventilator bundle each weekday and intervene if nonadherence was noted and providing monthly feedback reports to ICU staff. VAP rates during the 3 periods were compared using ANOVA. Segmented regression analysis of time series data were used only to study changes made within Phase 3 (Appendix Table G1).

###### Results and Limitations

Adherence to process measures was presented for this study, but statistical analysis was not included. During the study, adherence with head of bed elevation increased from 74.1 percent in Phase 1 (baseline), to 89.5 percent in Phase 2, and 96.8 percent in Phase 3. Adherence with “daily sedation vacations” was 98.9 percent in Phase 3. The mean VAP rate per 1,000 ventilator-days decreased from 16.4 to 15.0 to 10.4 over the three periods (p=0.05 by ANOVA). There were 91 cases of VAP in Phase 1 (baseline), 234 in Phase 2, and 62 in Phase 3. Limitations of this study include lack of a control group, not providing statistical analysis of adherence data, not using interrupted time series analysis to compare the 3 phases, and not comparing patient characteristics for the 3 periods.

###### Papadimos et al. (2008)57

###### Summary

Papadimos et al. studied the impact of using audit and feedback and organizational change. The setting was a United States-based surgical ICU.57 Time series analysis showed a significant decrease in VAP rates.

###### Description

During 2004 and 2005, an intensivist-led multidisciplinary team, including nursing, anesthesiology and respiratory therapy, conducted an improvement project to reduce cases of VAP in a 10-bed SICU. In year 1, procedural interventions were highlighted such as oral care. In year 2 (2005), the emphasis changed to an evaluative intervention, that is, the preventive interventions were emphasized on twice-daily patient rounds by the critical care team. This evaluative approach used the concept of “FASTHUG” for daily assessment of Feeding, Analgesia, Sedation, Thromboembolic prevention, Head of bed elevation, Ulcer prophylaxis, and Glucose control. The year 2 work was in response to lack of significant improvement in the VAP rate during year 1. The authors performed a number of analyses. A two-tailed z-test was used to compare the rates for single years, and followup pairwise comparison was done using a Wilcoxon test. Interrupted time series analysis with ARIMA (autoregressive integrated moving average) modeling was used to test for the impact of intervention on monthly rates of VAP. Consequently, the reduction in VAP may be underestimated.

###### Results and Limitations

The authors did not report adherence with preventive process measures. The VAP rate decreased from 19.3 per 1,000 ventilator-days at baseline (in 2003 before any intervention) to 7.3 in 2005, the first year of the FASTHUG program (p<0.01; the VAP rate in 2004 was 16.6). The median VAP rate during 2005 (FASTHUG) was lower than both baseline and the less-intensive year 1 intervention, p=0.028 for both comparisons. There were 24 cases of VAP in 2003, 26 in 2004, and 11 in 2005. A time series analysis was also conducted for preFASTHUG compared with postFASTHUG. This analysis reported a statistically significant drop in VAP rates during the postFASTHUG period (p=0.0004; Appendix Table G1). There was a statistically significant increase in severity of illness during the postFASTHUG period.

###### Hawe et al. (2009)51

###### Summary

Hawe et al. reported on their intervention using audit and feedback, organizational change, provider education, and provider reminder systems. The setting was a European surgical/medical ICU and the intervention lasted 10 months.51 This interrupted time series study found a significant increase in adherence to several measures, including overall adherence, and a statistically significant decrease in VAP rate.

###### Description

The baseline for this study was considered passive implementation and consisted of approving preventive interventions for VAP as ICU policy. Active implementation included the addition of an educational intervention, feedback about adherence and VAP rates, and use of various prompts as reminders of the preventive interventions. VAP rates were compared between the passive and active implementation periods using rate difference and rate ratio tests. In addition, the authors used SPC (statistical process control) analysis of the number of ventilator-days between episodes of VAP. Adherence was measured for 50 consecutive ventilated patients three times during the study, including one measurement during the baseline period.

###### Results and Limitations

Adherence with all six preventive interventions of the ventilator bundle increased from 0 percent at baseline to 54 percent in the eighth month of the intervention (p<0.0001). Adherence with head of bed elevation increased from 54 percent to 94 percent (p<0.001), daily weaning plan from 52 percent to 72 percent (p=0.039), and daily sedation holiday from 72 percent to 82 percent (p=0.23) over the same interval. VAP rates decreased from 19.2 per 1,000 ventilator-days at baseline to 7.5 during the intervention. The rate ratio was 0.39 (99% CI: 0.16 to 0.96; p=0.01). The SPC analysis of “days since last VAP” showed an increase in days between cases of VAP during active implementation. During this period there were two points above the upper control limit, indicating change consistent with an external cause, that is, active implementation. There were 49 episodes of VAP during the baseline period and 10 episodes during active implementation. The mean Acute Physiology and Chronic Health Evaluation II (APACHE II) score did not change.

The major limitation of this study is lack of a formal interrupted time series analysis.

###### Cheema et al. (2011)50

###### Summary

Cheema et al. reported on the use of audit and feedback, a provider reminder system, organizational change, and provider education.50 This took place in a pediatric ICU in the United States and lasted 29 months. This interrupted time series found a significant improvement in infection rates during the final phase.

###### Description

This intervention was conducted a three phases. The baseline period consisted of 13 months. In the first phase after the baseline period, nurses and respiratory therapists used the VAP prevention checklist everyday on every ventilated patient. The second phase was a 4-month washout phase as the staff found the checklist too cumbersome. In the last phase of the intervention a flow sheet was implemented. This provided cues for VAP prevention bundle practices. Staff was also educated on VAP prevention and the prevention bundle. Statistical process control (SPC) analysis (u-charts, p-charts, and g-charts) were used to analyze the outcomes. The p-values reported originate from a t-test and are comparing the phase to the phase that preceded it.

###### Results and Limitations

During the baseline period, the VAP rate was 4.2 infections per 1,000 ventilator-days. During the first phase of the intervention it fell to 0.7 (p=0.059), but during the washout period, it rose to 4.8 infections per 1,000 ventilator-days (p=0.042). The VAP rate fell again during the last phase of the intervention period to 0.8 (p=0.047). Self-reported adherence ranged from 48 percent to 59 percent during the first part of the checklist phase and by the end of the checklist phase, adherence ranged from 65 percent to 78 percent.

Number of VAP cases was not provided and the statistical analysis (p-values) was not adjusted for multiple comparisons. In addition, the mean rates in the SPC charts did not correspond to the four study periods.

##### Simple Before-After Studies

###### Berenholtz et al. (2011)47

Berenholtz et al. reported on use of audit and feedback, organizational change, provider education, and patient (family) education. Data were analyzed from 112 ICUs in 72 hospitals, predominantly in Michigan, as part of the Keystone ICU project. Quarterly data for VAP were reported during the 30-month intervention period; however, only one baseline measurement was obtained.47 Analysis showed a significant improvement in both overall adherence and VAP rate.

The QI strategies were used to improve adherence with five evidence-based recommendations for patients on ventilators to prevent VAP. The 112 ICUs reported data for 3,228 ICU-months and 550,800 ventilator-days during the entire study period. The data were summarized using median and mean VAP rates. A generalized linear latent and mixed model with Poisson distribution for quarterly number of VAP infections was used to explore the relationship between time since implementation and VAP rates. Overall adherence with the preventive interventions increased from 32 percent at baseline to 84 percent in the final quarter (p<0.001); the “relative risk” of complete adherence was 2.59 (95% CI: 2.49 to 2.69). The overall median VAP rate decreased from 5.5 per 1,000 ventilator-days (mean 6.9) during the 3-month baseline to 0 infections (mean 2.4 infections) at 28-30 months (p<0.001). The multilevel Poisson regression model showed VAP incidence rate ratio of 0.28 (95% CI: 0.24 to 0.34) during the final quarter. This study found a significant decrease in VAP rates at multiple points during the 30-month intervention, even with the relatively low baseline rate. In addition, there was a significant decrease in the VAP incidence rate ratio in all ICU subgroups (such as teaching status, ICU type, and ICU size), except in hospital size of fewer than 200 beds, at 16-18 and 28-30 months after implementation.

Some limitations of this study are the lack of uniformity in surveillance across sites or information pertaining to other contemporaneous QI efforts in the hospitals, and the variability in the sample provided. The hospitals that provided baseline data were not the same as those that provided postintervention data. However, a subgroup analysis was provided of hospitals with complete data and the authors found similar results. In addition to the limitations noted above, the following strengths are worth noting: (1) extensive hospital participation across the state and surrounding area, (2) sustained reductions in majority of the settings, and (3) similar results reported in the subgroup analysis of hospitals with complete data.

###### DePalo et al. (2010)67

DePalo et al. reported on an intervention that included audit and feedback, organizational change, and provider education. This was a statewide (Rhode Island) study in 23 ICUs (263 ICU beds in 11 hospitals) over a 27-month period.67 There was a significant improvement in overall adherence, but not in the VAP rate.

This study applied the approach from the Michigan Keystone project46,47 to ICUs in Rhode Island. For VAP, data were available for 679 of 690 months (98.4% complete). During the study, quarterly data were summarized using median and mean VAP rates; a mixed effects model with Poisson distribution was used to examine the number of infections over time. Complete adherence with the VAP preventive interventions showed a statistically significant linear increase from 60 percent in the baseline quarter to 78 percent in the final quarter (p<0.0001). Mean VAP rates decreased from 3.44 infections per 1,000 ventilator-days at baseline (median 0.58) to 2.92 (median 0) in the final quarter. Using the mixed model framework, VAP rate during the first year (baseline and intervention) compared with the final year was reported as showing a decreasing trend (p=0.075). No overall time trend was noted for VAP (p=0.60). While this study found improved adherence, the low baseline VAP rate made it difficult to detect a significant change in this study.

###### Prospero et al. (2008)110

Prospero et al. reported on a 4-month study of an educational program and organizational change to reduce VAP in a 12-bed medical-surgical ICU.110 The baseline period had 104 ventilator patients and 27 cases of VAP, postintervention there were 81 ventilator patients with 17 cases of VAP. Time-dependent Cox regression models were used to assess the association between potential risk factors and VAP. Adherence was not measured. There was a statistically significant improvement (i.e., decrease) in the VAP rate from 36.9 to 22.5 infections per 1,000 ventilator-days (p=0.03).

###### Barrera et al. (2011)48

Barrera et al. described a 4-year study in six ICUs (general, trauma, neurosurgery, burn, pediatric and neonatology) in Colombia investigating organizational change and provider education.48 There were 14,516 patients included over the entire study of which 2,398 acquired a HAI. Risks for VAP and HAI were compared using Poisson regression. Alcohol-based hand rub was used as an indirect measure of hand hygiene. Use of the hand rub significantly improved 9.2 percent annually (p<0.001). There was a nonsignificant increase in VAP rate (per 1000 ventilator-days) from 9 to 14 (p=0.87).

###### Morris et al. (2011)56

Morris et al. assessed the impact of organizational change, provider education, audit and feedback, and provider reminder systems on VAP rates in surgical ICUs in Scotland.56 There were 1,961 patients over the 4-year study period. Data were analyzed using a Poisson regression. The study reported 70 percent adherence to the complete bundle and 95 percent adherence to HOB elevation and oral care. Adherence was measured through chart review. The overall VAP rate (per 1000 ventilator-days) significantly decreased from 32 (95% CI: 27 to 35) to 12 (95% CI: 9 to 15; p<0.001). The overall relative risk reduction was significant (RRR: 40%; 95% CI: 22% to 67%). Patients that required six or more days in the ICU had a greater relative risk reduction (RRR: 44%; 95% CI: 22% to 67%). Patients that required 14 or more days in the ICU had a smaller relative risk reduction (RRR: 35%; 95% CI: 13% to 56%).

###### Omrane et al. (2007)111

Omrane et al. reported on a 6-month intervention to reduce VAP in a 24-bed ICU using organizational change, provider education, and provider reminder systems. The baseline period had 349 ventilator patients and 23 cases of VAP, postintervention there were 360 ventilator patients with 22 cases of VAP.111 Poisson regression analysis was performed to assess the effect of the intervention on the risk of VAP. Adherence was not reported. While the postintervention VAP rate decreased from 25.0 to 22.3 infections per 1,000 ventilator-days, regression analysis did not demonstrate an association between the intervention and VAP rate (adjusted rate ratio 0.86, 95% CI: 0.71 to 1.05).

###### Harris et al. (2011)74

Harris et al. reported on VAP rates in pediatric ICUs within the United States assessing the impact of organizational change, provider education, audit and feedback and provider reminder systems.74 There were a total of 2,379 patients within this 3-year study. The study was broken up into baseline, intervention and postintervention periods. Infection rates were analyzed using logistic regression. Adherence to intervention was not assessed. Outcomes were adjusted for patient's age, sex, race, insurance coverage, comorbidities, and specialty of treating physician. Overall infection rate (per 1000 ventilator-days) changed from 1.9 to 2.6 to 0.7. The odds ratios for the intervention (OR: 1.44; 95% CI: 0.71 to 2.92) and postintervention (OR: 0.37; 95% CI: 0.15 to 0.97) were compared to baseline (p<0.05). Average costs of PICU stay decreased from $34,365 to $30,175 to $25,938 during the three study periods and were statistically significant when compared to baseline (p<0.01). Average costs of hospital stay decreased from $54,323 to $46,773 to $42,071 during the study periods and were also statistically significant when compared to baseline. Adjusted costs were also reported.

###### Dubose et al. (2010)112

Dubose et al. described a 13-month intervention using a Quality Rounds Checklist to reduce VAP in a trauma ICU.112 The complete intervention included audit and feedback, organizational change, provider education, and provider reminder systems. There were 577 patients with 33 cases of VAP in the baseline period and 570 patients and 25 cases of VAP in the intervention period. Multivariable logistic regression was used to obtain adjusted rates of VAP. Data showing increased rates of adherence were presented but no statistical analysis was reported. There was a statistically significant improvement in the VAP rate decreasing from 12.41 to 8.74 infections per 1,000 ventilator-days (adjusted mean difference 6.652, 95% CI: 4.04 to 9.27; p=0.008).

###### Kulvatunyou et al. (2007)113

Kulvatunyou et al. described their 1-year intervention of provider education and organizational change to reduce VAP in a six bed surgical ICU.113 There were 85 and 89 patients in the baseline and intervention periods, respectively, requiring ventilator support for 48 hours or more, and there were 42 cases of VAP during baseline and 11 during the intervention. Multiple logistic regression analysis was performed to identify independent risk factors associated with VAP. No data on adherence were presented. The VAP rate decreased from 39.7 to 10.5 infections per 1,000 ventilator-days (p<0.001).

#### Studies That Do Not Control for Confounding or Secular Trend

Twenty-five studies that addressed prevention of ventilator-associated pneumonia used a simple two sample test to analyze outcomes80,82,89,91,94,97,103,114-131 (Appendix Table F1). All 25 studies were simple before-after study designs. QI strategies to reduce rates of VAP were as follows: 18 used audit and feedback,80,82,94,97,114,115,117-119,121-125,127,128,130,131 18 provider education,80,89,94,103,114-119,121-124,127,128,130,131 17 organizational change,80,94,97,114-116,118-121,124-130 and 7 used provider reminder systems.91,114,122,124,125,129,130 Nineteen studies used 2 or more QI strategies.80,94,97,114-119,121-125,127-131 The combination of audit and feedback with the base strategies was used in 13 studies;80,94,97,115,117-119,121,123,125,127,128,131 Five studies114,122,124,125,130 added provider reminder systems to this combined approach. Fifteen of these studies were from the United States.80,82,94,97,114-116,119,122-127,129 There were less than 30 postintervention cases of VAP in 8 of 13 studies reporting this information.80,89,114,115,119,120,124,129

#### Strength of Evidence

As noted in the initial section of this chapter, evidence from studies was evaluated based on the combination of QI strategies that were performed. The strength of evidence for the most common combinations of QI strategies to promote adherence to preventive interventions and reduce VAP rates are presented in Table 19 to Table 24. For all of these tables, except for “readiness for weaning,” adherence rates are considered direct measures. An objective of this review is to assess whether QI strategies improved adherence to evidence-based practices that have been shown to reduce rates of HAI including VAP. Therefore, adherence to process measures is considered a direct measure for this review.

Table 19 Audit and feedback and provider reminder systems with the base strategies compared with usual care within VAP

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: overall/summary | 1 controlled study107 2 interrupted time series51,109 | Medium | Consistent | Direct | Precise | Moderate
Adherence: HOB elevation | 2 controlled studies58,107 2 interrupted time series51,109 | Medium | Consistent | Direct | Precise | Moderate
Adherence: oral care | 1 controlled study107 2 interrupted time series51,109 | Medium | Consistent | Direct | Precise | Moderate
Adherence: readiness to wean | 2 controlled studies58,107 1 interrupted time series51 | Medium | Consistent | Indirect | Imprecise | Insufficient
Infection rate | 1 Controlled study107 3 interrupted time series50,51,109 3 simple before-after 56,74,112 | Medium | Consistent | Direct | Precise | Moderate
Adherence and infection rates | 1 controlled study107 2 interrupted time series51,109 | Medium | Consistent | Direct | Precise | Moderate

Abbreviations: HOB = head of bed; VAP = ventilator-associated pneumonia.

Note: The base strategies are organizational change and provider education.

Table 20 Audit and feedback with the base strategies compared with usual care within VAP

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: overall/Summary | 2 simple before-after 47,67 | Medium | Consistent | Direct | Precise | Moderate
Adherence: hand hygiene | 1 simple before after 48 | High | Unknown | Direct | Imprecise | Insufficient
Infection rate | 2 interrupted time series55,57 3 simple before-after 47,48,67 | Medium | Consistent | Direct | Precise | Moderate
Adherence and infection rates | 3 simple before-after 47,48,67 | Medium | Consistent | Direct | Precise | Moderate

Abbreviation: VAP = ventilator-associated pneumonia.

Note: The base strategies are organizational change and provider education.

Table 21 Provider reminder systems with the base strategies within VAP compared with usual care

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Infection rate | 1 simple before-after study111 | High | Unknown | Direct | Imprecise | Insufficient

Note: The base strategies are organizational change and provider education. VAP = ventilator-associated pneumonia

Table 22 Base strategies within VAP compared with usual care

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: HOB elevation | 1 controlled study108 | Medium | Unknown | Direct | Imprecise | Insufficient
Infection rate | 1 controlled study108 2 simple before-after studies110,113 | High | Consistent | Direct | Imprecise | Insufficient
Adherence and infection rates | 1 controlled study108 | Medium | Consistent | Direct | Imprecise | Insufficient

Abbreviations: HOB = head of bed; VAP = ventilator-associated pneumonia.

Note: The base strategies are organizational change and provider education.

Table 23 Audit and feedback with the base strategies within VAP compared with low intensity intervention

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: Overall Summary | 1 Nonrandomized stepped wedge53 | Medium | Unknown | Direct | Imprecise | Insufficient
Infection rate | 1 Nonrandomized stepped wedge53 | Medium | Unknown | Direct | Imprecise | Insufficient
Adherence and infection rates | 1 Nonrandomized stepped wedge53 | Medium | Unknown | Direct | Imprecise | Insufficient

Table 24 Base strategies within VAP compared with low intensity intervention

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Infection rate | 1 Controlled study60 | Medium | Unknown | Direct | Imprecise | Insufficient

##### Audit and Feedback and Provider Reminder Systems With the Base Strategies Compared With Usual Care

Overall, strength of evidence for most outcomes in the eight studies using this combination of strategies is moderate, including adherence rates (overall, head of bed elevation, and oral care) and for studies that measured infection rate and both adherence and infection rate. Strength of evidence is insufficient for the adherence measure of “readiness to wean” (Table 19). One of these studies presented results on costs/savings using this combined QI approach.74

###### Overall Adherence

Three studies reported this outcome.51,107,109 As shown in Table 17, 1 study107 is of higher quality, 1 is medium,109 and 1 is lower.51 However, the higher-quality study did not measure adherence during the baseline period. These studies are quasi-experimental. The risk of bias is medium. Zaydfudim et al.107 showed an increase in overall adherence from 39 percent to 89 percent (p<0.001), Bouadma et al.109,132 showed an increase in adherence with the complete bundle from 0 to 28.2 percent (p<0.0001),and Hawe et al. (2009)51 showed an increase from 0 percent to 54 percent (p<0.0001). These results are consistent given the similar direction of change. This outcome is a direct measure of adherence. Given the direction and magnitude of change, the evidence is judged to be precise. The strength of evidence is considered to be moderate that audit and feedback and provider reminder systems with the base strategies improves overall adherence to a bundle of VAP preventive interventions compared with usual care.

###### Head of Bed Elevation

Four studies reported this outcome.51,58,107,109 As shown in Table 17, 1 study107 is of higher quality, 2^58,109^ are medium, and 1^51^ is lower. However, the higher quality study did not measure adherence during the baseline period. Three of the 4 studies are quasi-experimental, and the cluster randomized, controlled trial had limitations (see below); thus this body of evidence was judged to have a medium risk of bias.

Three of the 4 studies showed a statistically significant increase in adherence rate for head of bed elevation: Zaydfudim et al. 107 found an increase from 92 percent (95% CI: 89 to 95%) to 98 percent (95% CI: 97 to 99%) during the intervention; Bouadma et al.109,132 found an increase of 5 percent to 58 percent (p<0.0001); and Hawe et al.51 reported an increase from 54 percent to 94 percent (p<0.001). In the cluster randomized, controlled trial, Scales et al.58 reported an increase in head of bed elevation adherence from 49.8 percent to 89.6 percent in the intervention group; this change during the intervention was statistically significant, but when analyzed compared to the control group, the summary ratio of odds ratios was not statistically significant (3.12; 95% CI: 0.79 to 12.41; p=0.11). Although Scales et al. conducted a cluster randomized, controlled trial, it was limited by the small number of units randomized and it was the shortest in duration, 4 months, compared with 10 months or more for the other studies. As discussed above, Scales et al.58 had a number of limitations, many of which may have introduced bias to accept the null hypothesis. These results are judged as consistent given the similar direction of change.

Head of bed elevation is a direct measure of adherence. Based on the direction and magnitude of change, the evidence was judged to be precise. The strength of evidence is considered to be moderate that audit and feedback and provider reminder systems with the base strategies improves adherence to head of bed elevation compared with usual care.

###### Oral Care

Three studies reported this outcome.51,107,109 As shown in Table 17, 1 study107 is of higher quality, 1^109^ is medium, and 1^51^ is lower. However, the higher-quality study did not measure adherence during the baseline period. These 3 studies are quasi-experimental; thus this body of evidence was judged to have a medium risk of bias.

The 3 studies showed a statistically significant increase in adherence rate for oral care: Zaydfudim et al.107 found an increase from 84 percent (95% CI: 78 to 90%) to 98 percent (95% CI: 97 to 98%) during the intervention; Bouadma et al.109,132 found an increase of 47 percent to 90 percent (p<0.0001); and Hawe et al.51 reported an increase of 8 percent to 100 percent (p<0.001). These results are judged as consistent.

Oral care is a direct measure of adherence. Based on the direction and magnitude of change, the evidence was judged to be precise. The strength of evidence is considered to be moderate that audit and feedback and provider reminder systems with the base strategies improves adherence to oral care compared with usual care.

###### Assessment of Readiness of Ventilator Weaning

Three studies reported adherence related to this preventive intervention.51,58,107 The studies report slightly different adherence rates: Zaydfudim et al.107 and Scales et al.58 reported adherence to spontaneous breathing trials, while Hawe et al. (2009)51 reported on adherence to both daily assessment on readiness to wean and daily sedation holidays. As shown in Table 17, 1 study107 is of higher quality, 1^58^ is medium quality, and 1^51^ is lower. However, Zaydfudim et al.107 did not measure adherence during the baseline period. One study58 is a cluster randomized, controlled trial (with limitations already noted above) and the other 2 are quasi-experimental.51,107 These studies were judged to have a medium risk of bias.

All measures showed improved adherence; however, only one change was statistically significant. Hawe et al.51 noted that adherence with daily assessment of readiness to wean improved significantly from 52 percent to 72 percent (p=0.039) but that adherence to daily sedation holiday changed from 72 percent to 82 percent (p=0.23). Zaydfudim et al.107 noted nonsignificant change in adherence with spontaneous breathing trials of 86 percent to 97 percent; and the cluster randomized, controlled trial from Scales et al.58 found a change in adherence to spontaneous breathing trials from 78.8 percent to 85.1 percent in the experimental ICUs and from 90.9 to 89.6 percent in the control ICUs. Neither the odds ratio for change during the 4 month intervention (1.35; 95% CI: 0.44 to 4.12; p=0.57) nor the summary ratio of odds ratios for experimental versus control (1.04; 95% CI: 0.21 to 5.03; p=0.96) was statistically significant. These results are judged to be consistent. This outcome is considered indirect because not all of the studies used direct measures of readiness of ventilator weaning.

With the lack of statistically significant change in three of the four measures, this is judged as imprecise. The strength of evidence is considered to be insufficient that audit and feedback and provider reminder systems with the base strategies improves adherence to assessment of readiness of ventilator weaning compared with usual care.

###### Infection Rate

Seven studies reported this outcome.50,51,56,74,107,109,112 As shown in Table 17, 1 study107 is of higher quality, 1^109^ is medium, and 5^50,51,56,74,112^ are lower. The evidence is quasi-experimental; these studies were judged to have a medium risk of bias. Six of the seven studies showed a statistically significant improvement (i.e., decrease) in VAP rate: Bouadma et al.109 found a decrease from 22.6 to 13.1 infections per 1,000 ventilator-days (p=0.001); Hawe et al.51 noted a decrease from 19.2 to 7.5 infections per 1,000 ventilator-days and the rate ratio was 0.39 (99% CI: 0.16 to 0.96); Dubose et al.112 found a decrease from 12.41 to 8.74 (p=0.008); Cheema at al.50 found a decrease from 4.2 to 0.8 (p<0.05); Morris et al.56 reported a decrease from 32 to 12 (p<0.001); and Harris et al.74 found a decrease from 1.9 to 0.7 (p<0.05). In the seventh study, Zaydfudim et al.107 noted the mean VAP rate decreased from a baseline of 15.2 (SD, 7.0) to 9.3 (SD, 4.9) per 1,000 ventilator-days in the intervention period (p=0.01), but analysis using the more rigorous segmented linear regression found that the change was not statistically significant (p=0.37). These results are judged as consistent. Infection rate is a direct measure. Again, based on the direction and magnitude of change, the evidence was judged to be precise. The strength of evidence is considered to be moderate that audit and feedback and provider reminder systems with the base strategies improves (i.e., decreases) VAP rate compared with usual care.

###### Adherence and Infection Rate

Three studies reported this combination of outcomes.51,107,109 As shown in Table 16, 1 study107 is of higher quality, one109 is medium, and 1^51^ is lower. Given these quasi-experimental studies, the risk of bias is medium. All of the studies show a statistically significant increase in adherence for at least 2 of the preventive interventions and the two studies that measured overall adherence showed improvement. Two of the three studies also showed an improvement (i.e., decrease) in VAP rates, and in the third study,107 the decrease was not statistically significant by time series analysis. This evidence is judged to be consistent. As noted above, these are direct measures. Finally, the evidence is judged to be precise given the direction and magnitude of change as described above, even when considering the adherence results for assessing readiness for ventilator weaning. The strength of evidence is considered to be moderate that audit and feedback and provider reminder systems with the base strategies improves both adherence and improves (i.e., decreases) VAP rate compared with usual care.

###### Cost/Savings

Only 1 study by Harris et al.74 reported on this outcome, which will be discussed in the section on Key Question 1b.

##### Audit and Feedback With the Base Strategies Compared With Usual Care

Overall, strength of evidence is moderate related to the 4 studies using this QI approach to reduce infection rates and is low for overall adherence and studies that measure both adherence and infection rate (Table 20). None of these studies reported results for costs/savings related to this QI approach.

###### Overall Adherence

Two studies reported this outcome.47,67 As shown in Table 17, both studies are of lower quality.47,67 The evidence from the 2 lower quality studies comes from large statewide initiatives and is quasi-experimental. The evidence was judged to have a medium risk of bias. Both studies showed a statistically significant improvement in overall adherence: Berenholtz et al.47 found an increase from 32 to 84 percent (p<0.001), and DePalo et al.67 found an increase of 60 to 78 percent (p<0.0001). These results are judged as consistent. Overall adherence is a direct measure. Based on the direction and magnitude of change, as well as the generalizability of these data from statewide initiatives, this evidence was judged to be precise. The strength of evidence is considered to be moderate that audit and feedback with the base strategies improves adherence to overall VAP preventive interventions.

###### Hand Hygiene

Only 1 study, Barrera et al., reported on this outcome.48 Thus, strength of evidence is insufficient.

###### Infection Rate

Five studies reported this outcome.47,48,55,57,67 As shown in Table 17, 1 study57 is of medium quality and 4^47,48,55,67^ are lower quality, although Berenholtz et al.47 and DePalo et al.67 represent 2 large statewide initiatives with multiple postintervention measurements. The evidence is quasi-experimental; these studies were judged to have a medium risk of bias. Four of the 5 studies showed a statistically significant improvement (i.e., decrease) in VAP rate: Papadimos et al.57 found a decrease from 19.3 to 7.3 infections per 1,000 ventilator-days (p=0.0004), Marra et al.55 noted a decrease from 16.4 to 10.4 infections per 1,000 ventilator-days (p=0.05 by ANOVA), and Berenholtz et al.47 found a decrease in the median rate from 5.5 to 0 (p<0.001). DePalo et al.67 noted the median VAP rate decreased from 0.58, the lowest baseline rate, to 0 (p=0.08). Furthermore, Barrera et al.48 reported a nonsignificant increase in VAP rates over the study period (9 vs. 14 infections per 1,000 ventilator-days, p=0.87) These results are judged as consistent. Infection rate is a direct measure. Based on the direction and magnitude of change, and noting that Berenholtz et al. (2011)47 and DePalo et al. (2010)67 are statewide initiatives, the evidence was judged to be precise. The strength of evidence is considered to be moderate that audit and feedback with the base strategies improve (i.e., decrease) the VAP rate compared with usual care.

###### Adherence and Infection Rate

Three studies reported this outcome.47,48,67 As shown in Table 17, all 3 studies are of lower quality.47,48,67 The evidence from 2 of the lower quality studies come from large statewide initiatives.47,67 The evidence was judged to have a medium risk of bias.

All 3 studies showed a statistically significant improvement in adherence and one47 of the 3 also showed a significant decrease in VAP rate. The change in VAP rate for the DePalo et al.67 study was not statistically significant and Barrera et al.48 reported a nonsignificant increase in VAP rates. These results are judged as consistent. These are direct measures. Based on the direction and magnitude of change from these 2 statewide initiatives, the evidence was judged to be precise. The strength of evidence is considered to be moderate that audit and feedback with the base strategies improves both adherence and improves (i.e., decreases) VAP rate.

##### Provider Reminder Systems With the Base Strategies Compared With Usual Care

Overall, strength of evidence is insufficient for improving infection rate related to this QI approach.

One study, Omrane et al. (2007),111 reported on use of this strategy; statistical analysis was only performed for infection rate. The strength of evidence is insufficient (Table 21).

##### Base Strategies Compared With Usual Care

Overall, strength of evidence for the 3 studies using the base strategies is insufficient for improving head of bed elevation, and insufficient for improving VAP rate and for studies that measure both adherence and infection rate (Table 22).

###### Head of Bed Elevation

Only 1 study, Apisarnthanarak et al. (2007), reported on this outcome.108 Thus, strength of evidence is insufficient.

###### Infection Rate

Three studies reported this outcome.108,110,113 As shown Table 17, one study108 is of higher quality and two110,113 are lower quality. The evidence is quasi-experimental. One of the higher quality studies is from a single 8-bed medical ICU.108 The two lower quality studies are small simple before-after studies. This evidence was judged to have a high risk of bias. All showed a statistically significant improvement (i.e., decrease) in VAP rate: Apisarnthanarak et al.108 found a decrease from 20.6 to 8.5 infections per 1,000 ventilator-days (p=0.002), which remained low (4.2 infections per 1,000 ventilator-days) during years 2 and 3; Prospero et al.110 found a decrease from 36.9 to 22.5 infections per 1,000 ventilator-days (p=0.03), and Kulvatunyou et al.113 found a decrease in the rate from 39.7 to 10.5 (p<0.001). These results are judged as consistent. Infection rate is a direct measure. The evidence is judged to be imprecise since it is primarily from small simple before-after studies. The strength of evidence is considered to be insufficient that the base strategies improve (i.e., decrease) VAP rate compared with usual care.

###### Adherence and Infection Rate

Only 1 study, Apisarnthanarak et al. (2007), reported on this outcome.108 Thus, strength of evidence is insufficient.

###### Cost/Savings

Only 1 study, Apisarnthanarak et al. (2007), reported on this outcome, which will be discussed in the section on Key Question 1b.108

##### Audit and Feedback With the Base Strategies Compared With a Low Intensity Intervention

One study compared the use of audit and feedback with the base strategies with provider education and a provider reminder system.53

Lilly et al. compared a tele-ICU health care delivery system to the use of provider education and a paper checklist.53 During the postintervention period, patients were more than twice as likely to receive the VAP preventive interventions as those in the baseline period (OR: 2.2; 95% CI: 1.79 to 2.7; p<0.001). The study also showed an 85 percent decrease in odds of developing an infection in the postintervention period (p<0.001). The infection rate decreased from 13 percent to 1.6 percent (p<0.001). The risk of bias was judged to be medium due to the medium study quality rating. With 1 study the consistency is unknown and the evidence is imprecise (Table 23). The strength of evidence is considered to be insufficient that audit and feedback and the base strategies improve (i.e., decrease) VAP rate compared with a low intensity intervention.

##### Base Strategies Compared With Low intensity Intervention

One study used a combination of organizational change and provider education compared with a low intensity intervention.60

Speroff et al. compared the use of a virtual collaborative to the use of a toolkit. The study was of higher quality and involved 60 hospitals.60 Due to the quality of the study, the risk of bias was rated as medium. With only 1 study the consistency is unknown. Infection rate is a direct measure and the evidence was deemed imprecise. The study showed no differential effect on infection rates (p=0.80). The strength of evidence was considered to be insufficient that the base strategies improve (i.e., decrease) VAP rates compared with a low intensity intervention (Table 24).

### Surgical Site Infection (SSI)

#### Overview

A total of 15 studies, four133-136 from the 2007 report and an additional 11^52,137-146^ identified from the current literature search, used quality improvement (QI) strategies to implement preventive interventions aimed at reducing SSI. These studies controlled for confounding or secular trends, and met all other criteria for inclusion in this systematic review. There were 2 randomized, controlled trials,52,133 1 controlled before after study,134 1 nonrandomized stepped wedge design,137 1 interrupted time series,138 and 10 simple before-after studies.135,136,139-146 Most studies used multiple QI strategies: 2 studies implemented four strategies,137,140 5 studies implemented three QI strategies,52,135,138,139,142 4 studies implemented two strategies,134,136,144,145 and 4 studies implemented one QI strategy.133,141,143,146 All but 3 studies used organizational change as one of their strategies.133,143,145 Nine of the 15 studies included a provider education component.52,134,135,137-140,142,145 Seven of the 15 studies implemented an audit and feedback strategy,52,135-138,140,145 and seven of the 15 studies133,137,139,140,142-144 included a provider reminder system (Table 25 and Table 26).

Table 25 Overview of SSI articles that control for confounding or secular trends

Author, location-year | Study type | Analysis for infection rates | Sample size (infections) | Organizational change | Provider education | Audit and feedback | Provider reminder systems | Patient education | Financial incentives
Kritchevsky, United States - 2008^52^ | Cluster RCT | Logistic regression | control pre: 2234 control post: 2238 study pre: 2213 study post: 2225 | • | • | •
Zanetti, United States - 2003^133^ | Individual RCT | Likelihood ratio test | control: 136 (8) study: 137 (5) | | | | •
Kao, United States - 2010^137^ | Stepped wedge (non-randomized) | Generalized linear model | pre hosp1: 119 (2) post hosp1: 115 (5) pre hosp2: 92 (3) post hosp2: 169 (0) | • | • | • | •
Gastmeier, Germany - 2002^134^ | Controlled before-after | Cox regression | control: 4848 (122^a^) study: 6447 (130^a^) | • | •
Mannien, Netherlands - 2006^138^/179 | Interrupted time series | Non-linear mixed model | pre: 1668 (90^*^) post: 1953 (88^*^) | • | • | •
Schwann, United States - 2011^143^ | Simple before-after | Logistic regression | pre: 9,127 (101^*^) post: 10,617 (75^*^) | | | | •
Dellinger, United States - 2005^136^ | Simple before-after | Poisson regression | | • | | •
Greco, Italy - 1991^135^ | Simple before-after | Mantel-Haenszel relative risks | pre: 4096 (286^*^) post: 1638 (101^*^) | • | • | •
Burkitt, United States - 2009^139^ | Simple before-after | Logistic regression | pre: 2550 post: 1779 | • | • | | •
Kestle, United States - 2011^144^ | Simple before-after | Logistic regression | pre: 896 (79) post: 1571 (89) | • | | | •
Salim, Israel - 2011^145^ | Simple before-after | Logistic and Poisson regression | pre: 751 (37) post: 865 (18) | | • | •
Hedrick, United States - 2007^140^/180 | Simple before-after | Logistic regression | pre: 379 (35^*^) post: 390 (22^*^) | • | • | • | •
Kaimal, United States - 2008^141^ | Simple before-after | Logistic regression | pre: 800 (51^*^) post: 516 (13^*^) | •
Trussell, United States - 2008^142^ | Simple before-after | Logistic regression | pre: 808 (28^*^) post: 674 (10^*^) | • | • | | •
Lavu, United States - 2011^146^ | Simple before-after | Logistic regression | pre: 233 (35) post: 233 (18) | •

* Number of infections was estimated from infection rates.

a Number of infections reflect the sum of all infections during all three study periods

Table 26 Specific attributes of organizational change implemented in SSI articles that control for confounding or secular trend

Author, Country-Publication Year | Multidisciplinary Team | Team Responsibilities | Hospital Executives on Team | New Protocol or Standards Implemented | Designate Staff Member Responsible for Implementation
Kritchevsky, United States - 2008^52^ | | | | •
Kao, United States - 2010^137^ | • | Identify barriers to adherence with SCIP antibiotic prophylaxis adherence | | • | •
Mannien, Netherlands - 2006^138^/179 | • | | | •
Gastmeier, Germany - 2002^134^ | • | Evaluated infection control measures, developed interventions to improve adherence, and ensured implementation of interventions | | •
Burkitt, United States - 2009^139^ | • | Identify obstacles and develop solutions for appropriate antibiotic use | | •
Kestle, United States - 2011^144^ | | | | •
Hedrick, United States - 2007^140^/180 | • | Develop an aim statement, select a target population, define outcomes and process measures, and begin collecting baseline data | | • | •
Kaimal, United States - 2008^141^ | • | Define magnitude of SSI problem, develop and implement an action plan | • | • | •
Trussell, United States - 2008^142^ | • | Develop protocol | | • | •
Lavu, United States - 2011^146^ | | | | •

Outcomes of interest in this review were adherence rates, infection rates, and cost analyses. Adherence rates most often reported related to appropriate antibiotic prophylaxis use, which in some studies was separated into antibiotic selection, timing of antibiotic administration, and duration of antibiotic. Other adherence rates included maintaining normothermia, appropriate hair removal, and glucose control. Eight of the 15 studies reported both adherence rates and infection rates,133,135-138,140,142,143 two of the 15 studies reported only adherence rates,52,139 and five of the 15 studies134,141,144-146 reported only infection rates. None of the 15 studies reported cost analyses.

Eleven of the 15 studies were conducted in the United States,52,133,136,137,139-144,146 with one study each from the Netherlands,138 Germany,134 Italy,135 and Israel.145 There were 7 multicenter studies. One of the randomized, controlled trials involved 44 hospitals,52 the controlled before-after study from Germany involved eight hospitals,134 the interrupted time series collected data from 12 hospitals,138 the nonrandomized stepped wedge study was implemented in two hospitals,137 the simple before-after study from the US136 involved 56 hospitals, the simple before-after study from Italy135 was implemented in 9 wards across several hospitals, and another simple before-after study was implemented in four surgical centers around North America.144 The remaining 8 studies were implemented in a single site.133,139-143,145,146 Sample sizes in the postintervention period varied, from 115 to 10,617. Postintervention rates of SSI ranged from 0 to 7.7 percent. Eight of the 15 studies provided baseline SSI rates,137,138,140-143,145,146 ranging from 1.1 to 15.0 percent.

An additional 34 studies99,103,147-178 were identified in the literature search which used QI strategies aimed at reducing SSI, but did not perform analyses to control for confounding or secular trends (Appendix Table F3). These studies were not included in the following analyses due to their weak designs and potential for biased results.

#### Methodological Quality of Included Studies

The 15 included studies were given a rating of higher, medium, or lower, based on the study design and the five dimensions The 2 randomized, controlled trials were rated higher quality,52,133 the controlled before-after study, the nonrandomized stepped wedge and interrupted time series were rated medium quality,134,137,138 and the ten simple before-after studies135,136,139-146 were rated lower quality (Table 27).

Table 27 Methodological quality for SSI articles that control for confounding or secular trend

Author, Location-Year | Study Type | Sufficient followup^a^ | Adequate control for confounding or secular trend^b^ | Change in adherence was analyzed^c^ | Change in infection rate was analyzed^d^ | Independent of other QI effort^e^ | Overall quality rating | Comments
Kritchevsky, United States - 2008^52^ | Cluster RCT | + | + | + | - | N/A | Higher | Infection rates were not reported.
Zanetti, United States - 2003^133^ | Individual RCT | - | + | + | + | N/A | Higher
Kao, United States - 2010^137^ | Stepped wedge (non-randomized) | + | + | + | - | - | Medium | Infection rates were reported, but no pre-post statistical comparisons were made.
Gastmeier, Germany - 2002^134^ | Controlled before-after | + | + | - | + | - | Medium | Study hospitals were chosen based on their interest in quality management activities. Control hospitals were allowed to initiate QI efforts and active surveillance if they wished.
Mannien, Netherlands - 2006^138^/179 | Interrupted time series | + | + | + | + | + | Medium
Schwann, United States - 2011^143^ | Simple before-after | + | + | + | + | ? | Lower | There was a JCHAO visit during the baseline period that may have affected provider behavior. Postdischarge surveillance was limited to positive cultures only.
Dellinger, United States - 2005^136^ | Simple before-after | - | + | + | + | ? | Lower | Many hospitals started surveillance part way through the intervention.
Greco, Italy - 1991^135^ | Simple before-after | - | + | + | + | ? | Lower | Followup was only 6 months. They did not conduct postdischarge surveillance.
Burkitt, United States - 2009^139^ | Simple before-after | + | + | + | - | - | Lower | Infection rates were not reported.
Kestle, United States - 2011^144^ | Simple before-after | + | - | + | + | ? | Lower | Association between each protocol item and infection rates was assessed, but change in adherence rates was not analyzed.
Salim, Israel – 2011^145^ | Simple before-after | + | + | - | + | ? | Lower | Adherence was not measured.
Hedrick, United States - 2007^140^/180 | Simple before-after | - | - | + | + | ? | Lower
Kaimal, United States - 2008^141^ | Simple before-after | + | - | - | + | ? | Lower | Adherence rates were not reported.
Trussell, United States - 2008^142^ | Simple before-after | + | - | + | + | ? | Lower
Lavu, United States - 2011^146^ | Simple before-after | + | + | - | + | ? | Lower | Adherence rates were not reported.

Note: All studies used standard and consistent infection definitions. Mannien et al., Hedrick et al., and Trussell et al. used the CDC methodology.

Independence from other QI efforts was not applicable for randomized controlled trials.

a Is the length of followup sufficient (at least 12 months) to support the evaluation of primary outcomes and harms?

b Were adequate measures taken to control for confounding or secular trend?

c Was change in adherence analyzed?

d Was change in infection rate analyzed?

e Was the intervention performed independent of other QI efforts or other changes?

‘+’ means ‘yes’ ‘-’ means ‘no’ ‘?’ means ‘uncertain’

Eleven of the 15 studies had followup of at least 1 year,52,134,137-139,141-146 11 of the 15 studies controlled for confounding or secular trends in their analyses,52,133-139,143,145,146 11 of the 15 studies analyzed change in adherence rates,52,133,135-140,142-144 and 12 of the 15 studies analyzed change in infection rates.133-136,138,140-146 One of the 15 studies explicitly stated that the hospitals involved in the study agreed not to introduce other interventions during the study period.138

#### Studies That Control for Confounding or Secular Trend

##### Controlled Studies

###### Kritchevsky et al. (2008)52

###### Summary

In a cluster randomized trial, Kritchevsky et al.52 compared adherence to antimicrobial prophylaxis measures among hospitals receiving audit and feedback reports alone, versus hospitals receiving audit and feedback reports plus support through a QI collaborative. In this particular study, membership in the QI collaborative did not provide a significant incremental improvement in adherence rates. Infection data were not collected.

###### Description

Forty-four hospitals were matched on adherence to prophylactic antibiotic timing in the baseline period and stratified by average daily census. Twenty-two hospitals were then randomized into the audit and feedback only group and 22 hospitals were assigned to the audit and feedback plus QI collaborative group. The feedback only group received a customized comparative report of five antibiotic performance measures at the beginning of the study and then did not have further communication with the investigators while they implemented changes at their institutions to improve antibiotic prophylaxis. The intervention group received the same customized report, followed by two onsite meetings and several teleconferences with QI experts. Intervention experiences, guidelines, forms, and literature reviews were shared during monthly conference calls among the intervention hospitals. Both study groups kept logs on intervention strategies that were implemented at their facilities. Baseline data were collected from May 2003 to November 2003, on 2,234 patients from the feedback only hospitals and on 2,213 patients from the intervention hospitals. Followup data were collected from February 2005 to July 2005, on 2,238 patients from the feedback only hospitals and on 2,225 patients from the intervention hospitals. To compare the changes in antibiotic administration, the authors used conditional margins, testing treatment group by time interaction and adjusting for type of surgery, hospital size, and region. Logistic regressions with the jackknife design were run.

###### Results and Limitations

The adjusted difference between the feedback only group and the feedback and QI collaborative group was 6.3 percent (95% CI: -7.3% to 19.8%), showing no incremental improvement through membership in the QI collaborative (Table 28). However, in a pre/post analysis within each study group, significant differences were found within both groups in antibiotic timing and duration (i.e., appropriate discontinuation of antibiotics). For the feedback only group, antibiotic timing improved 10.5 percent (95% CI: 2.7% to 18.3%) and antibiotic duration improved 13.2 percent (95% CI: 2.1% to 24.3%). Adjusted analysis showed that for the feedback and QI collaborative group, antibiotic timing improved 6.7 percent (95% CI: 0.2% to 13.1%) and antibiotic duration improved 21.3 percent (95% CI: 12.5% to 30.1%). Infection data were not reported.

Table 28 Outcomes for SSI articles that control for confounding or secular trend

Author, Country-Year | Intervention/ Comparator | Type of Outcome | Specific Measure | Improve | Worsen | NS | Change in Specific Measure | Comments
Kritchevsky, United States - 2008^52^ | Joining a quality improvement collaborative + audit and feedback program/ Audit and feedback program | Adherence | All or none' prophylactic measures | | | ⋄ | Control: 42.5% → 55.7% Intervention: 38.2% → 57.2% (p=NS) | Analysis reflects difference between intervention groups, not baseline and postintervention change. The adjusted difference between the feedback only group and the feedback and QI collaborative group was 6.3% (95% CI: -7.3 to 19.8%).
Kritchevsky, United States - 2008^52^ | Joining a quality improvement collaborative + audit and feedback program/ Audit and feedback program | Adherence
Kritchevsky, United States - 2008^52^ | Joining a quality improvement collaborative + audit and feedback program/ Audit and feedback program | Adherence | Appropriate timing | | | ⋄ | Control: 74.8% → 85.3% Intervention: 76.3% → 83.2% (p=NS)
Kritchevsky, United States - 2008^52^ | Joining a quality improvement collaborative + audit and feedback program/ Audit and feedback program | Adherence
Kritchevsky, United States - 2008^52^ | Joining a quality improvement collaborative + audit and feedback program/ Audit and feedback program | Adherence | Appropriate duration | | | ⋄ | Control: 54.7%→66.8% Intervention: 51.3%→69.5% (p=NS)
Kritchevsky, United States - 2008^52^ | Joining a quality improvement collaborative + audit and feedback program/ Audit and feedback program | Adherence
Kritchevsky, United States - 2008^52^ | Joining a quality improvement collaborative + audit and feedback program/ Audit and feedback program | Adherence | Appropriate selection | | | ⋄ | Control: 93.4%→95.4% Intervention: 93.8%→94.7% (p=NS)
Kritchevsky, United States - 2008^52^ | Joining a quality improvement collaborative + audit and feedback program/ Audit and feedback program
Kritchevsky, United States - 2008^52^ | Joining a quality improvement collaborative + audit and feedback program/ Audit and feedback program | Infection Rate
Kritchevsky, United States - 2008^52^ | Joining a quality improvement collaborative + audit and feedback program/ Audit and feedback program
Kritchevsky, United States - 2008^52^ | Joining a quality improvement collaborative + audit and feedback program/ Audit and feedback program | Costs/Savings
Zanetti, United States - 2003^133^ | Computer automated reminder system for antibiotic prophylaxis/ No intervention (usual care) | Adherence | Received intraoperative redose | ⋄ | | | Baseline: 27% Control: 40% (p<0.001 compared to baseline) Study: 68% (p<0.001 compared to control) | Adherence in the control group was significantly better than the baseline period (p<0.001) and the study group was significantly better than the control group (p<0.001). Infection rate was not significantly different between groups, but significantly improved from the baseline period (p=0.02).
Zanetti, United States - 2003^133^ | Computer automated reminder system for antibiotic prophylaxis/ No intervention (usual care)
Zanetti, United States - 2003^133^ | Computer automated reminder system for antibiotic prophylaxis/ No intervention (usual care) | Infection Rate | Overall | | | • | Baseline: 10% Control: 6% Study: 4%
Zanetti, United States - 2003^133^ | Computer automated reminder system for antibiotic prophylaxis/ No intervention (usual care)
Zanetti, United States - 2003^133^ | Computer automated reminder system for antibiotic prophylaxis/ No intervention (usual care) | Costs/Savings
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Appropriate timing, selection, and discontinuation after extended timeout (low intensity intervention): | | | | | Hospitals were compared against each other as well as to baseline period. Results to the left represent within hospital comparisons, between baseline and postintervention. Comparisons between hospital 1 and hospital 2: - Hospital 1 had greater overall adherence than hospital 2 (p=0.003). - Patients in hospital 2 were less likely to develop an SSI compared with patients at hospital 1 (OR: 0.23; 95% CI: 0.10 to 0.56; p=0.001). A separate multiple regression analysis demonstrated that nonadherence with the antibiotic guidelines (OR: 2.61; 95% CI: 1.20 to 5.70) and hospital (OR: 0.22; 95% CI: 0.09 to 0.53) were independent predictors of SSI.
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 1 | ⋄ | | | 44% → 70%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 2 | ⋄ | | | 28% → 67%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Appropriate timing, selection, and discontinuation after intervention:
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 1 | | | ⋄ | 70% → 80%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 2 | | | ⋄ | 67% → 70%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Time between antibiotics and incision after extended timeout (low intensity intervention):
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 1 | ⋄ | | | 74% → 90%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 2 | ⋄ | | | 65% → 82%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Time between antibiotics and incision after intervention:
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 1 | | | ⋄ | 90% → 90%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 2 | ⋄ | | | 82% → 98%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Appropriate antibiotic selection after extended timeout (low intensity intervention):
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 1 | ⋄ | | | 61% → 78%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 2 | ⋄ | | | 69% → 80%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Appropriate antibiotic selection after intervention:
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 1 | ⋄ | | | 78% → 90%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 2 | ⋄ | | | 80% → 81%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Appropriate discontinuation after extended timeout (low intensity intervention):
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 1 | | | ⋄ | 92% → 95%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 2 | | | ⋄ | 85% → 91%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Appropriate discontinuation after intervention:
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 1 | | | ⋄ | 95%→93%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Adherence | Hospital 2 | | | ⋄ | 91%→90%^a^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care)
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Infection Rate | | | | | Hospital 1: 2.5% → 10.5% → 4%^a,b^ Hospital 2: 4% → 1.5% → 0%^a,b^
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care)
Kao, United States - 2010^137^ | Extended timeout for 2 hospitals, 1 with added education, 1 with added preop checklist/ No Intervention (usual care) | Costs/Savings
Gastmeier, Germany - 2002^134^ | Quality circles and increased surveillance efforts/ No intervention (usual care) | Adherence | | | | | | Cox regression showed the first intervention period to be a protective factor on all nosocomial infections (HR: 0.75; 95% CI: 0.58 to 0.97). The addition of the enhanced surveillance in the second intervention period does not seem to have an additive protective effect on all nosocomial infections (HR: 0.78; 95% CI: 0.60 to 1.01).
Gastmeier, Germany - 2002^134^ | Quality circles and increased surveillance efforts/ No intervention (usual care)
Gastmeier, Germany - 2002^134^ | Quality circles and increased surveillance efforts/ No intervention (usual care) | Infection Rate | Overall | | | • | SSI incidence densities: Control: 2.6 → 2.5 → 2.0 Study: 2.2 → 1.6 → 2.2
Gastmeier, Germany - 2002^134^ | Quality circles and increased surveillance efforts/ No intervention (usual care)
Gastmeier, Germany - 2002^134^ | Quality circles and increased surveillance efforts/ No intervention (usual care) | Costs/Savings
Mannien, Netherlands - 2006^138^/179 | Optimized antibiotic prophylaxis/ No Intervention (usual care) | Adherence | Inappropriate administration | ⋄ | | | Expected/Observed: 93.5%/37.5% | Time series analysis showed improvements in both antibiotic timing and administration post intervention (p<0.01), but adherence did not impact SSI (p=0.99)
Mannien, Netherlands - 2006^138^/179 | Optimized antibiotic prophylaxis/ No Intervention (usual care) | Adherence | | | | | | Time series analysis showed improvements in both antibiotic timing and administration post intervention (p<0.01), but adherence did not impact SSI (p=0.99)
Mannien, Netherlands - 2006^138^/179 | Optimized antibiotic prophylaxis/ No Intervention (usual care) | Adherence | Inappropriate timing | ⋄ | | | Expected/Observed: 51.8%/39.4% | Time series analysis showed improvements in both antibiotic timing and administration post intervention (p<0.01), but adherence did not impact SSI (p=0.99)
Mannien, Netherlands - 2006^138^/179 | Optimized antibiotic prophylaxis/ No Intervention (usual care) | | | | | | | Time series analysis showed improvements in both antibiotic timing and administration post intervention (p<0.01), but adherence did not impact SSI (p=0.99)
Mannien, Netherlands - 2006^138^/179 | Optimized antibiotic prophylaxis/ No Intervention (usual care) | Infection Rate | Overall | | | • | 5.4%→4.5% (p=0.22) | Time series analysis showed improvements in both antibiotic timing and administration post intervention (p<0.01), but adherence did not impact SSI (p=0.99)
Mannien, Netherlands - 2006^138^/179 | Optimized antibiotic prophylaxis/ No Intervention (usual care) | | | | | | | Time series analysis showed improvements in both antibiotic timing and administration post intervention (p<0.01), but adherence did not impact SSI (p=0.99)
Mannien, Netherlands - 2006^138^/179 | Optimized antibiotic prophylaxis/ No Intervention (usual care) | Costs/Savings | | | | | | Time series analysis showed improvements in both antibiotic timing and administration post intervention (p<0.01), but adherence did not impact SSI (p=0.99)
Schwann, United States - 2011^143^ | Automatic antibiotic administration reminder incorporated into anesthesia information management system/ No Intervention (usual care) | Adherence | Antibiotic timing | ⋄ | | | 62% → 92% (p=0.003) | Outcomes were controlled for inpatient vs. outpatient surgery, location, surgical service, and individual surgeon. ANOVA showed that all postintervention periods are significantly improved from the baseline period for infection rates.
Schwann, United States - 2011^143^ | Automatic antibiotic administration reminder incorporated into anesthesia information management system/ No Intervention (usual care)
Schwann, United States - 2011^143^ | Automatic antibiotic administration reminder incorporated into anesthesia information management system/ No Intervention (usual care) | Infection | Overall | • | | | 1.1% → 0.7% (RR=0.35; 95% CI: 0.13 to 0.52; p=0.003)
Schwann, United States - 2011^143^ | Automatic antibiotic administration reminder incorporated into anesthesia information management system/ No Intervention (usual care)
Schwann, United States - 2011^143^ | Automatic antibiotic administration reminder incorporated into anesthesia information management system/ No Intervention (usual care) | Cost/Savings
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Adherence | Appropriate antibiotic timing | ⋄ | | | Quarterly Median: 72% → 82% → 89% → 92% (p<0.0001) | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Adherence | | | | | | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Adherence | Appropriate antibiotic selection | ⋄ | | | Quarterly Median: 90% → 94% → 95% → 95% (p=0.02) | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Adherence | | | | | | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Adherence | Appropriate antibiotic duration | ⋄ | | | Quarterly Median: 67% → 69% → 74% → 85% (p<0.001) | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Adherence | | | | | | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Adherence | Normothermia | ⋄ | | | Quarterly Median: 57% → 64% → 69% → 74% (p<0.0001) | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Adherence | | | | | | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Adherence | Avoid shaving | ⋄ | | | Quarterly Median: 59% → 83% → 90% → 95% (p=0.006) | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Adherence | | | | | | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Adherence | Glucose control | ⋄ | | | Quarterly Median: 46% → 49% → 53% → 54% (p<0.0001) | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | | | | | | | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Infection Rate | Overall | | | • | 2.3% → 1.7% | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | | | | | | | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Dellinger, United States - 2005^136^ | Nationwide collaborative/ No Intervention (usual care) | Costs/Savings | | | | | | While the trend over time was nonsignificant for infection rates, comparison of the first and last 3 months was significantly different (p=0.0005).
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations/ No Intervention (usual care) | Adherence | Shaving | ⋄ | | | 76.8% → 73.5% (p<0.01) | 3 units reported a significant reduction, 4 had no change, and 2 reported a significant increase in infection rates. Although the decrease in infection rates started before the initiation of the intervention.
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations/ No Intervention (usual care) | Adherence
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations/ No Intervention (usual care) | Adherence | Postoperative prophylaxis | ⋄ | | | 36.9% → 27.2% (p<0.00001)
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations/ No Intervention (usual care)
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations/ No Intervention (usual care) | Infection Rate | Overall (per 100 patients) | | | • | 7.8 → 6.2 (Adjusted RR: 0.85; 95% CI: 0.68 to 1.06)
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations/ No Intervention (usual care) | Infection Rate
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations/ No Intervention (usual care) | Infection Rate | Superficial (per 100 patients) | | | • | 6.7 → 5.7 (Adjusted RR: 0.91; 95% CI: 0.72 to 1.14)
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations/ No Intervention (usual care) | Infection Rate
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations/ No Intervention (usual care) | Infection Rate | Deep (per 100 patients) | | | • | 1.9 → 1.05 (Adjusted RR: 0.63; 95% CI: 0.38 to 1.05)
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations/ No Intervention (usual care)
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations/ No Intervention (usual care) | Costs/Savings
Burkitt, United States - 2009^139^ | Toyota Production System - appropriate antibiotic choice and duration/ No Intervention (usual care) | Adherence | Appropriate selection | | | ⋄ | 64.3% → 65.6% → 59.3% → 64.1% → 63.5% (p=0.49)
Burkitt, United States - 2009^139^ | Toyota Production System - appropriate antibiotic choice and duration/ No Intervention (usual care) | Adherence
Burkitt, United States - 2009^139^ | Toyota Production System - appropriate antibiotic choice and duration/ No Intervention (usual care) | Adherence | Appropriate duration | ⋄ | | | 39.2% → 46.9% → 45.1% → 47.4% → 67.6% (p<0.01)
Burkitt, United States - 2009^139^ | Toyota Production System - appropriate antibiotic choice and duration/ No Intervention (usual care)
Burkitt, United States - 2009^139^ | Toyota Production System - appropriate antibiotic choice and duration/ No Intervention (usual care) | Infection Rate
Burkitt, United States - 2009^139^ | Toyota Production System - appropriate antibiotic choice and duration/ No Intervention (usual care)
Burkitt, United States - 2009^139^ | Toyota Production System - appropriate antibiotic choice and duration/ No Intervention (usual care) | Costs/Savings
Kestle, United States - 2011^144^ | Operating room protocol with flow chart/ No Intervention (usual care) | Adherence | | | | | | Of all of the protocol items, proper hand washing by all team members and double gloving by all team members were significantly associated to lower infection rates (p=0.03 and p=0.04, respectively). Antibiotic-impregnated sutures, and preoperative use of chlorhexidine shampoo were significantly associated with decreased infection rates (3.8% vs. 6.6%; p=0.03 and 3.4% vs. 7.4%; p=0.004, respectively) while BioGlide catheters were associated with significantly higher rates of infection (8.3% vs. 4.5%; p=0.002).
Kestle, United States - 2011^144^ | Operating room protocol with flow chart/ No Intervention (usual care)
Kestle, United States - 2011^144^ | Operating room protocol with flow chart/ No Intervention (usual care) | Infection | Overall | • | | | 8.8% → 5.7% (p=0.003)
Kestle, United States - 2011^144^ | Operating room protocol with flow chart/ No Intervention (usual care)
Kestle, United States - 2011^144^ | Operating room protocol with flow chart/ No Intervention (usual care) | Cost/Savings
Salim, Israel - 2011^145^ | Refresher courses on infection control and catheter insertion/ No Intervention (usual care) | Adherence | | | | | | All ORs and IRRs were adjusted for membrane rupture and duration of operation. Results are also further broken down by elective and nonelective cesarean. More significant results were found in the elective cesarean group.
Salim, Israel - 2011^145^ | Refresher courses on infection control and catheter insertion/ No Intervention (usual care)
Salim, Israel - 2011^145^ | Refresher courses on infection control and catheter insertion/ No Intervention (usual care) | Infection | Overall | • | | | 4.9% → 2.1% (OR=0.4, 95% CI: 0.23 to 0.72, p=0.002)
Salim, Israel - 2011^145^ | Refresher courses on infection control and catheter insertion/ No Intervention (usual care) | Infection
Salim, Israel - 2011^145^ | Refresher courses on infection control and catheter insertion/ No Intervention (usual care) | Infection | Incisional | • | | | 3.5% → 0.9% (OR=0.27, 95% CI: 0.12 to 0.59, p=0.001)
Salim, Israel - 2011^145^ | Refresher courses on infection control and catheter insertion/ No Intervention (usual care) | Infection
Salim, Israel - 2011^145^ | Refresher courses on infection control and catheter insertion/ No Intervention (usual care) | Infection | Organ Space | | | • | 1.6% → 1.2% (OR=0.67, 95% CI: 0.28 to 1.56, p=0.52)
Salim, Israel - 2011^145^ | Refresher courses on infection control and catheter insertion/ No Intervention (usual care)
Salim, Israel - 2011^145^ | Refresher courses on infection control and catheter insertion/ No Intervention (usual care) | Cost/Savings
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | Adherence | Appropriate antibiotic selection | ⋄ | | | 89%→97% (p≤0.05) | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | Adherence | | | | | | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | Adherence | Appropriate timing | ⋄ | | | 89%→97% (p≤0.05) | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | Adherence | | | | | | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | Adherence | Appropriate discontinuation | | | ⋄ | 93%→92% (p=NS) | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | Adherence | | | | | | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | Adherence | Normothermia | | | ⋄ | 85%→90% (p=NS) | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | Adherence | | | | | | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | Adherence | Glucose control | | ⋄ | | 54%→36% (p≤0.05) | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | | | | | | | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | Infection Rate | Overall | | | • | 9.2%→5.6% (p=0.07) | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | | | | | | | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Hedrick, United States - 2007^140^/180 | Bundle - antibiotic prophylaxis/ No Intervention (usual care) | Costs/Savings | | | | | | Nonadherence with any of the preventive interventions was not predictive of SSI. Operative time, colorectal surgery, and age were independent risk factors for SSI.
Kaimal, United States - 2008^141^ | Implement policy on timing of antibiotic prophylaxis/ No Intervention (usual care) | Adherence | | | | | | P-values reflect simple pre-/post-test. Controlling for labor, previous cesarean delivery, parity, maternal age, body mass index, diabetes mellitus, chorioamnionitis and group B streptococcus vaginal culture status, multivariable regression found a significant decrease in overall SSI after the intervention (OR=0.33, 95%CI 0.14 to 0.77).
Kaimal, United States - 2008^141^ | Implement policy on timing of antibiotic prophylaxis/ No Intervention (usual care)
Kaimal, United States - 2008^141^ | Implement policy on timing of antibiotic prophylaxis/ No Intervention (usual care) | Infection Rate | Overall | • | | | 6.4%→2.5% (p=0.02)
Kaimal, United States - 2008^141^ | Implement policy on timing of antibiotic prophylaxis/ No Intervention (usual care) | Infection Rate
Kaimal, United States - 2008^141^ | Implement policy on timing of antibiotic prophylaxis/ No Intervention (usual care) | Infection Rate | Cesareans deliveries before labor | | | • | 2.7%→1.1% (p=0.16)
Kaimal, United States - 2008^141^ | Implement policy on timing of antibiotic prophylaxis/ No Intervention (usual care) | Infection Rate
Kaimal, United States - 2008^141^ | Implement policy on timing of antibiotic prophylaxis/ No Intervention (usual care) | Infection Rate | Cesareans deliveries during labor | • | | | 10.6%→4.2% (p=0.005)
Kaimal, United States - 2008^141^ | Implement policy on timing of antibiotic prophylaxis/ No Intervention (usual care)
Kaimal, United States - 2008^141^ | Implement policy on timing of antibiotic prophylaxis/ No Intervention (usual care) | Costs/Savings
Trussell, United States - 2008^142^ | Protocol pathway for appropriate antibiotic use, hair removal, and glucose control/ No Intervention (usual care) | Adherence | Appropriate timing | ⋄ | | | 81%→94% (p=0.001) | Infection rate p-value is adjusted for diabetes mellitus, gender, and NNIS wound class II, all of which were independent predictors of SSI.
Trussell, United States - 2008^142^ | Protocol pathway for appropriate antibiotic use, hair removal, and glucose control/ No Intervention (usual care) | Adherence | | | | | | Infection rate p-value is adjusted for diabetes mellitus, gender, and NNIS wound class II, all of which were independent predictors of SSI.
Trussell, United States - 2008^142^ | Protocol pathway for appropriate antibiotic use, hair removal, and glucose control/ No Intervention (usual care) | Adherence | Shaving | ⋄ | | | 60%→20% (p=0.001) | Infection rate p-value is adjusted for diabetes mellitus, gender, and NNIS wound class II, all of which were independent predictors of SSI.
Trussell, United States - 2008^142^ | Protocol pathway for appropriate antibiotic use, hair removal, and glucose control/ No Intervention (usual care) | | | | | | | Infection rate p-value is adjusted for diabetes mellitus, gender, and NNIS wound class II, all of which were independent predictors of SSI.
Trussell, United States - 2008^142^ | Protocol pathway for appropriate antibiotic use, hair removal, and glucose control/ No Intervention (usual care) | Infection Rate | Overall | • | | | 3.5%→1.5% (p=0.001) | Infection rate p-value is adjusted for diabetes mellitus, gender, and NNIS wound class II, all of which were independent predictors of SSI.
Trussell, United States - 2008^142^ | Protocol pathway for appropriate antibiotic use, hair removal, and glucose control/ No Intervention (usual care) | | | | | | | Infection rate p-value is adjusted for diabetes mellitus, gender, and NNIS wound class II, all of which were independent predictors of SSI.
Trussell, United States - 2008^142^ | Protocol pathway for appropriate antibiotic use, hair removal, and glucose control/ No Intervention (usual care) | Costs/Savings | | | | | | Infection rate p-value is adjusted for diabetes mellitus, gender, and NNIS wound class II, all of which were independent predictors of SSI.
Lavu, United States - 2011^146^ | Surgical care bundle/ No Intervention (usual care) | Adherence | | | | | | Infection rate was controlled for estimated blood loss, albumin, and hemoglobin A1c. Estimated blood loss and albumin were independent risk factors for SSI (p=0.01 and p=0.012, respectively).
Lavu, United States - 2011^146^ | Surgical care bundle/ No Intervention (usual care) | | | | | | | Infection rate was controlled for estimated blood loss, albumin, and hemoglobin A1c. Estimated blood loss and albumin were independent risk factors for SSI (p=0.01 and p=0.012, respectively).
Lavu, United States - 2011^146^ | Surgical care bundle/ No Intervention (usual care) | Infection | Overall | • | | | 15% → 7.7% (p<0.001) | Infection rate was controlled for estimated blood loss, albumin, and hemoglobin A1c. Estimated blood loss and albumin were independent risk factors for SSI (p=0.01 and p=0.012, respectively).
Lavu, United States - 2011^146^ | Surgical care bundle/ No Intervention (usual care) | | | | | | | Infection rate was controlled for estimated blood loss, albumin, and hemoglobin A1c. Estimated blood loss and albumin were independent risk factors for SSI (p=0.01 and p=0.012, respectively).
Lavu, United States - 2011^146^ | Surgical care bundle/ No Intervention (usual care) | Cost/Savings | | | | | | Infection rate was controlled for estimated blood loss, albumin, and hemoglobin A1c. Estimated blood loss and albumin were independent risk factors for SSI (p=0.01 and p=0.012, respectively).

Abbreviations: NS = nonsignificant; OR = odds ratio; CI = confidence interval; NNIS = National Nosocomial Infections Surveillance

• was used for infection rate outcomes

⋄ was used for adherence and costs/savings outcomes

a Numbers were extrapolated from a graph

b Reported, but not analyzed

A limitation of this study is that there was overlap in the type of QI strategies implemented in the two study groups. In an appendix to this study, information from the intervention strategy logs showed that common strategies were implemented in both study groups in similar proportions. For example, supplemental education occurred in 71 percent of the feedback only hospitals and 68 percent of the intervention hospitals, and process changes were implemented in 67 percent of the feedback only hospitals and 64 percent of the intervention hospitals. With similar QI strategies implemented in both groups, differences between the two groups are difficult to detect.

###### Zanetti et al. (2003)133

Zanetti et al.133 conducted a randomized control trial to test the efficacy of an electronic reminder system to improve antibiotic use. Details of this study are found in the 2007 report.

###### Gastmeier et al. (2002)134

Gastmeier et al.134 conducted a controlled before-after study to reduce nosocomial infections in surgical patients. Details of this study are found in the 2007 report.

###### Kao et al. (2010)137

###### Summary

Kao et al.137 used a nonrandomized stepped wedge design in two hospitals to compare the effectiveness of an extended timeout period followed by two different QI strategies to improve adherence with antibiotic prophylaxis use. An organizational change was instituted in both hospitals, providing a dedicated time for antibiotic administration and feedback to faculty on antibiotic use. Hospital 1 then added a provider education component in a subsequent study period, and hospital 2 added a provider reminder component in a subsequent study period. Results were as follows:

- Antibiotic selection improved in both hospitals following both the extended timeout period and the period with the additional QI strategy.
- Antibiotic timing improved significantly in both hospitals after the extended timeout, but improved further only in hospital 2 following implementation of the additional QI strategies.
- Antibiotic duration did not improve significantly in either hospital following the extended timeout period or after the period in which additional QI strategies were implemented.
- Infection rates were reported, but baseline versus postintervention analyses on these rates were not conducted.

###### Description

There was a baseline period from July 2006 to December 2006 (hospital 1: n=119, hospital 2: n=92), followed by three study periods from July 2007 to May 2009. In the first study period (hospital 1: n=100, hospital 2: n=206), a standardized antibiotic prophylaxis form was developed and became available to both hospitals and both hospitals incorporated an extended timeout period. The extended timeout involved administration of the antibiotic during the preoperative period and feedback to faculty on antibiotic use. During period 2 (hospital 1: n=97, hospital 2: n=154), both hospitals continued the extended timeout, and hospital 1 added educational lectures for the anesthesia and general surgery staff. In period 3 (hospital 1: n=115, hospital 2: 169), hospital 1 continued extended timeout and staff education, while hospital 2 continued extended timeout and added a preoperative checklist, nursing documentation of antibiotic choice, and a campaign to increase use of the standardized antibiotic form. Hospital 1 had 14 months of followup for their education component and hospital 2 had 6 months of followup for their checklist, antibiotic documentation, and campaign components. Data on adherence and SSI incidence were collected retrospectively from chart reviews. Chi-square analysis and analysis of variance were used to compare categorical and continuous variables between hospitals and time periods. Logistic regressions were run to determine factors related to nonadherence and SSI rates. General linear modeling examined interaction effects between hospitals and level of intervention.

###### Results and Limitations

Antibiotic selection improved significantly for both hospitals following both the extended timeout and the periods in which additional QI strategies were implemented (p<0.001). Timing of antibiotic improved significantly for both hospitals after the extended timeout. Data collected after the additional QI strategies were implemented showed significant improvements in antibiotic timing only in hospital 2 (p=0.05). Antibiotic discontinuation did not significantly improve in either hospital after any of the study periods. Hospital 1 had greater overall adherence compared with hospital 2 (p=0.003), but hospital 2 experienced fewer SSI compared with hospital 1 (OR: 0.23; 95% CI: 0.10 to 0.56; p=0.001) (Table 28). Limitations of this study include only a 6 month followup for hospital 2 in the final phase and no pre/post analysis of SSI rates. Another limitation is the potential underestimation of infections because SSI were identified through chart review and therefore dependent on the provider documenting the incidence in the chart.

##### Interrupted Time Series

###### Mannien et al. (2006)138

###### Summary

Mannien et al.138 report on a multisite prospective study, the Surgical Prophylaxis and Surveillance project, conducted in the Netherlands^b^ Organizational change, provider reminder systems, and audit and feedback were QI strategies implemented in this study. Statistically significant improvements in antibiotic timing and administration following the intervention were reported. Overall SSI rates decreased, but not significantly.

b This study provides 1 month of additional followup to a report published in 2005 (van Kasteran 2005) that was reviewed in the 2007 Evidence Report on preventing health care-associated infections.

###### Description

Twelve hospitals, representing different population densities and hospital types, which participated in the Dutch nosocomial surveillance network, volunteered to collect data on antibiotic prophylaxis and SSI rates. At the beginning of the intervention phase, participating hospitals received an auditing report on their use of antibiotic prophylaxis during January 2000 to November 2001 (n=1,668) from the study's supervising committee. The auditing reports and guidelines were discussed with each hospital's multidisciplinary study team. Recommendations for improvement in each hospital were made and educational meetings were conducted. Followup data were collected from July 2001 to November 2002, n=1,953. Logistic regressions were used to compare baseline and intervention SSI rates, adjusting for procedure specific confounders. Segmented time series analysis measured the effect size of the intervention, adjusting for hospital, procedure, and hierarchical structure of the data collected.

###### Results and Limitations

Time series analysis showed statistically significant improvements in antibiotic timing and administration following the intervention (p<0.01). Overall SSI rates decreased, but not significantly from a baseline rate of 5.4 percent (95% CI: 4.3% to 6.5%) to a postintervention rate of 4.5 percent (95% CI: 3.6% to 5.4%) (Table 28). A limitation of this study is the lack of a control group.

##### Simple Before-After

###### Schwann et al. (2011)143

Schwann et al. reported on the effect of SSI rates through intervention by provider reminder systems in the United States.143 Data were collected on 19,744 people over a 3-year period divided by a primary evaluation phase and a sustainability phase. Chi-Square tests were used to determine overall adherence. Bivariate, hierarchical chi-square and logistic regression were also used to assess adherence and SSI rates adjusting for inpatient versus outpatient, location, location of surgical service and individual surgeon. Adherence to antibiotic timing increased from 62 percent to 92 percent and was statistically significant (p=0.003). The overall SSI rate in the study decreased from 1.1 percent to 0.7 percent (RR: 0.35; 95% CI: 0.13 to 0.52) and was statistically significant (p=0.003).

###### Dellinger et al. (2005)136

Fifty-six hospitals joined a collaborative to decrease SSI in this simple before-after study described by Dellinger et al.136 Details of this study are found in the 2007 report.

###### Greco et al. (1991)135

Greco et al.135 describe a simple before-after study to reduce SSI, conducted across several hospitals in Italy. Details of this study are found in the 2007 report.

###### Burkitt et al. (2009)139

The Toyota production system, an approach developed by industrial engineers to improve manufacturing quality, was adapted by Burkitt et al.139 to improve antibiotic prophylaxis in a 146 bed tertiary care Veterans Affairs medical center. Organizational change, provider education, and provider reminder systems were strategies used in this study. Logistic regression analysis, which included a time variable to account for the rolling out of interventions, found significant improvements in the neurosurgical and gastrointestinal departments in antibiotic selection, with adjusted p-values of p<0.01 and p=0.03, respectively, but not in the vascular, genitourinary, or orthopedic departments. The analysis also found significant improvements in antibiotic duration in three of the five participating departments, gastrointestinal, genitourinary, and orthopedic, with adjusted p-values of p=0.04, p<0.01, and p=0.03, respectively. Analysis for all five departments combined showed no significant improvement in antibiotic selection (adjusted p=0.49), but a significant improvement in antibiotic duration (adjusted p<0.01; Table 28).

###### Kestle et al. (2011)144

Kestle et al. investigated the effect of an organizational change and provider reminder systems intervention on SSI rates in pediatric surgical centers within the United States.144 There were 2,467 patients in this 12-month, multicenter study. Adherence was not reported. Logistic regression was used to assess SSI rates. Overall SSI rate decreased significantly from 8.8 percent to 5.7 percent (p=0.003). Kestle et al. (2011) found that proper hand washing by all team members and double gloving by all team members were associated with lower infection rates (p=0.03 and p=0.04, respectively). Antibiotic-impregnated sutures and preoperative use of shampoo were associated with decreased infection rates (3.8% vs. 6.6%; p=0.03 and 3.4% vs. 7.4%; p=0.04 respectively). BioGlide catheters were significantly associated with higher rates of infection (8.3% vs. 4.5%; p=0.002).

###### Salim et al. (2011)145

Salim et al. reported on the effects of provider education and audit and feedback on SSI rates in women who underwent caesarean delivery in Israel.145 There were 1,616 patients enrolled in this 2-year study. Adherence was not reported. Infection rates were assessed using logistic and Poisson regression. Overall infection rates decreased significantly from 4.9 percent to 2.1 percent (OR: 0.4, 95% CI: 0.23 to 0.72; p=0.002). All ORs and IRRs were adjusted for membrane rupture and duration of operation. Salim et al. reported results by elective and nonelective cesarean. There were more significant results found in the elective cesarean group.

###### Hedrick et al. (2007)140

Hedrick et al.140 report on the implementation of bundled interventions in a single tertiary care 547 bed hospital aimed to improve: (1) antibiotic timing, (2) antibiotic selection, (3) antibiotic discontinuation, (4) normothermia maintenance, and (5) glucose control among patients undergoing intra-abdominal surgery. QI strategies implemented include organizational change, provider education, provider reminder systems, and audit and feedback. Data were compared from the first four months of the study, June 2004 to September 2004, to the last four months of the study, January 2005 to April 2005. Adherence with antibiotic selection and antibiotic timing significantly improved during the study period (p<0.05), while discontinuation of antibiotics and maintaining normothermia did not change significantly. Maintaining glucose control worsened significantly (p<0.05). Overall SSI rates decreased during the study period, but not significantly (Table 28). In a stepwise logistic regression analysis controlling for select clinical characteristics and illness severity, nonadherence with any of the preventive interventions was not predictive of SSI occurrence.

###### Kaimal et al. (2008)141

In a study focusing on patients undergoing cesarean deliveries in a single university affiliated hospital, Kaimal et al.141 describe the effect on SSI rates of an organizational change, the institution of a policy requiring prophylactic antibiotics to be administered before skin incision. The baseline period with a low level intervention including provider education was from March 2005 to June 2006, and the postintervention period with the policy change was from June 2006 to June 2007. There were no significant demographic or clinical differences between the two study groups. A multiple logistic regression analysis controlling for potential confounders showed a significant decline in overall SSI following the intervention (OR: 0.33; 95% CI: 0.14 to 0.77)

###### Trussell et al. (2008)142

Trussell et al.142 describe a bundle of interventions implemented in a single nonuniversity teaching hospital, aimed at reducing SSI for patients undergoing coronary artery bypass grafting procedures. The QI strategies implemented were organizational change, provider education, and provider reminder systems. The baseline and postintervention groups differed significantly in age, American Society of Anesthesiologists score, smoking history, and wound class. Antibiotic timing significantly improved (p=0.001), shaving decreased significantly (p=0.001), and adherence with the tight glucose control protocol was 100 percent. In a logistic regression model including potential confounders identified through stepwise regression, the postprotocol time period was a predictor of fewer SSI (OR: 0.21; 95% CI: 0.09 to 0.51; p=0.001)

###### Lavu et al. (2011)146

Lavu et al. assessed the effects of organizational change on SSI rates in patients within the United States.146 Data were collected on 466 patients in this 5-year study. Adherence was not reported. Infection rates were assessed by logistic regression and controlled for estimated blood loss, albumin and hemoglobin A1c. Overall infection rates significantly decreased from 15 percent to 7.7 percent (p<0.001). Lavu et al. reported that estimated blood loss and albumin were independent risk factors for SSI (p=0.01 and p=0.012 respectively).

#### Studies That Do Not Control for Confounding or Secular Trend

There were 34 studies that used QI strategies aimed at reducing SSI, but did not perform analyses to control for confounding or secular trends.99,103,147-178 Five of the 34 studies used a single QI strategy,103,147,154,155,161 while the remaining studies implemented combinations of QI strategies. The most common QI strategy implemented among these studies was provider education (28 of the 34).99,103,148-154,156,157,159-162,164-173,175-177 Seventy-four percent of the studies used organizational change as one of their QI strategies.148,150-153,155,157-160,162,163,165,167-178 Sixteen of 34 studies implemented provider reminder systems,147-149,151,152,157-159,166,167,171,173-176,178 12 of 34 implemented audit and feedback,99,149,150,156,157,164,167,168,172,173,176,177 and none included a patient education component (Appendix Table F3).

#### Strength of Evidence

##### Audit and Feedback and the Base Strategies With or Without Provider Reminder Systems Compared With Usual Care

The strength of the evidence for the use of audit and feedback and base strategies with or without provider reminder systems compared with usual care is summarized in Table 29. Six of the 15 studies used this combination of QI strategies.135-138,140,145

Table 29 Strength of evidence for audit and feedback and the base strategies with or without provider reminder systems compared with usual care

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: antibiotic selection | 1 stepped wedge137 2 simple before-after136,140 | Medium | Consistent | Direct | Precise | Low
Adherence: antibiotic timing | 1 interrupted time series138 1 stepped wedge137 2 simple before-after136,140 | Medium | Consistent | Direct | Precise | Moderate
Adherence: antibiotic duration | 1 stepped wedge137 3 simple before-after135,136,140 | Medium | Inconsistent | Direct | Imprecise | Insufficient
Adherence: normothermia | 2 simple before-after136,140 | High | Inconsistent | Direct | Imprecise | Insufficient
Adherence: glucose control | 2 simple before-after136,140 | High | Unknown | Direct | Imprecise | Insufficient
Adherence: shaving | 2 simple before-after135,136 | High | Consistent | Direct | Precise | Low
Infection rate | 1 interrupted time series138 4 simple before-after135,136,140,145 | Medium | Unknown | Direct | Imprecise | Insufficient
Adherence and infection rates | 1 interrupted time series138 1 stepped wedge137 3 simple before-after135,136,140 | Medium | Unknown | Direct | Imprecise | Insufficient

###### Antibiotic Selection

Three of the six studies reported antibiotic selection as an outcome.136,137,140 One study is of medium quality137 and 2 studies are of lower quality136,140 (Table 27). Due to the overall quality of the studies, risk of bias was determined as medium. The findings were consistent between studies, with all studies reporting statistically significant improvements in antibiotic selection (Table 28). The measures are direct because antibiotic selection is a component of appropriate antibiotic use. The reported results were precise, with adherence rates improving from 61 percent to 78 percent and 69 percent to 80 percent in the two hospitals in the stepped wedge study,137 and 89 percent to 97 percent in 1 of the simple before-after studies (p≤0.05)140 and from 90 percent to 95 percent in the other simple before-after study (p=0.02)136 (Table 28). Use of audit and feedback and base strategies with or without provider reminder systems compared with usual care for improving antibiotic selection has low strength of evidence (Table 29).

###### Antibiotic Timing

Four of the 6 studies reported antibiotic timing as an outcome.136-138,140 Two studies are of medium quality137,138 and 2 studies are of lower quality136,140 (Table 27), providing a medium risk of bias. The four studies report consistent findings, a significant improvement in antibiotic timing following the interventions (Table 28). The measures are direct because antibiotic timing is a component of appropriate antibiotic use. The reported results are precise, with adherence rates improving from 74 percent to 90 percent and 65 percent to 98 percent in the two hospitals in one study,137 72 percent to 92 percent in another study,136 89 percent to 97 percent in the third study (p≤0.05),140 and an observed rate of 60.6 percent compared with an expected rate of 48.2 percent in the fourth study138 (Table 28). Use of audit and feedback and base strategies with or without provider reminder systems compared with usual care for improving antibiotic timing has moderate strength of evidence (Table 29).

###### Antibiotic Duration

Four of the 6 studies reported antibiotic duration as an outcome.135-137,140 One study is of medium quality137 and 3 studies are of lower quality135,136,140 (Table 27), providing a medium risk of bias. Two studies report nonsignificant results137,140 and 2 studies report significant improvements135,136 (Table 28) for inconsistent findings. The measure is direct. Nonsignificant and significant results are imprecise. Use of audit and feedback and base strategies with or without provider reminder systems compared with usual care for improving antibiotic duration has insufficient evidence (Table 29).

###### Normothermia Maintenance

Two simple before-after studies with a high risk of bias reported normothermia maintenance as an outcome.136,140 One study reports nonsignificant findings140 and 1 study reports significant findings,136 resulting in inconsistency and imprecision. The strength of evidence for use of audit and feedback and base strategies with or without provider reminder systems compared with usual care for normothermia maintenance is insufficient.

###### Glucose Control

Two simple before-after studies with a high risk of bias reported glucose control as an outcome.136,140 One study reports nonsignificant findings140 and 1 study reports significant findings,136 resulting in inconsistency and imprecision. The strength of evidence for use of audit and feedback and base strategies with or without provider reminder systems compared with usual care for glucose control is insufficient.

###### Shaving

Two simple before-after studies with a high risk of bias reported appropriate hair removal as an outcome.135,136 A high risk of bias was assigned due to the simple before-after study design, but both studies have large sample sizes, with 1 study involving a collaborative effort among 56 hospitals136 and the other study involving nine wards in several hospitals across Italy.135 The findings were consistent between the studies, with both studies reporting statistically significant improvements (Table 28). The measure is direct. The results are precise, with appropriate hair removal improving in one study from 59 percent to 95 percent136 and a decrease in shaving in the other study from 76.8 percent to 73.5 percent.135 The strength of evidence for use of audit and feedback and base strategies with or without provider reminder systems for appropriate hair removal compared with usual care is low.

###### Infection Rate

Five of the 6 studies reported infection rates and conducted statistical analyses to compare the rates.135,136,138,140,145 The remaining study reported infection rates but did not perform statistical comparisons.137 Of the 5 studies that conducted statistical analyses, 1 is of medium quality138 and four are of lower quality,135,136,140,145 providing a medium risk of bias. The results were nonsignificant in 4 of the 5 studies (Table 28), so consistency is unknown. Infection rate is a direct measure. Because the majority of the results are nonsignificant, they are imprecise. The strength of evidence for use of audit and feedback and base strategies with or without provider reminder systems compared with usual care for improving infection rates is insufficient (Table 29).

###### Adherence Rate and Infection Rate

Four of the 6 studies reported adherence rates and infection rates and conducted statistical analyses to compare the rates.135,136,138,140 An additional study did not perform statistical analysis on pre and post infection rates, but conducted a multiple regression analysis including both adherence and infection rates in the model.137 Of the 4 that conducted analyses comparing rates, 1 study is of medium quality138 and 3 studies are of lower quality,135,136,140 providing a medium risk of bias. While adherence rates improved significantly in antibiotic selection, antibiotic timing, and appropriate hair removal, changes in infection rates were nonsignificant (Table 28), so consistency is unknown. The adherence rates and infection rates are direct measures. Because comparisons of adherence to antibiotic duration rates and infection rates are nonsignificant, they are imprecise. Three studies137,138,140 conducted multivariable analyses to assess whether adherence to preventive interventions was predictive of SSI rates. The nonrandomized stepped wedge study, which did not perform statistical analysis on the infection rates, did run a multiple regression analysis which demonstrated that nonadherence with antibiotic guidelines was a predictor of SSI (OR: 2.61; 95% CI: 1.20 to 5.70) (Table 29).137 The interrupted time series study used a time series analysis and found that adherence did not impact SSI (p=0.99) (Table 28).138 The simple before-after study describes a multivariable analysis that found nonadherence with any of the preventive interventions was not predictive of SSI (Table 28).140 The strength of evidence for use of audit and feedback and base strategies with or without provider reminder systems compared with usual care for improving adherence and infection rates is insufficient (Table 29).

##### Provider Reminder Systems With the Base Strategies Compared With Usual Care

Five studies used the combination of QI strategies consisting of provider reminder systems with the base strategies compared with usual care.133,139,142-144 One study is a randomized control trial of higher quality133 and four studies are simple before-after studies and therefore are of lower quality.

###### Antibiotic Selection

One of the 5 studies reported adherence to antibiotic selection as an outcome.139 Risk of bias is high because the study is a simple before-after study, consistency is unknown with only 1 study, the adherence measure (p=0.49) is direct, and because the finding was nonsignificant, the measure is imprecise. The strength of evidence for use of provider reminder systems with the base strategies compared with usual care for antibiotic selection is insufficient (Table 30).

Table 30 Strength of evidence for provider reminder systems with the base strategies compared with usual care

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: antibiotic selection | 1 simple before-after 139 | High | Unknown | Direct | Imprecise | Insufficient
Adherence: antibiotic timing | 1 controlled study133 2 simple before-after 142,143 | Medium | Consistent | Direct | Precise | Low
Adherence: antibiotic duration | 1 simple before-after study139 | High | Unknown | Direct | Imprecise | Insufficient
Adherence: hair removal | 1 simple before-after study142 | High | Unknown | Direct | Imprecise | Insufficient
Infection rate | 1 Controlled study133 3 Simple before-after studies142-144 | Medium | Consistent | Direct | Imprecise | Low
Adherence and infection rates | 1 Controlled study133 2 Simple before-after studies142,143 | Medium | Unknown | Direct | Imprecise | Insufficient

###### Antibiotic Timing

Three of the 5 studies reported adherence to antibiotic timing as an outcome.133,142,143 Risk of bias is medium because 1 study is a controlled study133 and 2 studies are simple before-after studies.142,143 The evidence is consistent, with all three studies reporting significant improvements in antibiotic timing. The measure is direct. The findings are precise, with the controlled study reporting an improvement from 27 percent to 68 percent,133 1 simple before-after study reporting an improvement from 81 percent to 94 percent,142 and the other reporting an improvement from 62 percent to 92 percent. The strength of evidence for use of provider reminder systems with the base strategies compared with usual care for antibiotic timing is low (Table 30).

###### Antibiotic Duration

One of the 5 studies reported adherence to antibiotic duration as an outcome.139 Risk of bias is high because the study is a simple before-after study, consistency is unknown with only 1 measure, the adherence measure (p<0.01) is direct and imprecise. The strength of evidence for use of provider reminder systems with the base strategies compared with usual care for antibiotic duration is insufficient (Table 30).

###### Appropriate Hair Removal

One of the 5 studies reported adherence to appropriate hair removal as an outcome.142 Risk of bias is high because the study is a simple before-after study, consistency is unknown with only one measure, the adherence measure (p=0.001) is direct and imprecise. The strength of evidence for use of provider reminder systems with the base strategies compared with usual care for appropriate hair removal is insufficient (Table 30).

###### Infection Rate

Four of the 5 studies reported infection rates as an outcome.133,142-144 Risk of bias is medium because 1 study is a controlled study and 3 studies are a simple before-after design. The findings are consistent, with 1 study reporting nonsignificant findings133 and 3 studies reporting statistical improvements.142-144 Infection rate is a direct measure. The findings are imprecise. The strength of evidence for use of provider reminder systems with the base strategies compared with usual care for improving infection rates is low (Table 30).

###### Adherence Rate and Infection Rate

Three of the 5 studies reported both adherence rates and infection rates as outcomes.133,142,143 Risk of bias is medium because 1 study is a controlled study and 2 studies are a simple before-after design. The findings are inconsistent, with antibiotic timing improving in all 3 studies, but infection rates improving significantly in only 2 of the studies. There was no analysis to assess if adherence to the preventive interventions was predictive of SSI. The strength of evidence for use of provider reminder systems with the base strategies compared with usual care for improving adherence and infection rates is insufficient (Table 30).

##### Base Strategies Compared With Usual Care

One controlled before-after study and one simple before-after study used a combination of the base strategies compared with usual care.134,146 Neither study reported any adherence rates, but they provided a comparison of infection rates.

###### Infection Rate

Three studies addressed infection rates and used a combination of the base strategies, 1 controlled study134 and 2 simple before-after study.141,146 Risk of bias is medium. Evidence is of unknown consistency. Infection rate is a direct measure. The findings were imprecise. The strength of evidence for organizational change and provider education compared to usual care is insufficient (Table 31).

Table 31 Strength of evidence for base strategies within SSI compared with usual care

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Infection rate | 1 controlled study134 2 simple before-after 141,146 | Medium | Unknown | Direct | Imprecise | Insufficient

##### Audit and Feedback With the Base Strategies Compared With Audit and Feedback Alone

One cluster randomized, controlled trial of 44 hospitals compared adherence rates between an audit and feedback group and an audit and feedback with membership in a QI collaborative group.52 Adherence rates for antibiotic selection, antibiotic timing, and antibiotic duration were reported. Infection rates were not reported.

###### Antibiotic Selection

Risk of bias for this cluster randomized, controlled trial52 is medium, consistency is unknown with only one study, the adherence measure is direct and because the measure is nonsignificant, the evidence is imprecise. The strength of evidence for use of audit and feedback with the base strategies compared with audit and feedback alone for antibiotic selection is insufficient (Table 32).

Table 32 Strength of evidence for audit and feedback with the base strategies within SSI compared with lower level of intervention

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: antibiotic selection | 1 controlled52 | Medium | Unknown | Direct | Imprecise | Insufficient
Adherence: antibiotic timing | 1 controlled52 | Medium | Unknown | Direct | Imprecise | Insufficient
Adherence: antibiotic duration | 1 controlled52 | Medium | Unknown | Direct | Imprecise | Insufficient

###### Antibiotic Timing

Risk of bias for this cluster randomized, controlled trial52 is medium, consistency is unknown with only one study, the adherence measure is direct and because the measure is nonsignificant, the evidence is imprecise. The strength of evidence for use of audit and feedback with the base strategies compared with audit and feedback alone for antibiotic timing is insufficient (Table 32).

###### Antibiotic Duration

Risk of bias for this cluster randomized, controlled trial52 is medium, consistency is unknown with only one study, the adherence measure is direct and because the measure is nonsignificant, the evidence is imprecise. The strength of evidence for use of audit and feedback with the base strategies compared with audit and feedback alone for antibiotic duration is insufficient (Table 32).

##### Organizational Change Alone Compared With a Low Intensity Intervention

One simple before-after study compared infection rates between a baseline period with a low level intervention consisting of provider education, to a postintervention period with a QI strategy of organizational change.141 No adherence rates were reported.

###### Infection Rate

Risk of bias for this simple before-after study141 is high, consistency is unknown with only one study, the infection rate (p=0.02) is direct and imprecise. The strength of evidence for use of organizational change compared with provider education for improving infection rates is insufficient (Table 33).

Table 33 Strength of evidence for organizational change alone within SSI compared with low intensity of intervention

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Infection rate | 1 simple before-after141 | High | Unknown | Direct | Imprecise | Insufficient

### Catheter-Associated Urinary Tract Infection (CAUTI)

#### Overview

The literature search identified 11 studies that addressed the prevention of catheter-associated urinary tract infections (CAUTI) and controlled for confounding factors or secular trend (Table 34).48,69,135,145,181-187 Two135,185 of the 11 studies are from the 2007 report.3 The objective of majority of the studies was to reduce indwelling urinary catheter duration and unnecessary catheterization among patients with an indwelling urinary catheter. In addition, the objective of 1 study was to limit use of urinary catheters in postoperative patients.135 Another study implemented a hand hygiene campaign.48

Table 34 Overview of CAUTI articles that control for confounding or secular trend

Author, location-year | Study type | Analysis for infection rates | Sample size (infections) | Organizational change | Provider education | Audit and feedback | Provider reminder systems | Patient education | Financial incentives
van den Broek, Netherlands - 2011^186^ | Stepped wedge design | Time-series analysis | pre: 1149 post: 1794 | • | • | | •
Loeb, Canada - 2008^182^ | Individual RCT | Logistic regression | control: 345 (51) study: 347 (51) | • | | | •
Saint, United States - 2005^185^ | Controlled before-after | Poisson regression (for adherence) | control pre: 1,449 control post: 1,202 study pre: 1,546 study post: 1,481 | | | | •
Apisarnthanarak, Thailand - 2007^64^ | Interrupted time series | Segmented regression | pre:1105 post: 1307 | • | | | •
Marra, Brazil - 2011^181^ | Interrupted time series | Generalized linear model | | • | • | • | •
Fakih, United States - 2012^187^ | Simple before-after | GEE model | | • | • | • | •
Barrera, Colombia - 2011^48^ | Simple before-after | Poisson regression | total: 14,516 (total # HAI: 2,398) | | | • | | •
Salim, Israel - 2011^145^ | Simple before-after | Logistic and Poisson regression | pre: 751 (9) post: 865 (3) | | • | •
Seguin, France - 2010^69^ | Simple before-after | Poisson regression | pre: 676 (29) post: 595 (18) | | | | •
Crouzet, France - 2007^184^ | Simple before-after | Logistic regression | pre: 141 post: 93 | | | | •
Greco, Italy - 1991^135^ | Simple before-after | Mantel-Haenszel relative risks | pre: 4,096 post: 1,638 | • | • | •

The study designs included 1 randomized stepped wedge design,186 1 randomized, controlled trial,182 1 controlled before-after study,185 2 interrupted time series,181,183 and 6 simple before-after studies.48,69,135,145,184,187 Two studies implemented four quality improvement (QI) strategies,181,187 2 studies implemented three QI strategies,135,186 4 studies implemented two QI strategies48,145,182,183 and 3 studies69,184,185 implemented one QI strategy. Provider reminder systems were used in 8 studies while 6 implemented organizational change as well. 48,69,135,145,181-187 Specific attributes of organizational change that were implemented for each study are shown in Table 35.

Table 35 Specific attributes of organizational change for CAUTI articles that control for confounding or secular trend

Author, Country-Publication Year | Multidisciplinary Team | Team Responsibilities | Hospital Executives on Team | New Protocol or Standards Implemented | Designate Staff Member Responsible for Implementation
van den Broek, Netherlands - 2011^186^ | • | Develop the method of implementation that will best suit the hospital and the introduce it to the wards.
Loeb, Canada - 2008^182^ | | | | • | •
Apisarnthanarak, Thailand - 2007^64^ | • | Give feedback to the ICU staff, create an action plan, and lead daily bedside discussions with treating physicians | • | • | •
Marra, Brazil - 2011^181^ | | | | •
Fakih, United States - 2012^187^ | • | Educate the patient care nurses, triggers the evaluation of catheter necessity, obtain physician support, and address infectious complications related to the urinary catheter.
Greco, Italy – 1991^135^ | | | | •

Infection and adherence rates were reported and analyzed in 6 studies;48,69,135,182-184 adherence alone was reported in 3 studies;185-187 and infection rates alone were reported in 2 studies.145,181 Duration of overall indwelling urinary catheterization was reported as an adherence measure in 5,^64,69,135,184,185^ while two64,182 reported inappropriate indwelling urinary catheterization among patients who had urinary catheters and 1 study135 reported on rate of urinary catheter use in post-operative patients. Three studies reported cost information.64,185,186

Seven studies48,64,69,145,181,184,185 were conducted in single center tertiary care and/or university affiliated hospitals and 4 were a multisite study.135,182,186,187 Two studies was from the United States,185,187 2 were from France,69,184 1 from Thailand,64 1 in Canada,182 1 in the Netherlands,186 1 in Brazil,181 1 in Colombia,48 1 in Israel,145 and 1 from Italy.135 Specific hospital settings included seven medical ICUs, one surgical ICU, nine surgical wards, one neurosurgery department, one cardiovascular surgery department, one orthopedic surgery department, one neurology department, one geriatrics department, and one medical-surgical department.

The sample size for the postintervention period ranged from 93 to 1,794 patients, and infection rates in the postintervention period ranged from 1.8 to 12.9 infections per 1,000 catheter-days. Baseline infection rates ranged from 1.7 to 21.5 infections per 1,000 catheter-days.

The search also identified 16 studies that addressed prevention of catheter-associated urinary tract infections that did not control for confounding or secular trend.80,89,97,103,154,188-198 These studies were not included in the analysis due to their weak designs and potential for biased results (Appendix F4).

#### Methodological Quality of Included Studies

As displayed in Table 36, 1 study182 was ranked of higher quality, 3^64,185,186^ of medium quality, and 7^48,69,135,145,181,184,187^ of lower quality. Six of the 11 had followup longer than 1 year after the intervention.48,64,145,181,182,187 Given the study designs, adequate measures were taken to control for confounding and secular trend in 8 of 11 studies.48,64,69,135,145,182,185,186 Six studies analyzed both adherence rates and infection rates.48,64,69,135,182,184 One study69 explicitly reported independence from other QI efforts; this dimension was not applicable for the randomized, controlled trials.182,186

Table 36 Study quality for CAUTI articles that control for confounding or secular trend

Author, Location-Year | Study Type | Sufficient followup^a^ | Adequate control for confounding or secular trend^b^ | Change in adherence was analyzed^c^ | Change in infection rate was analyzed^d^ | Independent of other QI effort^e^ | Overall quality rating | Comments
van den Broek, Netherlands - 2011^186^ | Stepped wedge design | - | + | + | - | N/A | Medium | Proportion of infected patients were reported but not analyzed and followup was only 5 months for each arm.
Loeb, Canada - 2008^182^ | Individual RCT | + | + | + | + | N/A | Higher | Randomized at patient level. Contamination of control group was highly possible.
Saint, United States - 2005^185^ | Controlled before-after | - | + | + | - | ? | Medium | Followup was only 8 months. There were large differences in catheterization rates and demographics between the control and study wards, but these were taken into account in the analysis.
Apisarnthanarak, Thailand - 2007^64^ | Interrupted time series | + | + | + | + | - | Medium
Marra, Brazil - 2011^181^ | Interrupted time series | + | - | - | + | ? | Lower | Patient characteristics were not compared
Fakih, United States - 2012^187^ | Simple before-after | + | - | + | - | ? | Lower | Authors use GEE model for analysis of inappropriate catheter and time use at the patient-level. Additional covariate data were not collected or used.
Barrera, Colombia - 2011^48^ | Simple before-after | + | + | + | + | ? | Lower
Salim, Israel - 2011^145^ | Simple before-after | + | + | - | + | ? | Lower | Adherence was not measured.
Seguin, France - 2010^69^ | Simple before-after | - | + | + | + | ? | Lower
Crouzet, France - 2007^184^ | Simple before-after | - | - | + | + | - | Lower | Sample size is small and followup is short, and different definition is used.
Greco, Italy - 1991^135^ | Simple before-after | - | + | + | + | ? | Lower | Followup was only 6 months.

Note: All studies used standard and consistent infection definitions. CDC methodology was used in all studies except Seguin et al. (2010).69

Infection rates were adjusted for device utilization in all studies except Loeb et al. (2008).182

Independence from other QI efforts was not applicable for randomized controlled trials

a Is the length of followup sufficient (at least 12 months) to support the evaluation of primary outcomes and harms?

b Were adequate measures taken to control for confounding or secular trend?

c Was change in adherence analyzed?

d Was change in infection rate analyzed?

e Was the intervention performed independent of other QI efforts or other changes?

‘+’ means ‘yes’

‘-’ means ‘no’

‘?’ means ‘uncertain’

#### Studies That Control for Confounding or Secular Trend

##### Controlled Studies

###### van den Broek et al. (2011)186

###### Summary

van den Broek et al. conducted a stepped wedge design study in ten Dutch hospitals.186 Organizational change, provider education, and provider reminder systems were implemented. Hospitals in the intervention group developed tailored approaches to implementing measures to reduce the use of indwelling urinary catheters. After 8 months, both groups were actively participating in the intervention. The proportion of correctly inserted indwelling urinary catheters, duration of catheterization, and prevalence of catheterized patients significantly improved after the intervention.

###### Description

Ten Dutch hospitals participating in the Dutch surveillance program of nosocomial infections (PREZIES) were randomized to two groups. Each hospital selected as many wards as necessary so that there would be roughly 20 catheterized patients occurring over the 17-month study period in each ward at each hospital. Hospitals chose the changes to implement to reduce indwelling urinary catheter use. In a post hoc summary, the changes were divided into three categories: (1) revision of existing protocols and materials used for catheterization, (2) provider education through various approaches, and (3) changing daily practice by paying closer attention to catheterized patients during daily meetings. Logistic and exponential regressions were used to analyze the outcomes.

###### Results and Limitations

During the baseline period, there were 1,149 catheterized patients in the ten hospitals. The postintervention population was 1,794 catheterized patients. The prevalence of catheters and the duration of indwelling urinary catheters was significantly lower in the surgery department after the intervention (OR: 0.84; 95% CI: 0.75 to 0.96; OR: 0.80; 95% CI: 0.71 to 0.90, respectively). The neurology departments also saw a significant improvement in duration of indwelling urinary catheterization (OR: 0.81; 95% CI: 0.69 to 0.96; Table 37). The authors found that 460 catheter-days (95% CI: 162 to 761) were eliminated per 100 catheterized patients due to the intervention. Overall measures were not reported for the catheter prevalence or duration of indwelling catheterization. Infection rates were reported but not analyzed; symptomatic CAUTI was 12.6% during baseline and 12.7% during the postintervention period; asymptomatic CAUTI was 37.4% during baseline and 38.3% during the postintervention period.

Table 37 Outcomes for CAUTI articles that control for confounding or secular trend

Author, Country-Year | Intervention/ Comparator | Type of Outcome | Specific Measure | Improve | Worsen | NS | Change in Specific Measure | Comments
van den Broek, Netherlands - 2011^186^ | Revision of existing protocols, introduction of staff education and change to daily practice/ No Intervention (usual care) | Adherence | Correctly inserted UC | ⋄ | | | 64% → 74% (p<0.0001) | Adherence analysis included hospital, ward type and the interaction between hospital and ward.
van den Broek, Netherlands - 2011^186^ | Revision of existing protocols, introduction of staff education and change to daily practice/ No Intervention (usual care) | Infection | Symptomatic CAUTI | | | | 12.6% → 12.7% | Adherence analysis included hospital, ward type and the interaction between hospital and ward.
van den Broek, Netherlands - 2011^186^ | Revision of existing protocols, introduction of staff education and change to daily practice/ No Intervention (usual care) | Infection | Asymptomatic CAUTI | | | | 37.4% → 38.3% | Adherence analysis included hospital, ward type and the interaction between hospital and ward.
van den Broek, Netherlands - 2011^186^ | Revision of existing protocols, introduction of staff education and change to daily practice/ No Intervention (usual care) | Cost/Savings | Cost of implementing program | | | | €2,638 (95% CI: €1,023 to €3,763) | Adherence analysis included hospital, ward type and the interaction between hospital and ward.
van den Broek, Netherlands - 2011^186^ | Revision of existing protocols, introduction of staff education and change to daily practice/ No Intervention (usual care) | Cost/Savings | Cost of insertion of UC | | | | € 28 | Adherence analysis included hospital, ward type and the interaction between hospital and ward.
van den Broek, Netherlands - 2011^186^ | Revision of existing protocols, introduction of staff education and change to daily practice/ No Intervention (usual care) | Cost/Savings | Cost of removal of UC | | | | € 3 | Adherence analysis included hospital, ward type and the interaction between hospital and ward.
van den Broek, Netherlands - 2011^186^ | Revision of existing protocols, introduction of staff education and change to daily practice/ No Intervention (usual care) | Cost/Savings | Cost of daily care of UC | | | | € 3 | Adherence analysis included hospital, ward type and the interaction between hospital and ward.
van den Broek, Netherlands - 2011^186^ | Revision of existing protocols, introduction of staff education and change to daily practice/ No Intervention (usual care) | Cost/Savings | Mean amount saved per 100 patients | | | | € 537 | Adherence analysis included hospital, ward type and the interaction between hospital and ward.
Loeb, Canada - 2008^182^ | Prewritten stop orders for indwelling urinary catheters/ No Intervention (usual care) | Adherence | Duration of inappropriate UC | ⋄ | | | Control: 3.89 Intervention: 2.20 (p<0.001) | RR was adjusted for sex and antimicrobial use during catheterization. Reinsertion rate was similar in both groups (7.0 vs. 8.6%, p=0.45).
Loeb, Canada - 2008^182^ | Prewritten stop orders for indwelling urinary catheters/ No Intervention (usual care) | Adherence | Duration of overall UC | ⋄ | | | Control: 5.04 Intervention: 3.70 (p<0.001) | RR was adjusted for sex and antimicrobial use during catheterization. Reinsertion rate was similar in both groups (7.0 vs. 8.6%, p=0.45).
Loeb, Canada - 2008^182^ | Prewritten stop orders for indwelling urinary catheters/ No Intervention (usual care) | Infection Rate | Overall | | | • | Control: 20% Intervention: 19% RR: 1.04 (95% CI: 0.75 to 1.44, p=0.80) | RR was adjusted for sex and antimicrobial use during catheterization. Reinsertion rate was similar in both groups (7.0 vs. 8.6%, p=0.45).
Loeb, Canada - 2008^182^ | Prewritten stop orders for indwelling urinary catheters/ No Intervention (usual care) | Costs/Savings | | | | | | RR was adjusted for sex and antimicrobial use during catheterization. Reinsertion rate was similar in both groups (7.0 vs. 8.6%, p=0.45).
Saint, United States - 2005^185^ | Urinary catheter reminder in patient chart and pager reminder/ No Intervention (usual care) | Adherence | Proportion of days catheterized | ⋄ | | | Control: 27.8% → 32.0% Study (Intent-to-treat): 14.4% → 13.3% (p=0.007) Study (per-protocol): 14.4% → 10.7% (p=NR) | Change in proportion of catheterized days was adjusted for baseline differences in catheterization, age, sex, and length of stay. Recatheterization occurred in 39 patients and was not significantly different between intervention and control ICUs after adjustment for age, sex, and length of stay (p=0.41). Per-protocol analysis was also done, removing cases that were not adherent with reminders.
Saint, United States - 2005^185^ | Urinary catheter reminder in patient chart and pager reminder/ No Intervention (usual care) | Infection Rate
Saint, United States - 2005^185^ | Urinary catheter reminder in patient chart and pager reminder/ No Intervention (usual care) | Costs/Savings | Annual net savings | | | | $249-$5,318 (per-protocol annual net savings: $50,832)
Apisarnthanarak, Thailand - 2007^183^ | Daily physician reminders to remove unnecessary catheter/ No Intervention (usual care) | Adherence | Percent of Inappropriate UC | ⋄ | | | 20.4% → 11% (p=0.04) | Initial change after intervention was significant, but trend after intervention was not significantly different than baseline trend.
Apisarnthanarak, Thailand - 2007^183^ | Daily physician reminders to remove unnecessary catheter/ No Intervention (usual care) | Adherence | Duration of overall UC | ⋄ | | | 11 → 3 (p<0.001) | Initial change after intervention was significant, but trend after intervention was not significantly different than baseline trend.
Apisarnthanarak, Thailand - 2007^183^ | Daily physician reminders to remove unnecessary catheter/ No Intervention (usual care) | Infection Rate | Overall | • | | | 21.5 → 5.2 (p<0.001) | Initial change after intervention was significant, but trend after intervention was not significantly different than baseline trend.
Apisarnthanarak, Thailand - 2007^183^ | Daily physician reminders to remove unnecessary catheter/ No Intervention (usual care) | Infection Rate | Medical Ward | • | | | 21.5 → 6.5 (p=0.04) | Initial change after intervention was significant, but trend after intervention was not significantly different than baseline trend.
Apisarnthanarak, Thailand - 2007^183^ | Daily physician reminders to remove unnecessary catheter/ No Intervention (usual care) | Infection Rate | Surgical Ward | • | | | 19.4 → 7.8 (p=0.03) | Initial change after intervention was significant, but trend after intervention was not significantly different than baseline trend.
Apisarnthanarak, Thailand - 2007^183^ | Daily physician reminders to remove unnecessary catheter/ No Intervention (usual care) | Infection Rate | ICU | • | | | 23.4 → 3.5 (p=0.003) | Initial change after intervention was significant, but trend after intervention was not significantly different than baseline trend.
Apisarnthanarak, Thailand - 2007^183^ | Daily physician reminders to remove unnecessary catheter/ No Intervention (usual care) | Costs/Savings | Mean monthly hospital costs for antibiotics | ⋄ | | | $3,739 → $1,378 (p<0.001) | Initial change after intervention was significant, but trend after intervention was not significantly different than baseline trend.
Apisarnthanarak, Thailand - 2007^183^ | Daily physician reminders to remove unnecessary catheter/ No Intervention (usual care) | Costs/Savings | Mean hospitalization costs per patient | ⋄ | | | $366 → $154 (p<0.001) | Initial change after intervention was significant, but trend after intervention was not significantly different than baseline trend.
Marra, Brazil - 2011^181^ | CAUTI Bundle with nurse empowerment and daily check of UC necessity/ Low intensity Intervention | Adherence | ICU Overall insertion measures | | | | ? → 84.3%
Marra, Brazil - 2011^181^ | CAUTI Bundle with nurse empowerment and daily check of UC necessity/ Low intensity Intervention | Adherence | SDU Overall insertion measures | | | | ? → 87.9%
Marra, Brazil - 2011^181^ | CAUTI Bundle with nurse empowerment and daily check of UC necessity/ Low intensity Intervention | Adherence | ICU appropriate UC indication | | | | ? → 87.9%
Marra, Brazil - 2011^181^ | CAUTI Bundle with nurse empowerment and daily check of UC necessity/ Low intensity Intervention | Adherence | SDU appropriate UC indication | | | | ? → 88.3%
Marra, Brazil - 2011^181^ | CAUTI Bundle with nurse empowerment and daily check of UC necessity/ Low intensity Intervention | Infection | Overall ICU | • | | | 7.6 (95% CI: 6.6 to 8.6) → 5.0 (95% CI: 4.2 to 5.8) (p<0.001)
Marra, Brazil - 2011^181^ | CAUTI Bundle with nurse empowerment and daily check of UC necessity/ Low intensity Intervention | Infection | Overall SDU | • | | | 15.3 (95% CI: 13.9 to 16.6) → 12.9 (95% CI: 11.6 to 14.2) (p=0.014)
Marra, Brazil - 2011^181^ | CAUTI Bundle with nurse empowerment and daily check of UC necessity/ Low intensity Intervention | Cost/Savings
Fakih, United States - 2012^187^ | CAUTI Bundle with education and feedback/ No Intervention (usual care) | Adherence | Appropriate catheterization | ⋄ | | | 44.3% (95% CI: 40.3% to 48.4%) → 57.6% (95% CI: 51.7% to 63.4%) (p=0.005) | Authors state data reported after week 140 was too unreliable to use due to sparse data collection (8% to 2%) at weeks 152 and 190 respectively. Final appropriate catheterization rate at 190 weeks was 65.3% (95% CI: 44.5% to 81.5%)
Fakih, United States - 2012^187^ | CAUTI Bundle with education and feedback/ No Intervention (usual care) | Infection
Fakih, United States - 2012^187^ | CAUTI Bundle with education and feedback/ No Intervention (usual care) | Cost/Savings
Barrera, Colombia - 2011^48^ | hand hygiene promotion/ No Intervention (usual care) | Adherence | ABHR use | ⋄ | | | 9.2% annual increase (p<0.001) | CAUTI significantly increased by 8.0% annually. ABHR use is an indirect measure of hand hygiene.
Barrera, Colombia - 2011^48^ | hand hygiene promotion/ No Intervention (usual care) | Infection | Overall | | • | | 1.7 → 4.5 (p=0.002)^a^ | CAUTI significantly increased by 8.0% annually. ABHR use is an indirect measure of hand hygiene.
Barrera, Colombia - 2011^48^ | hand hygiene promotion/ No Intervention (usual care) | Cost/Savings | | | | | | CAUTI significantly increased by 8.0% annually. ABHR use is an indirect measure of hand hygiene.
Salim, Israel - 2011^145^ | Refresher courses on infection control and catheter insertion/ No Intervention (usual care) | Adherence | | | | | | All ORs and IRRs were adjusted for membrane rupture and duration of operation. These results are also further broken down by elective and nonelective cesarean. More significant results were found in the elective cesarean group.
Salim, Israel - 2011^145^ | Refresher courses on infection control and catheter insertion/ No Intervention (usual care) | Infection | Overall | | | • | 1.2% → 0.3% (OR=0.31, 95% CI: 0.08 to 1.17, p=0.08)
Salim, Israel - 2011^145^ | Refresher courses on infection control and catheter insertion/ No Intervention (usual care) | Cost/Savings
Seguin, France - 2010^69^ | Physician reminder of catheter duration/ No Intervention (usual care) | Adherence | Duration of overall UC | ⋄ | | | 5 → 4 (p<0.001) | Duration of overall UC and infection rates were adjusted for age, SAPS II, and admission diagnosis.
Seguin, France - 2010^69^ | Physician reminder of catheter duration/ No Intervention (usual care) | Adherence | Median time to UC removal | ⋄ | | | 14 → 8 (p<0.001) | Duration of overall UC and infection rates were adjusted for age, SAPS II, and admission diagnosis.
Seguin, France - 2010^69^ | Physician reminder of catheter duration/ No Intervention (usual care) | Infection Rate | Overall | | | • | 5.0 → 4.9 (p=0.938) | Duration of overall UC and infection rates were adjusted for age, SAPS II, and admission diagnosis.
Seguin, France - 2010^69^ | Physician reminder of catheter duration/ No Intervention (usual care) | Costs/Savings | | | | | | Duration of overall UC and infection rates were adjusted for age, SAPS II, and admission diagnosis.
Crouzet, France - 2007^184^ | Physician reminder to remove catheter beginning on day 4/ No Intervention (usual care) | Adherence | Duration of overall UC | | | ⋄ | 8.4 → 6.7 (p=0.14) | Overall late CAUTI was adjusted for sex, age, average duration of catheterization, iterative catheter change, and use of antibiotics before or during catheterization. Unit of measure for early CAUTI was frequency of early CAUTI per 100 catheterized patients.
Crouzet, France - 2007^184^ | Physician reminder to remove catheter beginning on day 4/ No Intervention (usual care) | Infection Rate | Late (>4 days) Overall | • | | | 12.3 →1.8 (p=0.03)
Crouzet, France - 2007^184^ | Physician reminder to remove catheter beginning on day 4/ No Intervention (usual care) | Infection Rate | Late (>4 days) Orthopedic and cardiovascular surgery | • | | | 17.3 → 0 (p=0.0002)
Crouzet, France - 2007^184^ | Physician reminder to remove catheter beginning on day 4/ No Intervention (usual care) | Infection Rate | Late (>4 days) Neurology and neurosurgery | | | • | 11.8 → 0 (p=0.06)
Crouzet, France - 2007^184^ | Physician reminder to remove catheter beginning on day 4/ No Intervention (usual care) | Infection Rate | Late (>4 days) Geriatrics | | | • | 4.1 → 13.4 (p=0.67)
Crouzet, France - 2007^184^ | Physician reminder to remove catheter beginning on day 4/ No Intervention (usual care) | Infection Rate | Early (≤4 days) Overall | | | • | 7.8 → 13.9 (p=0.13)
Crouzet, France - 2007^184^ | Physician reminder to remove catheter beginning on day 4/ No Intervention (usual care) | Costs/Savings
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations in postoperative patients/ No Intervention (usual care) | Adherence | Mean duration of overall UC | ⋄ | | | 4.6 → 3.9 (p=0.02)
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations in postoperative patients/ No Intervention (usual care) | Adherence | Percent of patients with UC | ⋄ | | | 34.4% → 28.2% (p< 0.0001)
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations in postoperative patients/ No Intervention (usual care) | Infection Rate | Percentage of patients with UC with UTI | | | • | 12.9% → 11.7% (Adjusted RR: 0.92; 95% CI: 0.69 to 1.23
Greco, Italy - 1991^135^ | Active surveillance and implementation of new infection control recommendations in postoperative patients/ No Intervention (usual care) | Costs/Savings

Abbreviations: UC = urinary catheter; RR = relative risk; SAPS II = Simplified Acute Physiological Score II

• was used for infection rate outcomes

⋄ was used for adherence and costs/savings outcomes

###### Loeb et al. (2008)182

###### Summary

Loeb et al. implemented a patient level randomized, controlled trial within seven medical ICUs at three Canadian tertiary care hospitals.182 Compared with usual care, organizational change and a provider reminder system improved adherence rates, but no significant change in infection rates was observed.

###### Description

Three-hundred forty-seven patients were randomized to receive a stop order for their urinary catheter while 345 patients were randomized to usual care. The organizational change was to give the nurses the task to review the patients' chart, review the criteria for appropriate use of an indwelling urinary catheter, and assess whether the catheter should be removed. Randomization was stratified by hospital. The individuals assessing the presence of an infection were blinded to study group. Chi-square test and multivariable logistic regression, controlling for sex, antimicrobial use during catheterization, and diabetes, were used to analyze the adherence and infection rates.

###### Results and Limitations

After 30 months, a significant improvement in both mean duration of inappropriate indwelling urinary catheterization (3.89 days vs. 2.20 days, p<0.001) and total indwelling urinary catheterization in the stop order group was observed (5.04 days vs. 3.70 days, p<0.001) (Table 37). One-hundred and two CAUTI were identified, 51 in each arm, resulting in a nonsignificant difference between infection frequencies (20% vs. 19%, adjusted p=0.80). Reinsertion rates of indwelling urinary catheters were also similar between study groups (7.0% vs. 8.6%, p=0.45). Analysis adjusting for covariates showed the stop order was not associated with CAUTI, but female sex was a risk factor (p=0.047) and receiving antimicrobials during catheterization (p<0.0001) was protective against infection.

###### Saint et al. (2005)185

Saint et al. conducted a controlled before-after study to decrease urinary catheter-days.185 Details of this study are found in the 2007 report.3

##### Interrupted Time Series

###### Apisarnthanarak et al. (2007)183

###### Summary

Apisarnthanarak et al. implemented organizational change and a provider reminder system hospitalwide to remove unnecessary indwelling catheters in a tertiary care university affiliated hospital in Thailand.183 Significant reductions in inappropriate indwelling urinary catheterization and infection rate were observed.

###### Description

Through the use of a multidisciplinary team, the hospital initiated a provider reminder system to reduce the inappropriate use of catheters in the hospital. Nurses were given the task to identify patients on catheter day 3 or later. Members of the multidisciplinary team then reviewed the indications for the catheter along with other information and determined if the indwelling urinary catheter was appropriate. If deemed inappropriate, a physician from the multidisciplinary team held a bedside discussion with the patient's treating physician to determine the possibility of discontinuing the indwelling urinary catheter. Continual support for the intervention was provided during monthly staff meetings. A total of 1,105 patients had catheters in a 10-month baseline period and 1,307 had catheters in a 12-month postintervention period. Chi-square test and segmented regression were used to analyze adherence and infection rates, respectively.

###### Results and Limitations

Proportion of patients with an inappropriate catheter significantly declined from 20.4 percent in the baseline period to 11 percent in the postintervention period (p=0.04; Table 36). Segmented regression showed a significant initial reduction in mean duration of overall indwelling catheterization (p<0.001, Appendix Table G3) and mean infection rate (p<0.001, Appendix Table G3). A nonsignificant change in trend over time was observed for both mean duration of catheterization and infection rates (p=0.24 and p=0.50, respectively). Overall mean infection rates dropped from 21.5 infections per 1,000 catheter-days in the baseline phase to 5.2 infections per 1,000 catheter-days in the postintervention phase. There was also a significant reduction in mean monthly costs for CAUTI-associated antibiotic treatments in this entire Thai hospital ($3,739 vs. $1,378, p<0.001), and mean hospitalization costs per patient also decreased ($366 vs. $154, p<0.001). While segmented regression takes secular trend into account, it does not consider the changes between baseline and postintervention for other factors, such as patient characteristics, that may influence the risk of infection or nonadherence.

###### Marra et al. (2011)181

###### Summary

Marra et al. implemented a QI initiative using audit and feedback, a provider reminder system, organizational change, and provider education.181 This took place in three units, one ICU and two step-down units, within a private tertiary care hospital in Brazil. Using this combination of QI strategies, infection rates significantly improved over the study period.

###### Description

During the intervention period, the hospital CEO declared zero tolerance for CAUTI in the hospital. So a bladder bundle was initiated in addition to the surveillance and other procedures from the baseline period (chlorhexidine skin preparation, no routine change of catheters, and nurses provided feedback to ICU team about adherence to CDC guidelines for insertion). The bladder bundle was accompanied by a catheter insertion cart that held everything needed for a proper indwelling urinary catheter insertion. At the time of performance monitoring, nurses were allowed to address nonadherent bundle elements. A presentation on the protocol and bundle was given. Feedback on adherence was provided via email every month to the ICU team. Posters were also used to display adherence rates. An ICU nurses' group was formed to remove unnecessary catheters every day. ICU nurses were instructed to ask the treating physician daily if the catheter is necessary. Generalized linear models with a Poisson distribution were used to analyze infection rates.

###### Results and Limitations

Adherence rates were not analyzed, although, adherence rates were between 84 percent and 99 percent in the postintervention period. The step down units had slightly higher adherence rates than the ICU did. Appropriate urinary catheter indications were present in about 88 percent of the patients in the postintervention period. After 19 months, infection rates significantly improved in all three units. In the ICU, infection rates went from 7.6 (95% CI: 6.6 to 8.6) infections per 1,000 catheter-days in the baseline period to 5.0 (95% CI: 4.2 to 5.8) in the postintervention period (p<0.001). In the step-down units, infection rates went from 15.3 (95% CI: 13.9 to 16.6) in the baseline period to 12.9 (95% CI: 11.6 to 14.2) in the postintervention period (p=0.014).

A limitation of this study was the lack of ongoing surveillance. Small audits were conducted once a month at random to observe process measures. In addition, no baseline process measures were reported so the full effect of the intervention was not examined.

##### Simple Before-After

###### Fakih et al. (2012)187

Fakih et al. investigated the effects of organizational change, provider education, audit and feedback, and provider reminder systems on CAUTI rates in 163 units within 71 acute-care hospitals in the United States.187 This study was part of the Keystone ICU Project.

The formation of a team designed to disseminate information regarding to the study and promote collection of data were recommended at every participating hospital. Provider education was implemented through multiple webinars that addressed the infectious and noninfectious risks of catheter use ultimately focusing on assessing daily catheter need. Continuous feedback of process measures was provided to each unit. Nurses were encouraged to assess the necessity of indwelling urinary catheters during nursing round and contact the physician if no indication was present. A bladder bundle manual was given to every participating hospital. Further support was available through coaching calls and additional webinars.

A sample size was not reported. Fakih et al. (2012) stated that data reported after week 104 was too unreliable due to sparse data collection (week 104, 48%; week 140, 13%; week 152, 8%; week 190, 2%). Appropriate catheterization rate increased from 44.3 percent (95% CI: 13.9% to 16.6%) at baseline to 57.6 percent (95% CI: 51.7% to 63.4%; p=0.005) at 104 weeks. Overall use of indwelling urinary catheters decreased from 18.1 percent (95% CI: 16.8% to 19.6%) at baseline to 13.8 percent (95% CI: 12.9% to 14.8%; p<0.001) at week 104.

There are some limitations to this study including but not limited to a lack of objective identification of proper catheter use, a failure to account for effects of a multicenter study, adjustment for hospitals that primarily address patients where daily catheter use is required, and the sharp decline in data collection after two years. While two years is a substantial amount of data, this speaks to the sustainability of such a project.

###### Barrera et al. (2011)48

Barrera eta al. described a 4-year study in six ICUs (general, trauma, neurosurgery, burn, pediatric and neonatology) in Colombia investigating organizational change and provider education.48 There were 14,516 patients included over the entire study of which 2,398 acquired a HAI. Risks for CAUTI and HAI were compared using Poisson regression. Alcohol based hand rub was used as an indirect measure of hand hygiene. Use of the hand rub significantly improved 9.2 percent annually (p<0.001). Infection rates for CAUTI increased from 1.7 to 4.5 and was statistically significant (p=0.002). Barrera et al. (2011) also reported that CAUTI significantly increased by 8 percent annually.

###### Salim et al. (2011)145

Salim et al. reported on the effects of provider education and audit and feedback on CAUTI rates in women who underwent caesarean delivery in Israel.145 There were 1,616 patients enrolled in this 2-year study. Adherence was not reported. Infection rates were assessed using logistic and Poisson regression. Overall infection rates decreased from 1.2 percent to 0.3 percent (OR: 0.31; 95% CI: 0.08 to 1.17; p=0.08) and was nonsignificant. All ORs and IRRs were adjusted for membrane rupture and duration of operation. Salim et al. (2011) reported results by elective and non-elective cesarean. There were more significant results found in the elective cesarean group.

###### Seguin et al. (2010)69

Seguin et al. reported on a 9-month intervention in a university affiliated hospital in France.69 The intervention included a provider reminder system to reduce the duration of indwelling urinary catheterization, as well as central venous catheterization. During the baseline period, 676 patients were included, and during the postintervention period, 595 patients were included. One way analysis of variance (ANOVA) was used to analyze duration of catheterization while Poisson regression was used to analyze the infection rates. Due to group imbalances, both outcomes were adjusted for age, Simplified Acute Physiology Score II (SAPS II), and admission diagnosis. Significant changes in median duration of indwelling urinary catheterization (5 days vs. 4 days, p<0.001) and median time to urinary catheter removal (14 days vs. 8 days, p<0.001) were observed, but the change in infection rates was not statistically significant (5.0 infections per 1,000 catheter-days versus 4.9 infections per 1,000 catheter-days, p=0.94) (Table 37).

###### Crouzet et al. (2007)184

Crouzet et al. reported on a 3-month intervention at a university affiliated hospital in France.184 The intervention included a provider reminder system to reduce the duration of indwelling urinary catheterization. The baseline sample size was 141 while the postintervention sample size was 93 patients. ANOVA was used to analyze duration of catheterization while logistic regression was used to analyze infection rates. The regression model was adjusted for age, sex, duration of catheterization, systemic antibiotic administration, and repeated catheter replacement. Overall duration of indwelling catheterization was similar in the postintervention period and the baseline period (8.4 days vs. 6.7 days, p=0.14; Table 37). The authors divided CAUTI into two categories in this study, early CAUTI, defined as an infection occurring on or before catheter-day 4, and late CAUTI, defined as an infection occurring after catheter-day 4. Overall incidence of late CAUTI dropped significantly from 12.3 infections per 1,000 catheter-days in the baseline period to 1.8 infections per 1,000 catheter-days in the postintervention period (p=0.03). Analysis adjusting for covariates showed the intervention was significantly protective against late CAUTI occurrence (p=0.01). Limitations of this study are the small sample size and short postintervention period. Overall assessment of outcomes is weakened by Crouzet et al. (2007) reporting early and late CAUTI rates which cannot be aggregated with the overall CAUTI rates in the other studies.

###### Greco et al. (1991)135

Greco et al. conducted a before-after study to decrease urinary catheter-days, decrease urinary catheter use, and decrease UTI in post-operative patients.135 Details of this study are found in the 2007 report.3

#### Studies That Do Not Control for Confounding or Secular Trend

Sixteen studies that addressed prevention of catheter-associated urinary tract infections used a simple two sample test to analyze outcomes (Appendix Table F4).80,89,97,103,154,188-198 Fifteen studies were simple before-after study designs and one191 was a controlled before-after study. The controlled before-after study was demoted due to lack of between group comparisons. Five studies focused on reducing duration of catheterization.188-190,192,193 Seven studies implemented CAUTI bundles, including standardized protocols that focused both on sterile insertion and necessity of the indwelling catheter.80,89,97,191,194,196,198 Two studies implemented an educational program to increase awareness of hygiene and hospital acquired infections.103,154 Two others focused on better educating their residents through novel methods.195,197 Nine studies80,97,188,190,191,193,194,196,198 implemented audit and feedback, 9 studies80,89,97,189,192-194,196,198 implemented organizational change, 15 studies80,89,103,154,188-198 implemented provider education, and 8 studies89,188,192-196,198 implemented a provider reminder system.

#### Strength of Evidence

##### Audit and Feedback and Provider Reminder Systems and the Base Strategies Compared With Usual Care

Two studies used a combination of audit and feedback and provider reminder systems with the base strategies compared with usual care.181,187 The strength of evidence for this combination is summarized in (Table 38).

Table 38 Audit and feedback and provider reminder systems and the base strategies within CAUTI compared with usual care

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: Appropriate urinary catheterization | 1 Simple before-after study187 | High | Unknown | Indirect | Imprecise | Insufficient
Infection rate | 1 Interrupted time series181 | Medium | Unknown | Direct | Imprecise | Insufficient

###### Appropriate Urinary Catheterization

One study reported proportion of appropriately indicated indwelling urinary catheters only.187 The strength of evidence for this combination was judged as insufficient because there was only one study.

###### Infection Rate

One study reported only on infection rates.181 The strength of evidence for this combination was judged as insufficient because there was only one study.

##### Audit and Feedback and the Base Strategies Compared With Usual Care

The strength of the evidence for the use of this combination to reduce CAUTI compared with usual care is summarized in Table 39. Three studies48,135,145 used this combination.

Table 39 Strength of evidence for audit and feedback and the base strategies within CAUTI compared with usual care

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: overall urinary catheterization | 1 simple before-after 135 | High | Unknown | Indirect | Imprecise | Insufficient
Adherence: hand hygiene | 1 simple before-after 48 | High | Unknown | Indirect | Imprecise | Insufficient
Infection rate | 3 simple before-after 48,135,145 | High | Unknown | Direct | Imprecise | Insufficient
Adherence and infection rates | 2 simple before-after 48,135 | High | Unknown | Direct | Imprecise | Insufficient

###### Overall Urinary Catheterization

One study reported rate of urinary catheter use and duration of urinary catheters as well as percentage of patients with urinary infection in post-operative patients.135 The strength of evidence for this combination was judged as insufficient because there was only one study.

###### Hand Hygiene

One study reported the on the change in hand hygiene through the use alcohol-based hand rub use.48 The strength of evidence for this combination was judged as insufficient because there was only one study.

###### Infection Rate

Three simple before-after studies used this combination and analyzed infection rates.48,135,145 The risk of bias was judged to be high. One study48 reported a significant worsening in infection rates, while the other two135,145 reported a nonsignificant change over time. The consistency of the evidence is unknown. Infection rate is a direct measure and the evidence was deemed imprecise. The strength of evidence for this combination was judged as insufficient.

###### Adherence and Infection Rate

Two simple before-after studies used this combination and analyzed both adherence and infection rates.48,135 With unknown consistency and imprecise evidence for each outcome separately, the evidence for improving adherence and infection rates is also deemed insufficient.

##### Provider Reminder Systems Alone or with the Base Strategies Compared With Usual Care

The strength of the evidence for the use of a provider reminder system alone or with the base strategies compared with usual care is summarized in Table 40. Six of 11 studies used this combination of QI strategies.

Table 40 Strength of evidence for provider reminder system alone or with the base strategies within CAUTI compared with usual care

Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Adherence: overall urinary catheterization | 3 controlled studies182,185,186 1 interrupted time series183 2 simple before-after69,184 | Medium | Consistent | Indirect | Precise | Moderate
Adherence: inappropriate urinary catheterization | 1 controlled study182 1 interrupted time series183 | Medium | Consistent | Indirect | Imprecise | Insufficient
Adherence: correctly inserted urinary catheters | 1 controlled study186 | Medium | Unknown | Indirect | Imprecise | Insufficient
Infection rate | 1 controlled study182 1 interrupted time series183 1 simple before-after69 | Medium | Inconsistent | Direct | Imprecise | Insufficient
Adherence and infection rates | 1 controlled study182 1 interrupted time series183 1 simple before-after69 | Medium | Inconsistent | Direct | Imprecise | Insufficient

###### Duration of Overall Urinary Catheterization

All studies reported duration of overall catheterization as an outcome.69,182-186 As shown in Table 36, 1 study182 is of higher quality, 3^183,185,186^ are of medium quality, and 2 studies69,184 are of lower quality. Due to the overall quality of these studies, the risk of bias was determined to be medium. Four of the 6 studies69,182,183,185 observed a significant improvement in duration of overall indwelling urinary catheterization, and the study184 with a nonsignificant finding was consistent in direction. The last study had mixed results.186 There were significant improvements in 2 of the 4 departments. Duration of overall indwelling urinary catheterization, however, is not a direct measure of appropriate catheter use. Therefore, this outcome was deemed to be an indirect measure of adherence. The baseline (or control) duration of overall catheterization ranged from 5.0 to 11.0 days. The postintervention duration ranged from 3.0 to 6.7 days. One controlled study found a significant decrease, from 14.4 to 13.3 percent, in the proportion of days catheterized.185 Another found that 460 catheter-days (95% CI: 162 to 761) were eliminated per 100 catheterized patients.186 The evidence was judged to be precise. Use of a provider reminder system alone or with the base strategies for improving duration of overall urinary catheterization as compared with usual care is considered to have a moderate strength of evidence.

###### Inappropriate Urinary Catheterization

Two studies182,183 reported measures of inappropriate indwelling urinary catheterization, but each used a different metric. Apisarnthanarak et al. (2007)183 used proportion of patients with an inappropriate catheter, while Loeb et al. (2008)182 measured duration of inappropriate catheterization. As shown in Table 36 1 study182 is of higher quality and 1 is of medium quality.183 Risk of bias was judged to be medium. The evidence was considered consistent because in both studies a statistically significant improvement was noted. This outcome is considered indirect given the two approaches to measuring inappropriate urinary catheter use. With only 2 studies and different measurements, this is judged as imprecise. The strength of evidence for use of a provider reminder system alone or with the base strategies for duration of inappropriate urinary catheterization as compared with usual care was considered insufficient.

###### Correctly Inserted Urinary Catheters

One study reported proportion of correctly inserted urinary catheters.186 Little can be gleaned from 1 study. The strength of evidence for the use of a provider reminder system alone or with the base strategies to improve correctly inserted urinary catheters is insufficient.

###### Infection Rate

Three of the 6 studies reported overall infection rates.69,182,183 While the study by Crouzet et al. (2007)184 reported on infection rates, it is not included here with the other studies because it reported on early CAUTI and late CAUTI but did not report on the overall CAUTI rate. As shown in Table 36, one study182 is of higher quality, 1 study183 of medium quality, and 1 study69 of lower quality. Risk of bias was judged to be medium. The evidence was considered inconsistent because there was no clear direction of change among all 3 studies. The higher quality study found no change in infection rate, 20 percent versus 19 percent; the medium quality study did not find a change in trend over time although an initial change due to the intervention was observed; and the lower quality study also observed no change in infection rate, 5.0 versus 4.9 infections per 1,000 catheter-days. The evidence for infection rate was judged as imprecise. Therefore, evidence for use of a provider reminder system alone or with the base strategies for improving infection rates as compared with usual care was considered insufficient.

###### Adherence and Infection Rate

Three of 6 studies reported overall infection and adherence rates.69,182,183 The strength of evidence for implementing a provider reminder system alone or with the base strategies for improving infection rates was judged to be insufficient. Therefore, the strength of evidence for implementing a provider reminder system alone or with the base strategies to improve adherence and infection rates was judged to be insufficient, as well.

###### Cost Savings

Two studies reported cost savings information,183,185 which will be discussed in the section on Key Question 1b.

## Key Question 1b What is the cost, return on investment, or cost-effectiveness of QI strategies to improve HAI?

### Costs and Savings Associated With QI Strategies

Fourteen studies45,49,70,72,74,76,104,105,108,115,159,185,186,199 discussed in the previous sections of Question 1, were identified that provided information related to the implementation costs and/or savings of QI initiatives to reduce HAI. Eleven studies45,49,70,72,74,76,105,108,185,186,199 adjusted for confounding or secular trend reported information on savings. Three studies that did not adjust for confounding or secular trend provided information on the costs of the QI initiative. Savings reported in studies that did not adjust for confounding or secular trend were not considered in this section given the concerns about the study outcomes as noted previously. The literature reviewed for this report identified only 1 study that provided a detailed analysis for net savings185 and no studies provided a comprehensive analysis of return on investment.

Waters et al.199 conducted an economic analysis of the Keystone ICU Project from the perspective of the hospital using infection data that was reported in 2 studies captured in this report.46,47 Through the use of activity-based costing techniques, the incremental operational costs of the Keystone ICU Project were calculated. Costs considered were the following: hospital staff salary, equipment costs, supplies costs, laboratory costs, and pharmaceutical costs. A random sample of six hospitals, ranging in size, location, and teaching status, were used. Taking into account initial education and training expenses, capital purchases, ongoing timing spent on the intervention, average annual salary, and product purchases, the total annual cost per hospital was estimated to be $161,584. Table 41 below provides an itemized breakdown of the total cost. Mean baseline CLABSI and VAP rates were 7.7 and 6.9 infections per 1,000 device-days, respectively. After 30 and 36 months of implementation, respectively, the CLABSI rate was 1.1and the VAP rate was 2.4 infections per 1,000 device days. The authors calculated that each year 47.9 infections per hospital were avoided due to this project, 29.9 CLABSI and 18.0 VAP, and the intervention cost was $3,375 per infection avoided.

Table 41 Savings associated with quality improvement initiatives in studies that control for confounding or secular trend

Author, Country – Year / Intervention | Audit and Feedback | Financial Incentives | Organizational Change | Patient Education | Provider Education | Provider Reminder Systems | Metric | Statistics for cost savings | Cost/Savings | Savings/Calculations
Waters, United States – 2011^46,47,199^ (Keystone ICU Project) | • | | • | • | • | | VAP rate | None | Startup costs (FY 2004-2005, Beginning of Project):; - Education and training expenses(per diem): $3,035; - Nurses (8 per hospital): $19,534; - Physicians (2 per hospital): $33,357; - Respiratory therapists: $3,459; - Infection control staff: $1,488; - Pharmacists: $2,047; - Central line insertion cart: $1,500; Startup costs (FY 2008):; - Education and training expenses(per diem): $691; - Nurses (8 per hospital): $4,397; - Physicians (2 per hospital): $7,591; - Respiratory therapists: $787; - Infection control staff: $339; - Pharmacists: $466; - Central line insertion cart: $341; Ongoing costs (FY 2008):; - Nurses (8.9% of time on average): $47,652; - Physicians (12.2% of time): $64,123; - Respiratory therapists (12.5%): $6,666; - Infection control staff (7.5%): $4,000; - Pharmacists (6.5%): 6,474; - Chlorhexidine: $2,058; - Oral care kits: $6,000; - Sterile central line dressing kits: $10,000; Total costs(FY 2008): $161,584 Cost of intervention per infection avoided: $3,375 | A sample of six hospitals that participated in the Keystone ICU Project was asked to participate in this study. Activity based costing techniques were used to estimate the cost of the project. A series of semistructured interviews with staff from each hospital took place to get an idea of how much time was spent on project specific activities. Cases avoided were calculated using the mean CLABSI and VAP rates from each quarter reported in the Keystone Project and comparing that to the baseline. Authors calculated 29.9 CLABSI and 18.0 VAP avoided per year during the study. The cost of the funding from AHRQ was not included in the study.
Waters, United States – 2011^46,47,199^ (Keystone ICU Project) | • | | • | | • | • | CLABSI rate | None
Apisarnthanarak, Thailand - 2007^108^ / Educational Program | | | • | | • | | Costs | 2-tailed student's t-test | Results reported for period 1 (baseline, 12 months) → period 2 (intervention period, 12 months) → period 3 (ongoing intervention and followup, 12 months) MICU hospitalization costs per patient: $466 → $293 → $254 (p<0.001, compared to period 1) MICU monthly antibiotic cost for VAP : $4769 → $2622 → $2378 (p<0.001, compared to period 1) SICU hospitalization costs per patient (Control): $399 → $384 → $395 (p=NS) SICU monthly antibiotic cost for VAP (Control): $2901 → $2884 → $2799 (p=NS) CCU hospitalization costs per patient (Control): $404 → $401 → $415 (p=NS) CCU monthly antibiotic cost for VAP (Control): $2876 → $2991 → $2994 (p=NS) | Costs for hospitalization were estimated using available programmatic, personnel, pharmacy, and laboratory data. Hospital costs were estimated from the Thai insurance and hospital reimbursement systems. Cost of antibiotics was calculated on the basis of the actual dosage given to the patients and based on the purchase price of the institution without administration costs. All costs were converted from Thai Baht to US Dollars at a conversion rate of 40 to 1.
Berenholtz, United States – 2004^49^ / Education, CVC cart, nurse empowerment, checklist, and daily assessment of need | • | | • | | • | • | CLABSI Rate | None | $1,945,922 ( Range $1,483,844-$2,408,000) | The attributable savings were calculated based on published estimates of extra costs per case of CLABSI of $45,254 ($34,508 - $56,000). The annual reduction on CLABSI rates was estimated to be 43 cases. Thus, the estimated savings [ $1,945,922 (Range $1,483,844-$2,408,000)] are based on this information.
Costello, United States - 2008^45^ / Pediatric multidisciplinary CLABSI bundle | • | • | • | | • | • | CLABSI rate | None | $236,000-$782,000 | The attributable savings was calculated using estimates from published cost analyses from adult ICUs and general PICUs. The authors assumed approximately 20 CLABSI were prevented each year.
Miller, United States - 2010^65,105^ / Bundle - CLABSI | • | | • | | • | • | CLABSI rate | None | Cost to participate in collaborative: $75,000 per hospital Cost per CLABSI episode: $45,000 CLABSI attributable health care cost savings: $31 million | Authors used literature based adult estimates of CLABSI attributable mortality rates and pediatric-specific CLABSI morbidity information to come up with an estimated per CLABSI episode. Using this and estimated lives saved and CLABSI prevented, the attributable health care cost savings was estimated.
Frankel, United States – 2005^76^ /Six Sigma Performance Improvement | • | | • | | • | | CLABSI rate | None | Estimated at least $66,000 per year | The attributable savings were calculated based on cost estimates, the authors estimated each case of CLABSI cost about $3,000. The annual reduction on CLABSI rates was estimated to be 22 cases. Thus, the estimated savings are “at least” $66,000 per year. The incremental costs of preparing insertion kits and purchasing antibiotic-coasted catheters were less than $5,000 per year. No additional information was provided about other costs of implementation, e.g. education and supervision.
Kim, United States – 2011^72^ / CLABSI bundle with cart | • | | • | | • | • | | None | Total weighted excess cost for CLABSI: $32,254 Cart cost: $100 per unit | This was calculated by adding up the cost of excess length of stay, replacement of the central line, drug administration costs, and the cost of the drug itself. Excess cost was weighted by type of organism isolated.
Harris, United States – 2011^74^ / Hand hygiene, VAP bundle, standardizing central line care | • | | • | | • | • | Cost of stay | Generalized linear models | Average baseline period PICU cost: $34,365 (SD $2,446) Average intervention period PICU cost: $30,175 (SD $2,139) Average postintervention period PICU cost: $25,938 (SD$1,146) | Adjusted costs were calculated for the intervention and postintervention periods using Adjusted intervention cost: -$3,948 (95% CI: -$10,678 to $2,782) Adjusted postintervention cost: -$8,826 (95% CI: -$13,950 to -$3,702)
Duane, United States - 2009^70^ / Group 3: Central venous line (CVL) protocol + CVL supply cart + nurse education + nurse checklist and nurse empowerment; Group 2: CVL protocol to reduce catheterization duration + resident education; Group 1: Usual care | | | • | | • | • | Length of stay | None | Group2 (vs. Group1): $19,615.70 hospital charges per patient; Group3 (vs. Group1): $28,391.87 hospital charges per patient | Costs were calculated by using the length of stay and comparing group 1 with group 2 and 3. Length of stay was adjusted by injury severity score which differed between groups. Adjusted length of stay was multiplied by the average daily charge for hospital stay ($7,249)
van den Broek, Netherlands – 2011^186^ / Revision of existing protocols, introduction of staff education and change to daily practice | | | • | | • | • | Cost of implementation | None | Cost of implementing program per hospital (Includes implementation expert): €2,638 (Range: €1,023 to €3,763) Cost of implementing program per hospital (Without implementation expert): €1,993 Cost of insertion of an indwelling catheter: €28 Cost of removal of an indwelling catheter: €3 Cost of daily care: €3 Mean amount saved per 100 hospitalized patients: €537 (Range: - €369 to €1,666) | All involved in the intervention were asked to record time spent on the intervention. Other costs such as travelling, meetings and material costs were listed. Cost of catheterization and daily care was estimated using material cost and mean time spend by health care workers. Mean time was estimated by asking 18 nurses as 5 different hospitals. Cost of materials was estimated using hospital purchase prices.
Saint, United States - 2005^185^ / Urinary catheter reminder in patient chart and pager reminder | | | | | | • | Reduction in urinary catheter days | None | Intention to treat analysis: $249 per year savings Per-protocol analysis: > $50,832 per year | Their economic analysis was based on the literature and their experience with the intervention. It involved a number of assumptions including the daily rate of bacteriuria with indwelling catheters, the number of patients a nurse can evaluate in an 8-hour workday, percentage of patients who are catheterized at any time, costs of supplies and printing for the reminders, and cost of a nurse with the skills to do the intervention (reminder). Based on an estimated 0.9 day reduction in urinary catheter use, savings were estimated at $53,449 per year while costs were $53,200 per year for a net savings of $249 per year.

Apisarnthanarak et al.108 used provider education and organizational change to reduce ventilator associated pneumonia (VAP) in an 8-bed medical ICU (MICU) in Thailand. In this quasi-experimental study, the surgical ICU and coronary care unit served as control groups. Costs were presented as a reduction in mean cost of antibiotics and hospitalization between the baseline and postintervention periods in the MICU and control groups. Costs were obtained from programmatic, personnel, pharmacy and laboratory data and converted from Thai Baht to U.S. dollars. The authors found a significant reduction in the total cost of antibiotics and cost of hospitalization (MICU hospitalization costs per patient decreased from $466 at baseline to $293 in period 2 to $254 in period 3; p<0.001 compared to baseline) for the MICU but no reduction was present for the SICU and CCU (Table 41).

Berenholtz et al.49 used audit and feedback, organizational change, provider education, and provider reminder systems for the reduction of CLABSI in a SICU in the United States. A concurrent ICU in the same hospital was used as a control group which received provider education alone. Previously published estimates of the extra costs incurred per CLABSI case of $45,254 ($34,508 to $56,000) were multiplied by the estimated number of prevented infections to calculate savings. The authors estimated an annual reduction of 43 CLABSI cases which corresponds to a savings of $1,945,922 ($1,483,844 to $2,408,000). No information on costs of implementation was presented.

Costello et al.45 used audit and feedback, organizational change, provider education and provider reminder systems for the reduction of CLABSI in a PICU in the United States. Savings were estimated from previously published cost analysis on the price of a CLABSI infection in the PICU and extrapolated based on the author's estimated reduction of 20 CLABSI cases per year for a total annual savings of $236,000 to $782,000.

Miller et al.65,105 used audit and feedback, organizational change, provider education, and provider reminder systems to reduce CLABSI rates in 29 pediatric ICUs across the United States. The authors estimated it cost $75,000 per hospital to be a part of the collaborative and that each CLABSI episode cost $45,000. The estimated CLABSI attributable health care cost savings was $31 million. No further details were provided.

Frankel et al.76 used audit and feedback, organizational change, and provider education for the reduction of CLABSI in a SICU at an academic tertiary care center in the United States. Savings attributed to the QI strategy were based on an estimate of $3,000 incurred per CLABSI case. The authors estimated that 22 CLABSI cases were prevented each year for a conservative estimated savings of $66,000 per year. The authors state that the costs of purchasing antibiotic-coated catheters and preparing insertion kits cost less than $5,000 per year. No additional information was provided about other costs of implementation, for example, costs of education and supervision.

Kim et al.72 used audit and feedback, organizational change, provider education, and provider reminder systems to reduce CLABSI rates in the emergency department and ICU of an academic hospital in the United States. The total excess cost was calculated using cost of excess length of stay, cost of replacement of central line including materials for maximal sterile barrier, drug administration costs, and antibiotic costs. The total weighted excess cost for CLABSI, regardless of organism, was $32,354. The authors say the cost of creating the bundle was not considered due to the fact that the overhead costs were negligible. Also, all materials for the bundle were already present in the hospital except for the actual cart, estimated to cost $100 per ICU. No administrative costs were taken into account because the policies did not change.

Harris et al.74 used audit and feedback, organizational change, provider education, and provider reminder systems to reduce CLABSI and VAP rates in the pediatric ICU of a tertiary academic institution. Costs were estimated using the hospital specific cost-to-charge ratio, reflecting the hospital's point of view, not the payer. Costs were adjusted for patient age, sex, race, insurance coverage, comorbidities, and the primary specialty of the treating physician. Costs were modeled using generalized linear models with a gamma distribution and log link function. Compared to baseline, the adjusted PICU costs during the intervention period was -$3,948 (95% CI: -$10,678 to $2,782) and during the postintervention period PICU costs were–$8,826 (95% CI: -$13,950 to -$3,702; p<0.001). Compared to baseline, the adjusted hospital costs during the intervention period was -$7,697 (95% CI: -$15,990 to $597) and during the postintervention period hospital costs were -$12,136 (95% CI: -$19,058 to -$5,214; p<0.001).

Duane et al.70 used organizational change, provider education, and provider reminder systems to reduce CLABSI at a Level 1 trauma center in the United States. Savings were based on changes in length of stay between the baseline, partial intervention, and full intervention periods. The average charge for a day in the ICU ($7,249) and outside of the ICU ($2,751) was used to calculate the differences in cost between the patient groups. Length of stay varied significantly from baseline (30.54 days ± 2.08) and the partial (23.41 days ± 1.73; p=0.02) and full interventions (20.22 days ± 2.0; p=0.001) and accounted for an estimated savings of $19,616 per patient when comparing the baseline to partial intervention group and $28,392 when comparing the baseline to full intervention group.

van den Broek et al.186 used organizational change, provider education, and provider reminder systems to reduce CAUTI rates in ten Dutch hospitals. All health care providers involved in the intervention were asked to record time spent on the intervention. Other costs such as travelling, meetings and material costs were also listed. Cost of catheterization and daily care was estimated using material cost and mean time spend by health care workers. The mean time was estimated by asking 18 nurses as 5 different hospitals. Cost of materials was estimated using hospital purchase prices. The mean cost per hospital of implementing program, with the help of an implementation expert was €2,638 ranging from €1,023 to €3,763. The cost of implementing program without an implementation expert was €1,993. Inserting an indwelling catheter was estimated to cost €28 while the removal of an indwelling catheter cost €3. The cost of daily care was estimated to be €3. All in all, the mean amount saved per 100 hospitalized patients was €537, ranging from - €369 to €1,666. Two of ten hospitals saw an increase in costs after the implementation of the QI initiative.

Saint et al.185 used provider reminder systems alone in an effort to reduce the duration of indwelling urethral catheterization in two wards of a university-affiliated hospital in the United States. Two concurrent, non-equivalent wards in the same hospital served as controls. The authors conducted an economic analysis with the following underlying assumptions based on experience and published literature: the daily rate of bacteriuria is 5 percent per day of indwelling catheterization, a nurse can evaluate approximately 360 hospitalized patients per 8-hour workday to assess urinary catheter status, 25 percent of patients will be catheterized at a given time, no cost is present for asymptomatic bacteriuria, the cost of supplies and printing the urinary catheter reminder is $2,000 per year, and the cost of a nurse to ensure the intervention is being followed appropriately is $51,000 for a total cost of $53,200. The cost of a symptomatic CAUTI was estimated as at least $500 per episode. The authors found that the reminder system decreased indwelling catheter duration by 0.9 days (4.6 days for the control wards and 3.7 days for the intervention wards) when conducting an intention to treat analysis and 1.6 days decrease when doing a per-protocol analysis. The net savings were calculated to be $249 per year in the intention to treat analysis and more than $50,832 per year in the per-protocol analysis.

Two additional studies112,138 that controlled for confounding or secular trend reported cost data but were not included in this section because of a lack of specific information related to the savings from the QI initiative. Mannien et al.138 report on work to reduce SSI rates in multiple institutions in the Netherlands. This study reports cost savings only briefly and states that the QI initiative led to a 25 percent decreased cost per procedure due to a shorter period of prophylaxis, but did not provide specific values. Dubose et al.112 implemented a QI strategy to reduce VAP at a trauma ICU in the United States. Results for mean charges were presented for the fully compliant group and the partially compliant group for only the postintervention period. The authors did not provide information on patient factors or comorbid conditions that can directly influence both adherence and costs.

The three studies that did not control for confounding or secular trends104,115,159 reported data on the costs of implementing aspects of the QI initiative. Kable et al.159 implemented a QI strategy to increasing adherence with antibiotic guidelines for five common, elective surgical procedures at two teaching hospitals in Australia. Costs of recommended antibiotic prophylaxis by procedure were determined and showed variability among type of procedure (Table 42). Sona et al.115 put into practice use of oral care to reduce rates of VAP. The authors estimated the total cost of the supplies for the protocol (toothbrushes, toothpaste, and oral antimicrobial solution) was $2,187.49 over a 12-month period and was used to treat about 900 patients on mechanical ventilators. Bakke et al.104 implemented a CLABSI bundle to reduce the incidence of catheter-related infections in end stage renal disease patients undergoing hemodialysis. The cost-effectiveness of current practice using 4 percent chlorhexidine soap and sodium hypochlorite ($27,771.02 per year) was compared to 3.15 percent chlorhexidine and 70 percent alcohol ($9,266.40 per year) for an estimated dialysis product savings of $18,504.62 over 52 weeks.

Table 42 Implementation costs associated with quality improvement initiatives in studies that did not control for confounding or secular trend

Author, Country – Year / Intervention | Study Design | Infection | Audit and Feedback | Financial Incentives | Organizational Change | Patient Education | Provider Education | Provider Reminder Systems | Cost of Intervention
Kable, Australia - 2008^159^ / Increased adherence to antibiotic prophylaxis guidelines | Simple before-after | SSI | | | | | • | • | Costs per patient of recommended prophylactic antibiotics: TURP: $0.62 Cholecystectomy: $2.54 Herniorrhaphy: $0.15 Hysterectomy: $6.24 Joint arthroplasty: $4.30
Sona, United States - 2009^115^ / Oral care with tooth brushing and oral chlorhexidine of ventilated patients | Simple before-after | VAP | • | | • | | • | | 473-mL bottle of oral antimicrobial solution, $2.11 Floor stock toothbrush, $0.07 Floor stock toothpaste, $0.24 The estimated cost of the protocol was $2187.49 for 12 months.
Bakke, United States – 2010^104^ /CLABSI Bundle for end stage renal disease hemodialysis patients | Simple before-after | CLABSI | • | | • | | • | • | 7 swabs for site-care $0.70 Registered Nurse time @ 39/hour with benefits doing site care for 3 minutes: $1.95 Registered Nurse time @ $39/hour with benefits doing HD hub/line care for 1 minute: $0.65 Estimated cost of changing to chlorhexidine 3.15%/alcohol 70% swabs per year: $9266.40

### Strength of Evidence

Given the limited number of studies that evaluate costs and/or savings, the limited data on net cost savings, as well as the variation in QI initiatives used in those studies and the varied metrics studied related to costs, the strength of evidence related to the overall cost and savings associated with use of various QI initiatives to reduce HAI is insufficient. Formal tables for strength of evidence were not created.

Furthermore, important questions related to costs and savings were not addressed by the studies; only one study that provided a detailed analysis for net savings and no studies provided a comprehensive analysis of return on investment.

## Key Question 1c Which factors are associated with the effectiveness of QI strategies?

Key Question 1c addresses which factors among the following are associated with the effectiveness of QI strategies: type of QI strategy, duration of intervention, setting of intervention, and staff involved in the implementation of the intervention. We limited this analysis to studies that report and analyze changes in both adherence rates and infection rates because these studies provide the strongest possible causal evidence. To provide a more generalizable and robust synthesis of QI strategies, the analysis in this section combines studies across the four HAI.

The focus of this section is type of QI strategy, for which there is the most evidence. Duration of the QI strategy was a part of the individual study quality appraisals, but will not be an independent factor in this section, with a majority of the studies lasting at least 1 year. Because all of the included studies were in hospital settings, and there were no direct comparisons of QI strategies between multiple units in a single hospital or across hospitals, we were unable to conduct any setting comparisons. Because we combined studies from the four infections, we were also unable to conduct staffing comparisons since different infections require different staffing involvement. For example, reducing VAP rates usually required cooperation from the nursing staff, while reducing SSI rates may have required involvement of the pharmacy and anesthesiology staff.

### Combinations of QI Strategies Across HAI

For Key Question 1a, we synthesized strength of evidence for combinations of QI strategies within four HAI: CLABSI, VAP, SSI, and CAUTI. Here we assess the strength of evidence for combinations of QI strategies across HAI.

Twenty-six studies analyzed both adherence and infection rates.45,47,48,51,53,59,64,65,67-70,75,107-109,133,135-138,140,142,143,182,183 Four of these studies did not separately analyze adherence rates, but adherence was included in the regression analysis for infections.59,65,70,137 Two studies analyzed adherence and infection rates for two infections each69,135 and one of these analyzed adherence and infection rates for three infections.48 These studies will be treated as separate studies, one for each infection, as was done for Key Questions 1 and 1a. Table 43 summarizes the 30 studies included in this section.

Table 43 Overview of studies across HAI

Study Characteristic | Categories | AF + PRS + Base^a^ | AF + Base^b^ | PRS + Base^c^ | Base^d^ | All
Infection | CLABSI | 3 | 3 | 2 | 1 | 8
Infection | VAP | 3 | 0 | 4 | 1 | 8
Infection | SSI | 2 | 3 | 3 | 0 | 8
Infection | CAUTI | 0 | 3 | 2 | 0 | 5
Infection | TOTAL | 8 | 9 | 11 | 2 | 30
Study Quality | Higher | 1 | 2 | 0 | 1 | 4
Study Quality | Medium | 4 | 1 | 3 | 0 | 8
Study Quality | Lower | 3 | 6 | 8 | 1 | 18
Study Quality | TOTAL | 8 | 9 | 11 | 2 | 30

a Audit and feedback and provider reminder systems with the base strategies

b Audit and feedback with the base strategies

c Provider reminder systems with the base strategies

d Base strategies alone

The strength of evidence for each combination was determined using the approach described in the Methods chapter and applied to each HAI in section 1a of the Results chapter. All comparisons were to usual care. Table 44 displays the strength of evidence for combinations of QI strategies across HAI.

Table 44 Strength of evidence for combinations of QI strategies

Combination | Outcome | Number/Type of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
AF + PRS + Base^e^ | Adherence and infection rates | 1 controlled study107 1 stepped wedge137 4 interrupted time series45,51,65,109 2 simple before-after75,140 | Medium | Consistent | Direct | Precise | Moderate
AF + Base^f^ | Adherence and infection rates | 1 controlled study53 a 2 interrupted time series64,138 8 simple before-after47,48,67,135,136 a,b,c | Medium | Consistent | Direct | Precise | Moderate
PRS + Base^g^ | Adherence and infection rates | 2 controlled studies133,182 1 interrupted time series183 6 simple before-after59,69,70,142,143 d | Medium | Inconsistent | Direct | Precise | Low
Base^h^ | Adherence and infection rates | 1 controlled study108 1 Simple before-after68 | High | Consistent | Direct | Imprecise | Insufficient

a One of these studies reported on both CLABSI and VAP, but only reported adherence for VAP. VAP outcomes only are considered for this strength of evidence.

b One of these studies reported on both SSI and CAUTI.

c One of these studies reported on CLABSI,VAP, and CAUTI.

d One of these studies reported on both CLABSI and CAUTI.

e Audit and feedback and provider reminder systems with the base strategies

f Audit and feedback with the base strategies

g Provider reminder systems with the base strategies

h Base strategies alone

#### Audit and Feedback, Provider Reminder Systems, and the Base Strategies Compared With Usual Care

Eight studies reported both adherence and infection rates and used a combination of audit and feedback, provider reminder systems, and the base strategies, compared with usual care.45,51,65,75,107,109,137,140 Three reported on CLABSI,45,65,75 3 reported on VAP,51,107,109 and 2 reported on SSI.137,140 One107 was of higher quality, four45,65,109,137 were of medium quality, and 3^51,75,140^ were of lower quality.

Considering the quality and number of studies using this combination, the risk of bias was judged to be medium. Three studies reported overall adherence measures, all of which showed statistically significant improvement after the intervention.51,107,109 In the other five studies, 16 of 26 adherence measures demonstrated a statistically significant improvement. In one of those studies, however, one of five measures had a statistically significant decline.140 Miller et al. did not analyze adherence rates separately, but in multivariable analysis, adherence to the maintenance bundle was protective against CLABSI.65

Five of 7 studies reported infection rates as significantly improved.45,51,65,75,109 One of the two nonsignificant infection rates went from 15.3 in the baseline period to 9.3 in the postintervention period.107 Kao et al. did not analyze infection rates separately, but the authors reported nonadherence to antibiotic prophylaxis to be predictive of SSI.137 The evidence was judged to be consistent and precise based on the direction and significance of the results across the eight studies. Adherence and infection rates together are considered a direct measure. There is moderate strength of evidence that the use of this combination improves adherence and infection rates compared with usual care.

#### Audit and Feedback and the Base Strategies Compared With Usual Care

Eleven studies reported both adherence and infection rates and used a combination of audit and feedback, organizational change, and provider education, compared with usual care.47,48,53,64,67,135,136,138 Two48,64 reported on CLABSI, 4^47,48,53,67^ reported on VAP, 3 reported on SSI,135,136,138 and 2^48,135^ reported on CAUTI. Three articles53,64,138 are of medium quality and 5 articles47,48,67,135,136 are of lower quality.

Considering the quality and number of studies, the risk of bias was judged to be medium. Three of the lower quality studies47,67,136 contributed strong evidence because they were multisite statewide initiatives that showed a large magnitude of improvement. The fourth lower quality study135 was also a multisite study. All adherence rates in this set of studies significantly improved. Ten of 17 infection measures showed a statistically significant improvement. Two of the 3 medium quality studies showed statistically significant improvement (for one, it was for 7 of 8 comparisons).47,64 Two of the studies that had a nonsignificant change in infection rates may have experienced a floor effect.67,136 DePalo et al. (2010)67 reported a baseline rate of 0.58 infections per 1,000 catheter-days that dropped to 0 in the postintervention period while Dellinger et al. (2005) found an improvement from 2.3 percent to 1.7 percent over the study period.136 For one measure, there was a statistically significant decline in CAUTI.48

The evidence was judged to be consistent and precise based on the direction and significance of the results across the 11 studies. Adherence and infection rates together are considered a direct measure. There is moderate strength of evidence that the use of this combination improves adherence and infection rates compared with usual care.

#### Provider Reminder Systems Alone or With the Base Strategies Compared With Usual Care

Nine studies reported both adherence and infection rates and used a combination of provider reminder systems alone, or with the base strategies, compared with usual care.59,69,70,133,142,143,182,183 Three studies59,69,70 reported on CLABSI, 3 reported on SSI,133,142,143 and 3 reported on CAUTI.69,182,183 Two133,182 are of higher quality, 1^183^ is of medium quality, and five articles59,69,70,142,143 are of lower quality.

Considering the quality and number of studies, the risk of bias was judged to be medium. One of the lower-quality studies59 contributed strong evidence because it was a multisite statewide initiative with a substantial and highly statistically significant magnitude of change. All adherence rates in this set of studies significantly improved and 5 of 9 studies observed a significant improvement in infection rates.59,70,142,143,183 Neither of the higher quality studies133,182 reported a significant improvement in infection rates. Loeb et al. (2008)182 did have some internal validity issues that have already been discussed in earlier sections of the Results chapter. Seguin et al. (2010) reported on both CLABSI and CAUTI.69 The CLABSI rate went from 2.8 infections per 1,000 catheter-days to 0.7 (p=0.051) while the CAUTI rate was similar in the baseline and postintervention periods (5.0 vs. 4.9 infections per 1,000 catheter-days, p=0.938). Schulman et al. (2011)59 did not analyze adherence separately, but utilization of the maintenance checklist was significantly associated with improved CLABSI rates.

Because half of the infection rates demonstrated nonsignificant change, the evidence was judged to be inconsistent. All adherence rates in all studies showed significant improvement. The evidence was judged to be precise. Adherence and infection rates together are considered a direct measure. There is low strength of evidence that the use of this combination improves adherence and infection rates compared with usual care.

Even though this combination of QI strategies was found to have moderate strength of evidence when used to improve CAUTI rates, there were limited data for this combination for the other three infections. Therefore this conclusion was not generalizable across all four infections.

#### Base Strategies Compared With Usual Care

Two studies reported both adherence and infection rates and used a combination of organizational change with or without provider education, compared with usual care.68,108 One reported on CLABSI68 and one reported on VAP.108 One108 is of higher quality and the other68 is of lower quality. Considering the quality and number of studies, the risk of bias was judged to be high. Both studies68,108 found some improvement in adherence rates and significant improvement in infection rates. The evidence was judged to be consistent and imprecise, because of the paucity of evidence. Adherence and infection rates together are considered a direct measure. There is insufficient strength of evidence that the use of this combination improves adherence and infection rates compared to usual care.

## Key Question 2 What is the impact of context on the effectiveness of QI strategies?

The 71 studies that controlled for confounding or secular trend were also evaluated to address the impact of context on the effectiveness of the QI strategies. Context, generally, can be thought of as the “characteristics of the organization and its environment that influence the implementation and effectiveness of the patient safety practice.”24 A major difference between traditional clinical trials and studies of QI interventions in clinical facilities is that the effectiveness of the latter relies not just on the effect of the intervention but also on the interaction between the intervention and the context. This issue is often discussed when interpreting traditional clinical trials in terms of the generalizability of the results. In the case of healthcare-associated QI strategies, the impact of the context may be as important to the efficacy of the strategy as the inherent features of the strategy itself. A given strategy may work well in a hospital with a strong patient safety culture and executive buy-in, for example, but may not work at all in a hospital with a different context. Understanding the contextual feature(s) which influence QI strategies is essential to translating these initiatives to other settings. Without a clear insight into context it is unclear if a QI strategy can be implemented in a similar or equally impactful fashion given varying environmental characteristics.

The first step in understanding which features of the context are important for a given intervention is to identify which features were present or absent in a given study where the intervention did or did not work. We abstracted the following contextual factors from the included studies, as the authors of the RAND report recommended for use when evaluating the effectiveness of patient safety practices:20

- Theory behind patient safety practice
- Existing patient safety infrastructure
- External factors
- Leadership at unit level
- Change in responsibilities at unit level
- Availability of implementation and management tools

Table 45 tabulates the contextual factors reported in the 71 studies that control for confounding or secular trend. While organizational characteristics are easily determined in all studies, reporting on the remaining contextual factors was not complete in most of the studies.

Table 45 Overview of available contextual factors

Contextual Factor | CLABSI | VAP | SSI | CAUTI | Total
Health care setting: Single site | 14 | 15 | 8 | 8 | 45
Health care setting: Multiple site^a^ | 12 | 4 | 7 | 3 | 26
Total | 26 | 19 | 15 | 11 | 71
United States | 18 | 9 | 11 | 2 | 40
Other | 8 | 10 | 4 | 9 | 31
Total | 26 | 19 | 15 | 11 | 71
Theory behind patient safety practice | 9 | 3 | 4 | 0 | 16
Existing patient safety infrastructure | 8 | 6 | 2 | 4 | 20
External factors | 9 | 7 | 5 | 2 | 23
Patient safety culture and teamwork at unit level | 14 | 10 | 3 | 4 | 31
Leadership at unit level | 17 | 12 | 5 | 3 | 37
Change in responsibilities at unit level | 14 | 11 | 12 | 7 | 44
Availability of implementation materials and management tools | 19 | 13 | 11 | 6 | 49
0 Contextual factors reported^b^ | 1 | 0 | 1 | 0 | 2
1 Contextual factors reported^b^ | 2 | 2 | 2 | 1 | 7
2 Contextual factors reported^b^ | 4 | 3 | 4 | 7 | 18
3 Contextual factors reported^b^ | 4 | 8 | 3 | 0 | 15
4 Contextual factors reported^b^ | 7 | 1 | 3 | 2 | 13
5 Contextual factors reported^b^ | 7 | 4 | 2 | 1 | 14
6 Contextual factors reported^b^ | 1 | 1 | 0 | 0 | 2

Abbreviations: CAUTI = catheter-associated urinary tract infection; CLABSI = central line–associated bloodstream infection; VAP = ventilator-associated pneumonia; SSI = surgical site infection.

a Of the multiple site studies, the following number were state or country wide initiatives: 5 in CLABSI, 2 in VAP, 3 in SSI, and 1 in CAUTI

b Organizational characteristics were reported by all included studies. These capture additional contextual factors reported.

Roughly two-thirds of the studies took place in single sites45,48-51,53,55-57,61-64,66,68-70,72-74,76-78,107-113,133,139-143,145,146,181,183-185 and about half were from the United States.45-47,50,52,53,57,60,61,63,65-67,70-74,107,112,137,139-144,146,187 The most commonly reported contextual factor was availability of implementation materials, followed by changes in responsibilities at the unit level, and leadership at the unit level. The contextual factors that were discussed the least were theory behind patient safety practice and patient safety culture and teamwork at the unit level. Two studies reported no additional contextual factors other than organizational characteristics.62,138 About half of the studies reported at least half of the additional contextual factors of interest (four53,58,67,74 of which reported on two infections each).45,46,50,52,53,56,58,59,67,70-77,136,137,140,141,181,186,187 However, no study reported all seven additional contextual factors.

Several multisite studies conducted statistical analyses in an attempt to adjust for contextual factors among the participating sites. For example, Pronovost et al. (2010)46 included teaching status and hospital size in the regression models and found that neither of those factors was associated with CLABSI rates. Berenholtz et al. (2011)47 also report that teaching status and hospital size were not associated with infection rates in their study on VAP. They also noted that larger hospitals and teaching hospitals saw a slower decline in VAP rate compared to smaller or nonteaching hospitals initially, though by the end of the 30-month followup VAP rates were comparable among all hospitals.47 In a national study on SSI by Mannien et al. (2006),138 a nonlinear mixed model included the number of surgical procedures and the different mix of surgical procedures among the participating hospitals.

Other studies provided contextual details to inform their discussions on the implementation of the QI strategies. Burkitt et al. (2009)139 explain that the implementation team for this SSI study focused more of their efforts on the surgical department that performed the most procedures, and then found that this department subsequently had the highest adherence rates compared to the other surgical departments by the end of the study. In a statewide CLABSI initiative, Schulman et al. (2011)59 explain that some of the differences in CLABSI rates among the participating neonatal ICUs may be due to the different hospital cultures and the different behaviors of the providers.

While contextual factors impact the effectiveness of QI strategy implementation and the sustainability of the interventions, reporting of these factors is neither standardized nor required. Another barrier to reporting such information is the required brevity of publications by journals. Investigators of some studies in this review attempted to control for contextual factors in the analyses, others provided discussions of contextual differences, and still others did not address contextual issues at all. Therefore, our synthesis of context was limited to mapping the frequency with which contextual factors are reported and providing examples of how contextual factors were addressed in some of the studies.