# References

1 Adams K, Corrigan JM, editors. Priority Areas for National Action: Transforming Health Care Quality. Washington, DC. The National Academies Press. 2003.
2 Shojania KG, McDonald KM, Wachter RM, et al. Closing The Quality Gap: A Critical Analysis of Quality Improvement Strategies, Volume 1—Series Overview and Methodology. AHRQ Publication No. 04-0051-1. Rockville, MD. 2004.
3 Ranji SR, Shetty K, Posley KA, et al. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies (Vol. 6: Prevention of Healthcare-Associated Infections). AHRQ Publication No. 04(07)-0051-6. Rockville, MD. Agency for Healthcare Research and Quality. 2007. www.ncbi.nlm.nih.gov/pubmed/20734530.
4 Horan TC, Andrus M, Dudeck MA. CDC/NHSN surveillance definition of health care-associated infection and criteria for specific types of infections in the acute care setting. Am J Infect Control. Jun. 2008;36(5):309-32. [pmid: 18538699].
5 Klevens RM, Edwards JR, Richards CLJ, et al. Estimating healthcare-associated infections and deaths in U.S. hospitals, 2002. Public Health Reports. 2007;122(2):160-6. [pmid: 17357358].
6 CDC. National healthcare-associated infections standardized infection ratio report: using data reported to the National Healthcare Safety Network. Centers for Disease Control. 2010. www.cdc.gov/HAI/pdfs/stateplans/SIR-2010_JunDec2009.pdf.
7 Cardo D, Dennehy P, Halverson P, et al. Moving toward elimination of healthcare-associated infections: a call to action. Am J Infect Control. 2010;38(9):671-5. [pmid: 21058460].
8 Scott RD II. The direct medical costs of healthcare-associated infections in U.S. hospitals and the benefits of prevention. Publication No. CS200891-A. Centers for Disease Control and Prevention. March. 2009. www.cdc.gov/HAI/pdfs/hai/Scott_CostPaper.pdf.
9 Comparative Effectiveness of Screening for Methicillin-Resistant Staphylococcus aureus (MRSA). Rockville MD. Agency for Healthcare Research and Quality. 2011. www.effectivehealthcare.ahrq.gov/ehc/products/228/691/MRSAScreening_Protocol_20110602.pdf.
10 Effectiveness of Screening and Treatment of C. difficile Infections. Rockville, MD. Agency for Healthcare Research and Quality. 2010. www.effectivehealthcare.ahrq.gov/ehc/products/115/446/Cdiff_Protocol_Final.pdf.
11 Anand N, Kollef MH. The alphabet soup of pneumonia: CAP, HAP, HCAP, NHAP, and VAP. Semin Respir Crit Care Med. Feb. 2009;30(1):3-9. [pmid: 19199181].
12 CDC. Vital signs: central line--associated blood stream infections --- United States, 2001, 2008, and 2009. MMWR. 2011;60(8):243-8. [pmid: 21368740].
13 Edmonston DL, Foulkes GD. Infection rate and risk factor analysis in an orthopaedic ambulatory surgical center. J Surg Orthop Adv. Fall. 2010;19(3):174-6. [pmid: 21086932].
14 Ouslander J, Greengold B, Chen S. External catheter use and urinary tract infections among incontinent male nursing home patients. J Am Geriatr Soc. 1987;35(12):1063-70. [pmid: 3680838].
15 Guide to Infection Prevention for Outpatient Settings: Minimum Expectations for Safe Care. Atlanta, GA. Centers for Disease Control. 2011. www.cdc.gov/HAI/pdfs/guidelines/standatds-of-ambulatory-care-7-2011.pdf.
16 Anderson DJ, Kaye KS, Classen D, et al. Strategies to prevent surgical site infections in acute care hospitals. Infect Control Hosp Epidemiol. Oct. Suppl 1. 2008;29:S51-61. [pmid: 18840089].
17 Lo E, Nicolle L, Classen D, et al. Strategies to prevent catheter-associated urinary tract infections in acute care hospitals. Infect Control Hosp Epidemiol. Oct. Suppl 1. 2008;29(Supplement 1):S41-50. [pmid: 18840088].
18 Coffin SE, Klompas M, Classen D, et al. Strategies to prevent ventilator-associated pneumonia in acute care hospitals. Infect Control Hosp Epidemiol. Oct. Suppl 1. 2008;29(Supplement 1):S31-40. [pmid: 18840087].
19 Marschall J, Mermel LA, Classen D, et al. Strategies to prevent central line-associated bloodstream infections in acute care hospitals. Infect Control Hosp Epidemiol. Oct. Suppl 1. 2008;29(Supplement 1):S22-30. [pmid: 18840085].
20 Shekelle PG, Pronovost PJ, Wachter RM. Assessing the Evidence for Context-Sensitive Effectiveness and Safety of Patient Safety Practices: Developing Criteria. AHRQ Publication No. 11-0006-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2010. www.ahrq.gov/qual/contextsensitive/context.pdf.
21 Schaefer MK, Jhung M, Dahl M, et al. Infection control assessment of ambulatory surgical centers. JAMA. Jun. 9. 2010;303(22):2273-9. [pmid: 20530781].
22 Pronovost PJ, Cardo DM, Goeschel CA, et al. A research framework for reducing preventable patient harm. Clin Infect Dis. Feb. 15. 2011;52(4):507-13. [pmid: 21258104].
23 Ogrinc G, Mooney SE, Estrada C, et al. The SQUIRE (Standards for QUality Improvement Reporting Excellence) guidelines for quality improvement reporting: explanation and elaboration. Qual Saf Health Care. Oct. Suppl 1. 2008;17:i13-32. [pmid: 18836062].
24 Shekelle PG, Pronovost PJ, Wachter RM, et al. Making Health Care Safer 2012: A Critical Analysis of the Evidence for Patient Safety Practices. Prepared under Contract No. HHSA-290-2007-10062-I-EPC 3. AHRQ Publication Number ###. Rockville, MD. Agency for Healthcare Research and Quality. 2012.
25 Shekelle PG, Pronovost PJ, Wachter RM, et al. Advancing the science of patient safety. Ann Intern Med. May. 17. 2011;154(10):693-6. [pmid: 21576538].
26 Dixon-Woods M, Bosk CL, Aveling EL, et al. Explaining Michigan: developing an ex post theory of a quality improvement program. Milbank Q. Jun. 2011;89(2):167-205. [pmid: 21676020].
27 Yokoe DS, Classen D. Improving patient safety through infection control: a new healthcare imperative. Infect Control Hosp Epidemiol. 2008;29(Suppl 1):S3-11. [pmid: 18840086].
28 Grimshaw JM, Shirran L, Thomas R, et al. Changing provider behavior: an overview of systematic reviews of interventions. Med Care. Aug. 2001;39(8 Suppl 2):II2-45. [pmid: 11583120].
29 Grimshaw JM, Thomas RE, MacLennan G, et al. Effectiveness and efficiency of guideline dissemination and implementation strategies. Health Technol Assess. Feb. 2004;8(6):iii-iv. 1. 72. [pmid: 14960256].
30 O'Brien MA, Rogers S, Jamtvedt G, et al. Educational outreach visits: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. Oct. 17. 2007;(4):CD000409. [pmid: 17943742].
31 Jamtvedt G, Young JM, Kristoffersen DT, et al. Audit and feedback: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2006;(2):CD000259. [pmid: 16625533].
32 Jamal A, McKenzie K, Clark M. The impact of health information technology on the quality of medical and health care: a systematic review. HIM J. 2009;38(3):26-37. [pmid: 19875852].
33 Ramsay CR, Matowe L, Grilli R, et al. Interrupted time series designs in health technology assessment: lessons from two systematic reviews of behavior change strategies. Int J Technol Assess Health Care. Fall. 2003;19(4):613-23. [pmid: 15095767].
34 Murray DM, Varnell SP, Blitstein JL. Design and analysis of group-randomized trials: a review of recent methodological developments. Am J Public Health. Mar. 2004;94(3):423-32. [pmid: 14998806].
35 Harris AD, Bradham DD, Baumgarten M, et al. The use and interpretation of quasi-experimental studies in infectious diseases. Clinical Infect Dis. 2004;38(11):1586-91. [pmid: 15156447].
36 Shardell M, Harris AD, El-Kamary SS, et al. Statistical analysis and application of quasi experiments to antimicrobial resistance intervention studies. Clin Infect Dis. Oct. 1. 2007;45(7):901-7. [pmid: 17806059].
37 Shadish WR, Cook TD, Campbell DT. Experimental and Quasi-Experimental Designs for Generalized Causal Inference. Belmont, CA. Wadsworth Cengage Learning™. 2002.
38 Cook T, Campbell D. Quasi-experimentation: Design and analysis issues for field settings. Chicago. Rand-McNally. 1979.
39 Committee on Quality of Health Care in America IoM. To Err is Human: Building A Safer Health System. Washington, DC. National Academy Press. 1999.
40 Committee on Quality of Health Care in America IoM. Crossing the Quality Chasm: A New Health System for the 21st Century. Washington, DC. National Academy Press. 2001.
41 Wagner AK, Soumerai SB, Zhang F, et al. Segmented regression analysis of interrupted time series studies in medication use research. J Clin Pharm Ther. Aug. 2002;27(4):299-309. [pmid: 12174032].
42 Visnawathan M, Berkman N. Assessing the Risk of Bias and Precision of Observational Studies of Intervention or Exposures: Development, Validation, and Reliability Testing of the RTI Item Bank. 2010. Contract No. 2902007100561.
43 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2011. www.effectivehealthcare.ahrq.gov.
44 Owens D, Lohr K, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
45 Costello JM, Morrow DF, Graham DA, et al. Systematic intervention to reduce central line-associated bloodstream infection rates in a pediatric cardiac intensive care unit. Pediatrics. May. 2008;121(5):915-23. [pmid: 18450894].
46 Pronovost PJ, Goeschel CA, Colantuoni E, et al. Sustaining reductions in catheter related bloodstream infections in Michigan intensive care units: observational study. BMJ. 2010;340:c309. [pmid: 20133365].
47 Berenholtz SM, Pham JC, Thompson DA, et al. Collaborative cohort study of an intervention to reduce ventilator-associated pneumonia in the intensive care unit. Infect Control Hosp Epidemiol. Apr. 2011;32(4):305-14. [pmid: 21460481].
48 Barrera L, Zingg W, Mendez F, et al. Effectiveness of a hand hygiene promotion strategy using alcohol-based handrub in 6 intensive care units in Colombia. Am J Infect Control. 2011;(8):633-9. [pmid: 21636170].
49 Berenholtz SM, Pronovost PJ, Lipsett PA, et al. Eliminating catheter-related bloodstream infections in the intensive care unit. Crit Care Med. Oct. 2004;32(10):2014-20. [pmid: 15483409].
50 Cheema AA, Scott AM, Shambaugh KJ, et al. Rebound in ventilator-associated pneumonia rates during a prevention checklist washout period. BMJ Qual Saf. Sep. 2011;20(9):811-7. [pmid: 21685186].
51 Hawe CS, Ellis KS, Cairns CJ, et al. Reduction of ventilator-associated pneumonia: active versus passive guideline implementation. Intensive Care Med. Jul. 2009;35(7):1180-6. [pmid: 19308354].
52 Kritchevsky SB, Braun BI, Bush AJ, et al. The effect of a quality improvement collaborative to improve antimicrobial prophylaxis in surgical patients: a randomized trial. Ann Intern Med. Oct. 7. 2008;149(7):472-80. W89. 93. [pmid: 18838727].
53 Lilly CM, Cody S, Zhao H, et al. Hospital mortality, length of stay, and preventable complications among critically ill patients before and after tele-ICU reengineering of critical care processes. JAMA - Journal of the American Medical Association. 2011;(21):2175-83.
54 Marra AR, Cal RG, Durao MS, et al. Impact of a program to prevent central line-associated bloodstream infection in the zero tolerance era. Am J Infect Control. Aug. 2010;38(6):434-9. [pmid: 20226570].
55 Marra AR, Cal RG, Silva CV, et al. Successful prevention of ventilator-associated pneumonia in an intensive care setting. Am J Infect Control. Oct. 2009;37(8):619-25. [pmid: 19559503].
56 Morris AC, Hay AW, Swann DG, et al. Reducing ventilator-associated pneumonia in intensive care: impact of implementing a care bundle. Crit Care Med. Oct. 2011;39(10):2218-24. [pmid: 21666444].
57 Papadimos TJ, Hensley SJ, Duggan JM, et al. Implementation of the “FASTHUG” concept decreases the incidence of ventilator-associated pneumonia in a surgical intensive care unit. Patient Saf Surg. 2008;2:3. [pmid: 18271952].
58 Scales DC, Dainty K, Hales B, et al. A multifaceted intervention for quality improvement in a network of intensive care units: a cluster randomized trial. JAMA. Jan. 26. 2011;305(4):363-72. [pmid: 21248161].
59 Schulman J, Stricof R, Stevens TP, et al. Statewide NICU central-line-associated bloodstream infection rates decline after bundles and checklists. Pediatrics. Mar. 2011;127(3):436-44. [pmid: 21339265].
60 Speroff T, Ely EW, Greevy R, et al. Quality improvement projects targeting health care-associated infections: comparing virtual collaborative and toolkit approaches. J Hosp Med. May. 2011;6(5):271-8. [pmid: 21312329].
61 Khouli H, Jahnes K, Shapiro J, et al. Performance of medical residents in sterile techniques during central vein catheterization: randomized trial of efficacy of simulation-based training. Chest. Jan. 2011;139(1):80-7. [pmid: 20705795].
62 Perez Parra A, Cruz Menarguez M, Perez Granda MJ, et al. A simple educational intervention to decrease incidence of central line-associated bloodstream infection (CLABSI) in intensive care units with low baseline incidence of CLABSI. Infect Control Hosp Epidemiol. Sep. 2010;31(9):964-7. [pmid: 20658936].
63 Barsuk JH, Cohen ER, Feinglass J, et al. Use of simulation-based education to reduce catheter-related bloodstream infections. Arch Intern Med. Aug. 10. 2009;169(15):1420-3. [pmid: 19667306].
64 Apisarnthanarak A, Thongphubeth K, Yuekyen C, et al. Effectiveness of a catheter-associated bloodstream infection bundle in a Thai tertiary care center: a 3-year study. Am J Infect Control. Aug. 2010;38(6):449-55. [pmid: 20006409].
65 Miller MR, Griswold M, Harris JM 2nd, et al. Decreasing PICU catheter-associated bloodstream infections: NACHRI's quality transformation efforts. Pediatrics. Feb. 2010;125(2):206-13. [pmid: 20064860].
66 McKee C, Berkowitz I, Cosgrove SE, et al. Reduction of catheter-associated bloodstream infections in pediatric patients: experimentation and reality. Pediatr Crit Care Med. Jan. 2008;9(1):40-6. [pmid: 18477912].
67 DePalo VA, McNicoll L, Cornell M, et al. The Rhode Island ICU collaborative: a model for reducing central line-associated bloodstream infection and ventilator-associated pneumonia statewide. Qual Saf Health Care. Dec. 2010;19(6):555-61. [pmid: 21127114].
68 Zingg W, Imhof A, Maggiorini M, et al. Impact of a prevention strategy targeting hand hygiene and catheter care on the incidence of catheter-related bloodstream infections. Crit Care Med. Jul. 2009;37(7):2167-73. quiz 80. [pmid: 19487942].
69 Seguin P, Laviolle B, Isslame S, et al. Effectiveness of simple daily sensitization of physicians to the duration of central venous and urinary tract catheterization. Intensive Care Med. Jul. 2010;36(7):1202-6. [pmid: 20237761].
70 Duane TM, Brown H, Borchers CT, et al. A central venous line protocol decreases bloodstream infections and length of stay in a trauma intensive care unit population. Am Surg. Dec. 2009;75(12):1166-70. [pmid: 19999905].
71 Render ML, Hasselbeck R, Freyberg RW, et al. Reduction of central line infections in Veterans Administration intensive care units: an observational cohort using a central infrastructure to support learning and improvement. BMJ Qual Saf. Aug. 2011;20(8):725-32. [pmid: 21460392].
72 Kim JS, Holtom P, Vigen C. Reduction of catheter-related bloodstream infections through the use of a central venous line bundle: Epidemiologic and economic consequences. Am J Infect Control. 2011;(8):640-6. [pmid: 21641088].
73 Taylor T, Massaro A, Williams L, et al. Effect of a dedicated percutaneously inserted central catheter team on neonatal catheter-related bloodstream infection. Adv Neonatal Care. Apr. 2011;11(2):122-8. [pmid: 21730901].
74 Harris BD, Hanson C, Christy C, et al. Strict hand hygiene and other practices shortened stays and cut costs and mortality in a pediatric intensive care unit. Health Aff (Millwood). Sep. 2011;30(9):1751-61. [pmid: 21900667].
75 Burrell AR, McLaws ML, Murgo M, et al. Aseptic insertion of central venous lines to reduce bacteraemia. Med J Aust. Jun. 6. 2011;194(11):583-7. [pmid: 21644871].
76 Frankel HL, Crede WB, Topal JE, et al. Use of corporate Six Sigma performance-improvement strategies to reduce incidence of catheter-related bloodstream infections in a surgical ICU. J Am Coll Surg. Sep. 2005;201(3):349-58. [pmid: 16125067].
77 Wall RJ, Ely EW, Elasy TA, et al. Using real time process measurements to reduce catheter related bloodstream infections in the intensive care unit. Qual Saf Health Care. Aug. 2005;14(4):295-302. [pmid: 16076796].
78 Yoo S, Ha M, Choi D, et al. Effectiveness of surveillance of central catheter-related bloodstream infection in an ICU in Korea. Infect Control Hosp Epidemiol. Jul. 2001;22(7):433-6. [pmid: 11583212].
79 Lobo RD, Levin AS, Oliveira MS, et al. Evaluation of interventions to reduce catheter-associated bloodstream infection: continuous tailored education versus one basic lecture. Am J Infect Control. Aug. 2010;38(6):440-8. [pmid: 20123149].
80 Venkatram S, Rachmale S, Kanna B. Study of device use adjusted rates in health care-associated infections after implementation of “bundles” in a closed-model medical intensive care unit. J Crit Care. 2010;25(1):174.e11-8. [pmid: 19682846].
81 Shannon RP, Frndak D, Grunden N, et al. Using real-time problem solving to eliminate central line infections. Jt Comm J Qual Patient Saf. Sep. 2006;32(9):479-87. [pmid: 17987871].
82 Assanasen S, Edmond M, Bearman G. Impact of 2 different levels of performance feedback on compliance with infection control process measures in 2 intensive care units. Am J Infect Control. Aug. 2008;36(6):407-13. [pmid: 18675146].
83 Warren DK, Cosgrove SE, Diekema DJ, et al. A multicenter intervention to prevent catheter-associated bloodstream infections. Infect Control Hosp Epidemiol. Jul. 2006;27(7):662-9. [pmid: 16807839].
84 Koll BS, Straub TA, Jalon HS, et al. The CLABs collaborative: a regionwide effort to improve the quality of care in hospitals. Jt Comm J Qual Patient Saf. Dec. 2008;34(12):713-23. [pmid: 19119725].
85 Wicker L, Saslow J, Shah S, et al. The effect of comprehensive infection control measures on the rate of late-onset bloodstream infections in very low-birth-weight infants. Am J Perinatol. 2011;28(3):227-32. [pmid: 20981639].
86 Bizzarro MJ, Sabo B, Noonan M, et al. A quality improvement initiative to reduce central line-associated bloodstream infections in a neonatal intensive care unit. Infect Control Hosp Epidemiol. Mar. 2010;31(3):241-8. [pmid: 20102278].
87 Yilmaz G, Caylan R, Aydin K, et al. Effect of education on the rate of and the understanding of risk factors for intravascular catheter-related infections. Infect Control Hosp Epidemiol. Jun. 2007;28(6):689-94. [pmid: 17520542].
88 Sannoh S, Clones B, Munoz J, et al. A multimodal approach to central venous catheter hub care can decrease catheter-related bloodstream infection. Am J Infect Control. Aug. 2010;38(6):424-9. [pmid: 20137829].
89 Gurskis V, Asembergiene J, Kevalas R, et al. Reduction of nosocomial infections and mortality attributable to nosocomial infections in pediatric intensive care units in Lithuania. Medicina (Kaunas). 2009;45(3):203-13. [pmid: 19357450].
90 Santana SL, Furtado GH, Wey SB, et al. Impact of an education program on the incidence of central line-associated bloodstream infection in 2 medical-surgical intensive care units in Brazil. Infect Control Hosp Epidemiol. Dec. 2008;29(12):1171-3. [pmid: 18956978].
91 Rogers E, Alderdice F, McCall E, et al. Reducing nosocomial infections in neonatal intensive care. J Matern Fetal Neonatal Med. Sep. 2010;23(9):1039-46. [pmid: 20718580].
92 Guerin K, Wagner J, Rains K, et al. Reduction in central line-associated bloodstream infections by implementation of a postinsertion care bundle. Am J Infect Control. Aug. 2010;38(6):430-3. [pmid: 20570395].
93 Jeffries HE, Mason W, Brewer M, et al. Prevention of central venous catheter-associated bloodstream infections in pediatric intensive care units: a performance improvement collaborative. Infect Control Hosp Epidemiol. Jul. 2009;30(7):645-51. [pmid: 19496731].
94 Berriel-Cass D, Adkins FW, Jones P, et al. Eliminating nosocomial infections at Ascension Health. Jt Comm J Qual Patient Saf. Nov. 2006;32(11):612-20. [pmid: 17120920].
95 Bhutta A, Gilliam C, Honeycutt M, et al. Reduction of bloodstream infections associated with catheters in paediatric intensive care unit: stepwise approach. BMJ. Feb. 17. 2007;334(7589):362-5. [pmid: 17303886].
96 Galpern D, Guerrero A, Tu A, et al. Effectiveness of a central line bundle campaign on line-associated infections in the intensive care unit. Surgery. Oct. 2008;144(4):492-5. discussion 5. [pmid: 18847630].
97 Jain M, Miller L, Belt D, et al. Decline in ICU adverse events, nosocomial infections and cost through a quality improvement initiative focusing on teamwork and culture change. Qual Saf Health Care. 2006;15(4):235-9. [pmid: 16885246].
98 Render ML, Brungs S, Kotagal U, et al. Evidence-based practice to reduce central line infections. Jt Comm J Qual Patient Saf. May. 2006;32(5):253-60. [pmid: 16761789].
99 McHugh SM, Corrigan MA, Dimitrov BD, et al. Preventing infection in general surgery: improvements through education of surgeons by surgeons. J Hosp Infect. Aug. 2011;(4):312-6. [pmid: 21640433].
100 Gozu A, Clay C, Younus F. Hospital-wide reduction in central line-associated bloodstream infections: a tale of two small community hospitals. Infect Control Hosp Epidemiol. Jun. 2011;32(6):619-22. [pmid: 21558777].
101 Lopez AC. A quality improvement program combining maximal barrier precaution compliance monitoring and daily chlorhexidine gluconate baths resulting in decreased central line bloodstream infections. Dimens Crit Care Nurs. Sep-Oct. 2011;30(5):293-8. [pmid: 21841426].
102 Cherry RA, West CE, Hamilton MC, et al. Reduction of central venous catheter associated blood stream infections following implementation of a resident oversight and credentialing policy. Patient Saf Surg. 2011;5(1):15. [pmid: 21639916].
103 Garcia-Vazquez E, Murcia-Paya J, Canteras M, et al. Influence of a hygiene promotion programme on infection control in an intensive-care unit. Clin Microbiol Infect. Jun. 2011;17(6):894-900. [pmid: 21040160].
104 Bakke CK. Clinical and cost effectiveness of guidelines to prevent intravascular catheter-related infections in patients on hemodialysis. Nephrol Nurs J. Nov-Dec. 2010;37(6):601-15. quiz 16. [pmid: 21290915].
105 Miller MR, Niedner MF, Huskins WC, et al. Reducing PICU central line-associated bloodstream infections: 3-year results. Pediatrics. Nov. 2011;128(5):e1077-83. [pmid: 22025594].
106 Kim DH, Spencer M, Davidson SM, et al. Institutional prescreening for detection and eradication of methicillin-resistant Staphylococcus aureus in patients undergoing elective orthopaedic surgery. J Bone Joint Surg Am. Aug. 4. 2010;92(9):1820-6. [pmid: 20610773].
107 Zaydfudim V, Dossett LA, Starmer JM, et al. Implementation of a real-time compliance dashboard to help reduce SICU ventilator-associated pneumonia with the ventilator bundle. Arch Surg. Jul. 2009;144(7):656-62. [pmid: 19620546].
108 Apisarnthanarak A, Pinitchai U, Thongphubeth K, et al. Effectiveness of an educational program to reduce ventilator-associated pneumonia in a tertiary care center in Thailand: a 4-year study. Clin Infect Dis. Sep. 15. 2007;45(6):704-11. [pmid: 17712753].
109 Bouadma L, Deslandes E, Lolom I, et al. Long-term impact of a multifaceted prevention program on ventilator-associated pneumonia in a medical intensive care unit. Clin Infect Dis. Nov. 15. 2010;51(10):1115-22. [pmid: 20936973].
110 Prospero E, Bacelli S, Barbadoro P, et al. Improvement of the ventilator associated pneumonia rate with infection control practices in an Italian ICU. Minerva Anestesiol. Oct. 2008;74(10):537-41. [pmid: 18854795].
111 Omrane R, Eid J, Perreault MM, et al. Impact of a protocol for prevention of ventilator-associated pneumonia. Ann Pharmacother. Sep. 2007;41(9):1390-6. [pmid: 17698898].
112 Dubose J, Teixeira PGR, Inaba K, et al. Measurable outcomes of quality improvement using a daily quality rounds checklist: One-year analysis in a trauma intensive care unit with sustained ventilator-associated pneumonia reduction. J Trauma. 2010;69(4):855-60. [pmid: 20032792].
113 Kulvatunyou N, Boonbarwornrattanakul A, Soonthornkit Y, et al. Incidence of ventilator-associated pneumonia (VAP) after the institution of an educational program on VAP prevention. J Med Assoc Thai. Jan. 2007;90(1):89-95. [pmid: 17621738].
114 Bigham MT, Amato R, Bondurrant P, et al. Ventilator-associated pneumonia in the pediatric intensive care unit: characterizing the problem and implementing a sustainable solution. J Pediatr. Apr. 2009;154(4):582-7 e2. [pmid: 19054530].
115 Sona CS, Zack JE, Schallom ME, et al. The impact of a simple, low-cost oral care protocol on ventilator-associated pneumonia rates in a surgical intensive care unit. J Intensive Care Med. Jan-Feb. 2009;24(1):54-62. [pmid: 19017665].
116 Garcia R, Jendresky L, Colbert L, et al. Reducing ventilator-associated pneumonia through advanced oral-dental care: a 48-month study. Am J Crit Care. Nov. 2009;18(6):523-32. [pmid: 19635805].
117 Rosenthal VD, Guzman S, Crnich C. Impact of an infection control program on rates of ventilator-associated pneumonia in intensive care units in 2 Argentinean hospitals. Am J Infect Control. Mar. 2006;34(2):58-63. [pmid: 16490607].
118 Landrum ML, Murray CK. Ventilator associated pneumonia in a military deployed setting: the impact of an aggressive infection control program. J Trauma. Feb. 2008;64(2 Suppl):S123-7. discussion S7-8. [pmid: 18376154].
119 Heimes J, Braxton C, Nazir N, et al. Implementation and enforcement of ventilator-associated pneumonia prevention strategies in trauma patients. Surg Infect (Larchmt). Apr. 2011;12(2):99-103. [pmid: 21348766].
120 Quenot JP, Ladoire S, Devoucoux F, et al. Effect of a nurse-implemented sedation protocol on the incidence of ventilator-associated pneumonia. Crit Care Med. Sep. 2007;35(9):2031-6. [pmid: 17855817].
121 Bloos F, Muller S, Harz A, et al. Effects of staff training on the care of mechanically ventilated patients: a prospective cohort study. Br J Anaesth. Aug. 2009;103(2):232-7. [pmid: 19457893].
122 Jimenez L, Pastrana EA, Rodriguez-Vega G, et al. Ventilator bundle compliance: Report from a neurosurgical intensive care unit. Crit Care Shock. 2009;12(3):109-16.
123 Ross A, Crumpler J. The impact of an evidence-based practice education program on the role of oral care in the prevention of ventilator-associated pneumonia. Intensive Crit Care Nurs. Jun. 2007;23(3):132-6. [pmid: 17204424].
124 Abbott CA, Dremsa T, Stewart DW, et al. Adoption of a ventilator-associated pneumonia clinical practice guideline. Worldviews Evid Based Nurs. 2006;3(4):139-52. [pmid: 17177928].
125 Bird D, Zambuto A, O'Donnell C, et al. Adherence to ventilator-associated pneumonia bundle and incidence of ventilator-associated pneumonia in the surgical intensive care unit. Arch Surg. May. 2010;145(5):465-70. [pmid: 20479345].
126 Blamoun J, Alfakir M, Rella ME, et al. Efficacy of an expanded ventilator bundle for the reduction of ventilator-associated pneumonia in the medical intensive care unit. Am J Infect Control. Mar. 2009;37(2):172-5. [pmid: 18945515].
127 Cocanour CS, Peninger M, Domonoske BD, et al. Decreasing ventilator-associated pneumonia in a trauma ICU. J Trauma. Jul. 2006;61(1):122-9. discussion 9-30. [pmid: 16832259].
128 Rosenthal VD, Alvarez-Moreno C, Villamil-Gomez W, et al. Effectiveness of a multidimensional approach to reduce ventilator-associated pneumonia in pediatric intensive care units of 5 developing countries: International Nosocomial Infection Control Consortium findings. Am J Infect Control. 2011. Nov. 2. [pmid: 22054689].
129 Stone ME Jr, Snetman D, et al. Daily multidisciplinary rounds to implement the ventilator bundle decreases ventilator-associated pneumonia in trauma patients: but does it affect outcome?. Surg Infect (Larchmt). Oct. 2011;(5):373-8. [pmid: 21933008].
130 Ban KO. The effectiveness of an evidence-based nursing care program to reduce ventilator-associated pneumonia in a Korean ICU. Intensive Crit Care Nurs. Aug. 2011;27(4):226-32. [pmid: 21680186].
131 Kastrup M, Nolting MJ, Ahlborn R, et al. An electronic tool for visual feedback to monitor the adherence to quality indicators in intensive care medicine. J Int Med Res. 2011;39(6):2187-200. [pmid: 22289534].
132 Bouadma L, Mourvillier B, Deiler V, et al. A multifaceted program to prevent ventilator-associated pneumonia: impact on compliance with preventive measures. Crit Care Med. Mar. 2010;38(3):789-96. [pmid: 20068461].
133 Zanetti G, Flanagan HL Jr., Cohn LH, et al. Improvement of intraoperative antibiotic prophylaxis in prolonged cardiac surgery by automated alerts in the operating room. Infect Control Hosp Epidemiol. Jan. 2003;24(1):13-6. [pmid: 12558230].
134 Gastmeier P, Brauer H, Forster D, et al. A quality management project in 8 selected hospitals to reduce nosocomial infections: a prospective, controlled study. Infect Control Hosp Epidemiol. Feb. 2002;23(2):91-7. [pmid: 11893154].
135 Greco D, Moro ML, Tozzi AE, et al. Effectiveness of an intervention program in reducing postoperative infections. Italian PRINOS Study Group. Am J Med. Sep. 16. 1991;91(3B):164S-9S. [pmid: 1928159].
136 Dellinger EP, Hausmann SM, Bratzler DW, et al. Hospitals collaborate to decrease surgical site infections. Am J Surg. Jul. 2005;190(1):9-15. [pmid: 15972163].
137 Kao LS, Lew DF, Doyle PD, et al. A tale of 2 hospitals: a staggered cohort study of targeted interventions to improve compliance with antibiotic prophylaxis guidelines. Surgery. Aug. 2010;148(2):255-62. [pmid: 20494387].
138 Mannien J, van Kasteren ME, Nagelkerke NJ, et al. Effect of optimized antibiotic prophylaxis on the incidence of surgical site infection. Infect Control Hosp Epidemiol. Dec. 2006;27(12):1340-6. [pmid: 17152032].
139 Burkitt KH, Mor MK, Jain R, et al. Toyota production system quality improvement initiative improves perioperative antibiotic therapy. Am J Manag Care. Sep. 2009;15(9):633-42. [pmid: 19747028].
140 Hedrick TL, Turrentine FE, Smith RL, et al. Single-institutional experience with the surgical infection prevention project in intra-abdominal surgery. Surg Infect (Larchmt). Aug. 2007;8(4):425-35. [pmid: 17883359].
141 Kaimal AJ, Zlatnik MG, Cheng YW, et al. Effect of a change in policy regarding the timing of prophylactic antibiotics on the rate of postcesarean delivery surgical-site infections. Am J Obstet Gynecol. Sep. 2008;199(3):310 e1-5. [pmid: 18771995].
142 Trussell J, Gerkin R, Coates B, et al. Impact of a patient care pathway protocol on surgical site infection rates in cardiothoracic surgery patients. Am J Surg. Dec. 2008;196(6):883-9. discussion 9. [pmid: 19095104].
143 Schwann NM, Bretz KA, Eid S, et al. Point-of-care electronic prompts: an effective means of increasing compliance, demonstrating quality, and improving outcome. Anesth Analg. Oct. 2011;113(4):869-76. [pmid: 21788319].
144 Kestle JR, Riva-Cambrin J, Wellons JC 3rd, et al. A standardized protocol to reduce cerebrospinal fluid shunt infection: the Hydrocephalus Clinical Research Network Quality Improvement Initiative. J Neurosurg Pediatr. Jul. 2011;8(1):22-9. [pmid: 21721884].
145 Salim R, Braverman M, Berkovic I, et al. Effect of interventions in reducing the rate of infection after cesarean delivery. Am J Infect Control. Dec. 2011;39(10):e73-8. [pmid: 21835505].
146 Lavu H, Klinge MJ, Nowcid LJ, et al. Perioperative Surgical Care Bundle Reduces Pancreaticoduodenectomy Wound Infections. J Surg Res. 2011. Oct. 11. [pmid: 22036201].
147 Wax DB, Beilin Y, Levin M, et al. The effect of an interactive visual reminder in an anesthesia information management system on timeliness of prophylactic antibiotic administration. Anesth Analg. Jun. 2007;104(6):1462-6. table of contents. [pmid: 17513642].
148 Gomez MI, Acosta-Gnass SI, Mosqueda-Barboza L, et al. Reduction in surgical antibiotic prophylaxis expenditure and the rate of surgical site infection by means of a protocol that controls the use of prophylaxis. Infect Control Hosp Epidemiol. Dec. 2006;27(12):1358-65. [pmid: 17152035].
149 Graf K, Sohr D, Haverich A, et al. Decrease of deep sternal surgical site infection rates after cardiac surgery by a comprehensive infection control program. Interact Cardiovasc Thorac Surg. Aug. 2009;9(2):282-6. [pmid: 19416962].
150 Takahashi Y, Takesue Y, Nakajima K, et al. Implementation of a hospital-wide project for appropriate antimicrobial prophylaxis. J Infect Chemother. Dec. 2010;16(6):418-23. [pmid: 20549286].
151 Kramer R, Groom R, Weldner D, et al. Glycemic control and reduction of deep sternal wound infection rates: a multidisciplinary approach. Arch Surg. May. 2008;143(5):451-6. [pmid: 18490552].
152 Liau KH, Aung KT, Chua N, et al. Outcome of a strategy to reduce surgical site infection in a tertiary-care hospital. Surg Infect (Larchmt). Apr. 2010;11(2):151-9. [pmid: 20201687].
153 Parker BM, Henderson JM, Vitagliano S, et al. Six sigma methodology can be used to improve adherence for antibiotic prophylaxis in patients undergoing noncardiac surgery. Anesth Analg. Jan. 2007;104(1):140-6. [pmid: 17179259].
154 Suchitra JB, Lakshmidevi N. Hospital-acquired infections: Are prevention strategies matching incidence rates?. Healthcare Infection. 2009;14(1):21-5.
155 Shimoni Z, Kama N, Mamet Y, et al. Empowering surgical nurses improves compliance rates for antibiotic prophylaxis after caesarean birth. J Adv Nurs. Nov. 2009;65(11):2345-9. [pmid: 19761458].
156 Ichikawa S, Ishihara M, Okazaki T, et al. Prospective study of antibiotic protocols for managing surgical site infections in children. J Pediatr Surg. Jun. 2007;42(6):1002-7. discussion 7. [pmid: 17560210].
157 Whitman G, Cowell V, Parris K, et al. Prophylactic antibiotic use: hardwiring of physician behavior, not education, leads to compliance. J Am Coll Surg. Jul. 2008;207(1):88-94. [pmid: 18589367].
158 Potenza B, Deligencia M, Estigoy B, et al. Lessons learned from the institution of the Surgical Care Improvement Project at a teaching medical center. Am J Surg. Dec. 2009;198(6):881-8. [pmid: 19969146].
159 Kable A, Gibberd R, Spigelman A. Measuring compliance with surgical antibiotic protocols: An intervention. Clin Govern. 2008;13(4):296-304.
160 Rauk PN. Educational intervention, revised instrument sterilization methods, and comprehensive preoperative skin preparation protocol reduce cesarean section surgical site infections. Am J Infect Control. 2010;38(4):319-23. [pmid: 20171756].
161 Ozgun H, Ertugrul BM, Soyder A, et al. Peri-operative antibiotic prophylaxis: adherence to guidelines and effects of educational intervention. Int J Surg. 2010;8(2):159-63. [pmid: 20026001].
162 Pastor C, Artinyan A, Varma MG, et al. An increase in compliance with the Surgical Care Improvement Project measures does not prevent surgical site infection in colorectal surgery. Dis Colon Rectum. Jan. 2010;53(1):24-30. [pmid: 20010346].
163 Carles M, Gindre S, Aknouch N, et al. Improvement of surgical antibiotic prophylaxis: a prospective evaluation of personalized antibiotic kits. J Hosp Infect. Mar. 2006;62(3):372-5. [pmid: 16337311].
164 Acklin YP, Widmer AF, Renner RM, et al. Unexpectedly increased rate of surgical site infections following implant surgery for hip fractures: problem solution with the bundle approach. Injury. Feb. 2011;42(2):209-16. [pmid: 21047637].
165 Willemsen I, van den Broek R, Bijsterveldt T, et al. A standardized protocol for perioperative antibiotic prophylaxis is associated with improvement of timing and reduction of costs. J Hosp Infect. 2007;67(2):156-60. [pmid: 17881087].
166 Nemeth TA, Beilman GJ, Hamlin CL, et al. Preoperative verification of timely antimicrobial prophylaxis does not improve compliance with guidelines. Surg Infect (Larchmt). Aug. 2010;11(4):387-91. [pmid: 20662740].
167 Berry SA, Doll MC, McKinley KE, et al. ProvenCare: quality improvement model for designing highly reliable care in cardiac surgery. Qual Saf Health Care. Oct. 2009;18(5):360-8. [pmid: 19812098].
168 Forbes SS, Stephen WJ, Harper WL, et al. Implementation of evidence-based practices for surgical site infection prophylaxis: results of a pre- and postintervention study. J Am Coll Surg. Sep. 2008;207(3):336-41. [pmid: 18722937].
169 Berenguer CM, Ochsner MG Jr, Lord SA, et al. Improving Surgical Site Infections: Using National Surgical Quality Improvement Program Data to Institute Surgical Care Improvement Project Protocols in Improving Surgical Outcomes. J Am Coll Surg. 2010;210(5):737-41. [pmid: 20421041].
170 Awad SS, Palacio CH, Subramanian A, et al. Implementation of a methicillin-resistant Staphylococcus aureus (MRSA) prevention bundle results in decreased MRSA surgical site infections. Am J Surg. Nov. 2009;198(5):607-10. [pmid: 19887186].
171 Paull DE, Mazzia LM, Wood SD, et al. Briefing guide study: preoperative briefing and postoperative debriefing checklists in the Veterans Health Administration medical team training program. Am J Surg. Nov. 2010;200(5):620-3. [pmid: 21056140].
172 Zvonar RK, Bush P, Roth V. Practice changes to improve delivery of surgical antibiotic prophylaxis. Healthc Q. 2008;11(3 Spec No.):141-4. [pmid: 18382176].
173 Hermsen ED, Smith Shull S, Puumala SE, et al. Improvement in prescribing habits and economic outcomes associated with the introduction of a standardized approach for surgical antimicrobial prophylaxis. Infect Control Hosp Epidemiol. May. 2008;29(5):457-61. [pmid: 18419372].
174 Bull A, Wilson J, Worth LJ, et al. A bundle of care to reduce colorectal surgical infections: an Australian experience. J Hosp Infect. Aug. 2011;78(4):297-301. [pmid: 21664720].
175 Sewell M, Adebibe M, Jayakumar P, et al. Use of the WHO surgical safety checklist in trauma and orthopaedic patients. Int Orthop. Jun. 2011;(6):897-901. [pmid: 20730425].
176 Sun TB, Chao SF, Chang BS, et al. Quality improvements of antimicrobial prophylaxis in coronary artery bypass grafting. J Surg Res. May. 15. 2011;167(2):329-35. [pmid: 19922949].
177 Barchitta M, Matranga D, Quattrocchi A, et al. Prevalence of surgical site infections before and after the implementation of a multimodal infection control programme. J Antimicrob Chemother. 2011. Nov. 29.
178 Lingard L, Regehr G, Cartmill C, et al. Evaluation of a preoperative team briefing: a new communication routine results in improved clinical practice. BMJ Qual Saf. Jun. 2011;20(6):475-82. [pmid: 21303767].
179 van Kasteren ME, Mannien J, Kullberg BJ, et al. Quality improvement of surgical prophylaxis in Dutch hospitals: evaluation of a multi-site intervention by time series analysis. J Antimicrob Chemother. 2005;56(6):1094-102. [pmid: 16234334].
180 Hedrick TL, Heckman JA, Smith RL, et al. Efficacy of protocol implementation on incidence of wound infection in colorectal operations. J Am Coll Surg. Sep. 2007;205(3):432-8. [pmid: 17765159].
181 Marra AR, Sampaio Camargo TZ, Goncalves P, et al. Preventing catheter-associated urinary tract infection in the zero-tolerance era. Am J Infect Control. Dec. 2011;39(10):817-22. [pmid: 21704427].
182 Loeb M, Hunt D, O'Halloran K, et al. Stop orders to reduce inappropriate urinary catheterization in hospitalized patients: a randomized controlled trial. J Gen Intern Med. Jun. 2008;23(6):816-20. [pmid: 18421507].
183 Apisarnthanarak A, Thongphubeth K, Sirinvaravong S, et al. Effectiveness of multifaceted hospitalwide quality improvement programs featuring an intervention to remove unnecessary urinary catheters at a tertiary care center in Thailand. Infect Control Hosp Epidemiol. Jul. 2007;28(7):791-8. [pmid: 17564980].
184 Crouzet J, Bertrand X, Venier AG, et al. Control of the duration of urinary catheterization: impact on catheter-associated urinary tract infection. J Hosp Infect. Nov. 2007;67(3):253-7. [pmid: 17949851].
185 Saint S, Kaufman SR, Thompson M, et al. A reminder reduces urinary catheterization in hospitalized patients. Jt Comm J Qual Patient Saf. Aug. 2005;31(8):455-62. [pmid: 16156193].
186 Van Den Broek PJ, Wille JC, Van Benthem BH, et al. Urethral catheters: can we reduce use?. BMC Urol. 2011;10.
187 Fakih MG, Watson SR, Greene MT, et al. Reducing Inappropriate Urinary Catheter Use: A Statewide Effort. Arch Intern Med. 2012. Jan. 9.
188 Gokula RM, Smith MA, Hickner J. Emergency room staff education and use of a urinary catheter indication sheet improves appropriate use of foley catheters. Am J Infect Control. 2007;35(9):589-93. [pmid: 17980237].
189 Rothfeld AF, Stickley A. A program to limit urinary catheter use at an acute care hospital. Am J Infect Control. 2010;38(7):568-71. [pmid: 20381918].
190 Wald HL, Kramer AM. Feasibility of audit and feedback to reduce postoperative urinary catheter duration. J Hosp Med. Apr. 2011;6(4):183-9. [pmid: 21480488].
191 Stéphan F, Sax H, Wachsmuth M, et al. Reduction of urinary tract infection and antibiotic use after surgery: A controlled, prospective, before-after intervention study. Clin Infect Dis. 2006;42(11):1544-51. [pmid: 16652311].
192 Wright MO, Kharasch M, Beaumont JL, et al. Reporting catheter-associated urinary tract infections: denominator matters. Infect Control Hosp Epidemiol. Jul. 2011;32(7):635-40. [pmid: 21666391].
193 Knoll BM, Wright D, Ellingson L, et al. Reduction of inappropriate urinary catheter use at a Veterans Affairs hospital through a multifaceted quality improvement project. Clin Infect Dis. Jun. 2011;(11):1283-90. [pmid: 21596671].
194 Titsworth WL, Hester J, Correia T, et al. Reduction of catheter-associated urinary tract infections among patients in a neurological intensive care unit: a single institution's success. J Neurosurg. 2012. Jan. 6.
195 Dyc NG, Pena ME, Shemes SP, et al. The effect of resident peer-to-peer education on compliance with urinary catheter placement indications in the emergency department. Postgrad Med J. Dec. 2011;87(1034):814-8. [pmid: 22039221].
196 Oman KS, Makic MB, Fink R, et al. Nurse-directed interventions to reduce catheter-associated urinary tract infections. Am J Infect Control. 2011. Nov. 1. [pmid: 22047997].
197 Biese K, Lamantia M, Zamora Z, et al. Impact of a geriatric curriculum on emergency medicine resident attitudes, knowledge, and decision-making. Academic Emergency Medicine. 2011;(5):S98.
198 Fuchs MA, Sexton DJ, Thornlow DK, et al. Evaluation of an evidence-based, nurse-driven checklist to prevent hospital-acquired catheter-associated urinary tract infections in intensive care units. J Nurs Care Qual. Apr-Jun. 2011;26(2):101-9. [pmid: 21037484].
199 Waters HR, Korn R Jr., Colantuoni E, et al. The business case for quality: economic analysis of the Michigan Keystone Patient Safety Program in ICUs. Am J Med Qual. Sep-Oct. 2011;26(5):333-9. [pmid: 21856956].
200 Shojania KG, Jennings A, Mayhew A, et al. The effects of on-screen, point of care computer reminders on processes and outcomes of care. Cochrane Database Syst Rev. 2009;(3):CD001096. [pmid: 19588323].
201 Kaplan HC, Brady PW, Dritz MC, et al. The influence of context on quality improvement success in health care: a systematic review of the literature. Milbank Q. Dec. 2010;88(4):500-59. [pmid: 21166868].
202 Scott I. What are the most effective strategies for improving quality and safety of health care?. Intern Med J. Jun. 2009;39(6):389-400. [pmid: 19580618].
203 de Vos M, Graafmans W, Kooistra M, et al. Using quality indicators to improve hospital care: a review of the literature. Int J Qual Health Care. Apr. 2009;21(2):119-29. [pmid: 19155288].
204 Meddings J, Rogers MA, Macy M, et al. Systematic review and meta-analysis: reminder systems to reduce catheter-associated urinary tract infections and urinary catheter use in hospitalized patients. Clin Infect Dis. Sep. 1. 2010;51(5):550-60. [pmid: 20673003].