# Introduction

## Background

In 2003, the Institute of Medicine (IOM) published a report, Priority Areas for National Action: Transforming Health Care Quality.1 The report identified 20 clinical topics for which there are quality concerns because of the gap between knowledge of the topic and integration of that knowledge into the clinical setting. In response to the IOM report, the Agency for Healthcare Research and Quality (AHRQ) initiated a series of technical reviews on quality improvement (QI) strategies focused on improving the quality of care for the IOM's 20 priority areas.2 The current systematic review serves to update and expand the 2007 Evidence Report, Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Volume 6: Prevention of Healthcare-Associated Infections.3

### Healthcare-Associated Infections

The Centers for Disease Control and Prevention (CDC) define a healthcare-associated infection (HAI) as “[A] localized or systemic condition resulting from an adverse reaction to the presence of an infectious agent(s) or its toxin(s). There must be no evidence that the infection was present or incubating at the time of admission to the acute care setting.”4 The CDC estimates that in 2002, there were 1.7 million HAI and 99,000 HAI-associated deaths in hospitals. The four largest categories of HAI, responsible for over 80 percent of all reported HAI, are central line-associated bloodstream infections (CLABSI; 14%), ventilator-associated pneumonia (VAP; 15%), surgical site infections (SSI; 22%), and catheter-associated urinary tract infections (CAUTI; 32%).5

The most recent national HAI data available are on CLABSI and SSI, reported by the National Healthcare Safety Network (NHSN), a public health surveillance system established in 2005 by the CDC's Division of Healthcare Quality Promotion (DHQP). Twenty-two states and the District of Columbia have required or have plans to require their health care facilities to report HAI to the NHSN; CLABSI and SSI are the infections most frequently mandated by these states for reporting. In a current report, the NHSN provides Standardized Infection Ratios (SIR) for CLABSI and SSI nationally and by state, for January 2009 to December 2009. The SIR measures the relative difference in HAI occurrence during a reporting period compared with a referent period. The referent period for this report is January 2006 through December 2008. For 2009, the CLABSI SIR is 0.83, which translates to a 17 percent national reduction compared with the referent period, and the SSI SIR is 0.92, for a national reduction in incidence of 8 percent. However, facility-specific SIRs for both infections showed great variability, with some facilities showing progress in their preventive efforts, while other facilities demonstrated increasing rates.6

### Burden of Healthcare-Associated Infections

According to the CDC, about one in four patients acquiring a bloodstream infection from the insertion of a central line dies (www.cdc.gov/VitalSigns/HAI/index.html). Identifying more effective ways to treat these patients is essential, but far better to prevent the infections in the first place. The prevention and reduction of HAI is a top priority for the United States Department of Health and Human Services (www.cdc.gov/HAI/prevent/prevention.html). A call to action for the elimination of HAI has been issued jointly by the Association for Professionals in Infection Control and Epidemiology, Inc., the Society for Healthcare Epidemiology of America, the Infectious Diseases Society of America, the Association of State and Territorial Health Officials, the Council of State and Territorial Epidemiologists, the Pediatric Infectious Diseases Society, and the CDC.7 In a consensus statement issued by these groups, a plan for the elimination of HAI includes the promotion of adherence to evidence-based practices through partnering, educating, implementing, and investing.

In a CDC report, national costs of HAI were estimated, based on 2002 infection rates and adjusted to 2007 dollars using the Consumer Price Index (CPI) for inpatient hospital services. Estimates of the annual direct medical costs of HAI for U.S. hospitals ranged from $35.7 billion to $45 billion. Using the same adjustment, the estimates of patient hospital costs for the four most common HAI ranged from $3.45 billion to $10.07 billion for SSI, $0.67 billion to $2.68 billion for CLABSI, $1.03 billion to $1.50 billion for VAP, and $0.39 billion to $0.45 billion for CAUTI.8 It is estimated that the cost savings of preventing 70 percent of HAI would be $25.0 billion to $31.5 billion, using the same adjustment.8

### 2007 Technical Assessment of Prevention of Healthcare-Associated Infections

The objective of the 2007 report was to identify quality improvement (QI) strategies that successfully increased adherence to effective preventive interventions and reduce infection rates for the following healthcare-associated infections:

- Central line-associated bloodstream infection (CLABSI)
- Ventilator-associated pneumonia (VAP)
- Surgical site infection (SSI)
- Catheter-associated urinary tract infection (CAUTI)

The QI strategies included in this review were those identified in the first volume of the Closing the Quality Gap series (Table 1).3 Authors of this report concluded that there were no QI strategies that effectively decreased the rate of SSI, although some did increase adherence to preventive interventions. Two studies reported lower CLABSI rates when an explicit checklist was implemented, empowering nurses to stop procedures until preventive interventions were used. The assessment concluded that several QI strategies, provider education and printed or computer-based reminder systems, were worthy of further study and possibly wider implementation, and that higher quality studies on implementation strategies were needed In many instances, the authors were unable to reach firm conclusions, because of the uncertainty associated with single-center and simple before-after studies.3

Table 1 Quality improvement strategies from 2007 report3

QI Strategy | Examples
Provider reminder systems | Reminders in charts for providers Computer based reminders for providers Computer based decision support
Facilitated relay of clinical data to providers | Transmission of clinical data from outpatient specialty clinic to primary care provider by means other than medical record, e.g., phone call or fax
Audit and feedback | Feedback of performance to individual providers Quality indicators and reports National/state quality report cards Publicly released performance data Benchmarking – provision of outcomes data from top performers for comparison with provider's own data
Provider education | Workshops and conferences Education outreach visits (e.g., academic detailing) Distribution of education materials
Patient education | Classes Parent and family education Patient pamphlets Intensive education strategies promoting self-management of chronic conditions
Promotion of self-management | Materials and devices to promote self-management
Patient reminder systems | Postcards or calls to patients
Organizational change | Case management, disease management Total quality management, cycles of quality improvement Multidisciplinary teams Change from paper to computer based records Increased staffing Skill mix changes
Financial incentives, regulation, and policy | Provider Directed: Financial incentives based on achievement of performance goals Alternative reimbursement systems (e.g., fee for service, capitated payments) Licensure requirements Patient Directed: Copayments for certain visit types Health insurance premiums, user fees Health System Directed: Initiatives by accreditation bodies (e.g., residency work hour limits) Changes in reimbursement schemes (e.g., capitation, prospective payment, salaried providers)

### Current Review Modifications

In planning the current evidence review, the continued relevance of the topic was assessed, as well as whether changes in scope were warranted. Given the continued prevalence of these infections, despite efforts to reduce them, the topic remains relevant. Many studies have been published since 2007. Whether the list of infections should be expanded was also considered. Three possible additions were considered: Methicillin-resistant Staphylococcus aureus (MRSA), Clostridium difficile (C. difficile), and norovirus. MRSA and C. difficile are already the subjects of comparative effectiveness reviews under AHRQ's Effective Health Care Program.9,10 The study on MRSA focuses specifically on the effectiveness of universal screening, while the report on C. difficile is broader in scope. Serious consideration was given to the inclusion of norovirus, because the need to include cleaning staff, clinical staff, and others in efforts to reduce infections might shed more light on the importance of context in influencing the effectiveness of various QI strategies to implement preventive interventions. However, the Healthcare Infection Control Practices Advisory Committee (HICPAC) guidelines for norovirus were in draft form when this project was started. Furthermore, there was concern that the epidemic nature of norovirus outbreaks would make it more difficult to link specific QI strategies to changes in infection rates. Based on these factors, this report will focus on the same four infections that the 2007 report did.3.

The scope of this report was expanded by broadening the list of health care settings included. Much of the initial work on HAI focused on hospital settings, as is evident in the 2007 report. Less information is available on HAI in nonhospital health care settings, such as ambulatory surgery centers, freestanding dialysis centers, and long-term care facilities, but it is clear that HAI are found in these settings as well and deserve attention.11-14 CDC has issued guidelines specifically for other health care settings.15 Although comparable estimates of the costs of HAI for nonhospital settings were not found, it is clear that the total direct medical costs of HAI are higher when other settings are included. This report, therefore, sought to include studies on the effectiveness of QI strategies in these nonhospital health care settings as well.

The 2007 report focused on “the implementation of preventive interventions that are recommended for universal use in target patient populations by professional societies and governmental organizations.” For the current report, we rely on guidelines from CDC, the SHEA, and IDSA. The CDC Guidelines are developed by HICPAC, which was formed to provide guidance to the CDC and the Secretary of Health and Human Services regarding strategies for prevention and surveillance of HAI and includes broad stakeholder input. We also reviewed SHEA/IDSA Compendium of Strategies to Prevent Healthcare-Associated Infections. The Compendium highlights evidence-based HAI prevention strategies to be implemented in acute care hospitals.16-19

In reviewing efforts to improve health care quality and specifically to prevent HAI, it is important to use consistent terminology to differentiate among several concepts.

- The first step in designing a quality improvement project is to identify a quality gap: According to Ranji and colleagues, a quality gap refers to the difference between health care processes or outcomes observed in practice and those potentially achievable on the basis of current professional knowledge.3 In this proposal, the quality gaps are the levels of HAI found in various health care settings.
  ○ Quality improvement target is the outcome process or structure that the QI strategy is aimed at changing.3
  ○ Preventive intervention is a specific infection control practice that has been demonstrated to reduce the incidence of an HAI.3 An example would be using maximal sterile barrier precautions when inserting a central line.
  ○ A quality improvement strategy aims to narrow the quality gap for a group of patients who are representative of those seen in routine practice by increasing the use of preventive interventions.3 An example would be staff training about the use of maximal sterile barrier precautions and authorizing any member of the team to stop the procedure if any part(s) of the preventive intervention is not being used.
  ○ The effectiveness of a QI strategy is dependent not only on the strategy chosen but also on the context in which it is implemented. According to a recent report prepared by RAND for AHRQ,20 there is no standard definition of context but it may include barriers and facilitators related to the organizational and policy environment, as well as information about the processes of implementation.
  ○ The above terminology is based on the terminology used in the original report on Closing the Quality Gap: Reducing Healthcare Associated Infections.3 Different terminology is used in other studies, such as patient safety practices in the RAND report cited above, which also is used to establish the framework for parts of this report.20 For consistency across this series, the term “quality improvement strategy” or “QI strategy” will be used.

### Quality Improvement Strategies

How to spur the adoption of preventive interventions has been the subject of considerable research in recent years. These efforts are taking place in single hospitals or units within a hospital, as well as across entire states and even multistate collaboration. For example, AHRQ has funded CUSP (Comprehensive Unit based Safety Program) to bring toolkits from Michigan's Keystone project to every other state in the United States and to Puerto Rico (www.hret.org). The focus will first be on bloodstream infections and then on catheter-associated urinary tract infections. An interim report released in April 2011 reported a 35 percent reduction in CLABSI rates from 1.8 to 1.17 infections per 1,000 central line-days among over 350 adult intensive care units (www.ahrq.gov/qual/onthecusprpt/). While not focused on prevention efforts, a recent report on infection control lapses in ambulatory surgical centers (ASCs) found that 46 of 68 ASCs audited had at least one lapse in infection control.21 Some efforts have been initiated internally by dedicated staff. Others have been spurred in part by external forces, such as Medicare's policy not to pay for “never events,” which include “patient death or serious disability associated with the use of contaminated drugs, devices or biologics provided by the healthcare facility” (www.qualityforum.org/Publications/2008/10/Serious_Reportable_Events.aspx; www.cms.gov/MedicareAdvtgSpecRateStats/downloads/oon-payments.pdf). A great deal of activity in this field since 2007 warrants an update and reexamination of what has been learned.

A corollary of the increase in quality improvement research has been the development of guidelines for reporting as well as of research frameworks to guide QI efforts. Pronovost and colleagues developed one research framework,22 whose structure parallels that of pharmaceutical research with phases from T0 through T4. Phase T3 focuses on moving evidence-based guidelines into practice, through delivery, dissemination, and diffusion research. The focus of this report falls within this phase.

Consistency in reporting of QI research was addressed in 2008 with the development of the Standards for Quality Improvement Reporting Excellence (SQUIRE) guidelines, which provide researchers and journals a checklist of how to report on QI research.23 However, the SQUIRE guidelines do not provide much detail on how the setting or context in which research takes place should be described. Additions from the RAND report and other discussions of the impact of context on research may increase the uniformity of reporting in the body of evidence.20,24-26

The challenges of implementing prevention and surveillance programs for HAI are many. These efforts are labor intensive and require an infrastructure that coordinates the education and supervision of staff, and in larger health care facilities, computerized support.27 There are a number of steps in creating the evidence base that supports efforts to reduce HAI. Once the targets of the efforts are identified, for example, the types of infections and most common locations or patient populations, the next step is to identify preventive interventions that, if undertaken, are likely to prevent these HAI. Extensive research in this area has resulted in the development of evidence-based guidelines, such as those produced by HICPAC and SHEA/IDSA. But knowledge of effective interventions to reduce HAI can be difficult to convert into practice. As extensive efforts to improve adherence with hand washing have shown, it can be difficult to translate the knowledge that hand washing can reduce infections into consistent, appropriate practice. This report will focus on the implementation of QI strategies to prevent HAI, for example, how to get health care workers to wash their hands and to do so correctly for each clinical situation.

The field of implementation of QI strategies is evolving, with reviews covering broad topics such as how to change provider behavior28 or how to incorporate guidelines into clinical practice.29 The reviews have found that studies often combine strategies into multifaceted approaches, rather than implement a single strategy. While the reviews report that these multifaceted approaches are more likely to be successful, there are challenges in determining which components are potentially effective alone, or if all components or a subset of the components are necessary for efficacy.28-31 In a health technology assessment on the effectiveness of guideline dissemination and implementation strategies, Grimshaw et al. report that the most common intervention strategy implemented was the use of provider reminders.29 Moderate improvements in the utilization of guidelines were reported when provider reminders were used. The next most common intervention was educational outreach, which was defined as the use of a trained person who met with providers in their practice settings to provide information with the intent of changing the provider's practice. Educational outreach, which was often one component of a multifaceted approach, demonstrated modest effects. The assessment found less evidence on the distribution of printed educational materials, audit and feedback, and patient directed interventions. The authors conclude that there is not a robust generalizable evidence base on effective strategies to promote guideline utilization.29

Reviews that focused on a single QI strategy included studies implementing the QI strategy alone, as well as studies in which the QI strategy was part of a multifaceted intervention system. A Cochrane review on the effects of audit and feedback on health care outcomes reported variable effects.31 For studies with dichotomous outcomes, the adjusted risk difference of adherence varied from a 16 percent decrease in adherence to a 70 percent increase in adherence. For studies with continuous outcomes, the adjusted percent change varied from a 10 percent decrease in adherence to a 68 percent increase in adherence.31 Another Cochrane review focused on a specific type of provider education strategy, educational outreach visits.30 This review reports that educational outreach visits, whether alone or in combination with other strategies, show consistent and small improvements in prescribing patterns, and small to moderate improvements in other professional performance measures. A review that focused solely on the effect of health information technology or health information systems on clinicians' adherence to evidence-based guidelines has found a positive effect on adherence, but inconsistent effects on patient outcomes.32 Many reviews cite a difficulty in forming conclusions on the effectiveness of a particular QI strategy due to the variability among studies, whether the strategy was implemented singly or as part of a multifaceted intervention.28-31

Shekelle et al. note that context may be the distinguishing factor between evaluating the impact of a QI strategy versus a clinical intervention.20 The RAND report identified important evaluation questions for QI strategies, reporting requirements, and the elements of context that may have an impact on the effectiveness of implementing QI strategies, all of which are incorporated into the present evidence review.

## Objectives

This systematic review updates the AHRQ Evidence Report on Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Volume 6: Prevention of Healthcare-Associated Infections.3 The objective is to identify QI strategies that successfully increase adherence to effective preventive interventions and reduce infection rates for CLABSI, VAP, SSI, and CAUTI. Successful strategies help to close the quality gap regarding HAI. The purpose of this review is to inform and assist health care decisionmakers, patients, clinicians, health systems leaders, and policy makers.

This review will evaluate the large number of implementation studies that have been published since 2006, when the literature search for the 2007 report ended. It will not expand infections included, for reasons previously explained. It will expand the settings to be considered from primarily hospitals to include ambulatory surgery centers, freestanding dialysis centers, and long-term care facilities, where the prevention of HAI needs to be addressed as well.

The current report also will apply the recommendations, where applicable, of a patient safety methodology report prepared for AHRQ by RAND Health.20 The objective of this report was to identify criteria for assessing the impact of context on the effectiveness of patient safety practices, which are a type of QI strategy. The context of an intervention, for example, the type of health care setting, the leadership structure, the safety culture, the openness to innovation, can have an important impact on whether preventive interventions are adopted. Furthermore, the ability to transfer a successful QI strategy from one setting to another may depend in part on whether the contexts differ. For example, cultures in which nurses are able to question a physician's adherence to recommended practices may be able to implement an intervention more successfully than those where they are not.

## Key Questions

Key Question 1. Which quality improvement strategies are effective in reducing the following healthcare-associated infections?

- Central line–associated bloodstream infections (CLABSI)
- Ventilator-associated pneumonia (VAP)
- Surgical site infections (SSI)
- Catheter-associated urinary tract infections (CAUTI)
  a. Which quality improvement strategies are effective in increasing adherence to evidence-based preventive interventions for the four healthcare-associated infections listed above?
  b. What is the cost, return on investment, or cost-effectiveness for health care providers, patients, and society as a whole of quality improvement strategies to reduce these healthcare-associated infections?
  c. Which factors are associated with the effectiveness of quality improvement strategies, including, for example,
    1. Type of quality improvement strategy
      a. Clinician education
      b. Patient education
      c. Audit and feedback
      d. Clinician reminder systems
      e. Organizational change
      f. Financial or regulatory incentives for patients or clinicians
      g. A combination of the above
    2. Duration of intervention
    3. Setting, for example, hospitals (intensive care unit, surgical or ventilator-dependent patients), outpatient surgical centers, long-term care facilities, and freestanding dialysis centers, and which kinds of clinicians implement the quality improvement strategies?

Key Question 2. What is the impact of the health care context on the effectiveness of quality improvement strategies, including reducing infections and increasing adherence to preventive interventions?