# Peer Reviewers

Mary Blank, M.P.H.

Manager, Hospital Performance Management

Highmark Blue Cross Blue Shield

Pittsburgh, PA

Barbara DeBaun, B.S.N., M.S.N.

Bay Area Patient Safety Collaborative (BEACON)

Improvement Advisor

Cynosure Health

San Francisco, CA

Donald Goldmann, M.D.

Senior Vice President

Institute for Healthcare Improvement

Cambridge, MA

Stephen Ostroff, M.D.

Director, Bureau of Epidemiology and Acting Physician General

Pennsylvania Department of Health

Harrisburg, PA

David A. Pegues, M.D.

Professor of Clinical Medicine and Program Director, Infectious Diseases

David Geffen School of Medicine

University of California Los Angeles

Los Angeles, CA

Cassandra D. Salgado, M.D., M.S.

Associate Professor of Medicine

Division of Infectious Disease

Medical University of South Carolina

Charleston, SC

Thomas R. Talbot, M.D., M.P.H.

Assistant Professor and Chief Hospital Epidemiologist

Vanderbilt University

Nashville, TN

Sharon Beth Brodie Wright, M.D.

Attending Physician, Medicine/Infectious Diseases

Research Director, Infection Control

Beth Israel Deaconess Medical Center

Boston, MA