# Technical Expert Panel

Joan Blanchard, B.S.N., M.S.S.

Perioperative Nursing Specialist

Association of Perioperative Registered Nurses

Centers for Disease Control and Prevention

Healthcare Infection Control Practices Advisory Committee Liaison

Denver, CO

Mary Blank, M.P.H.

Manager, Hospital Performance Management

Highmark Blue Cross Blue Shield

Pittsburgh, PA

Barbara DeBaun, B.S.N., M.S.N.

Bay Area Patient Safety Collaborative (BEACON)

Improvement Advisor

Cynosure Health

San Francisco, CA

Jan K. Horn, M.D.

Professor of Clinical Surgery

University of California San Francisco School of Medicine

San Francisco, CA

Mitchell Levy, M.D.

Professor of Medicine

Brown University School of Medicine

Providence, RI

Lisa Maragakis, M.D., M.P.H.

Assistant Professor of Medicine

Division of Infectious Diseases

The Johns Hopkins University

Baltimore, MD

Lisa McGiffert, B.A.

Campaign Director, Safe Patient Project and Stop Hospital Infections Campaign

Consumers Union

Austin, TX

Sanjay Saint, M.D., M.P.H.

Professor, Department of Internal Medicine

University of Michigan

Ann Arbor, MI

Sharon Beth Brodie Wright, M.D.

Attending Physician, Medicine/Infectious Diseases

Research Director, Infection Control

Beth Israel Deaconess Medical Center

Boston, MA