# Details of Interrupted Time Series Analysis

Appendix Table G1 Description of interrupted time series results for VAP studies

Author, Country-Year | Outcome | Test | Values | p-value | Comment
Zaydfudim, United States - 2009 | Infection rates | t-test | Mean baseline: 15.2
Zaydfudim, United States - 2009 | Infection rates | t-test | Mean post-intervention: 9.3 | 0.01
Zaydfudim, United States - 2009 | Infection rates | piecewise linear regression | | 0.37 | The trend during the baseline period is not significantly different than the trend during the post-intervention period.
Apisarnthanarak, Thailand - 2007 | MICU Infection rates | t-test | Mean baseline: 20.6 | | p-values are comparing the subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | MICU Infection rates | t-test | Mean post-intervention: 8.5 | 0.001 | p-values are comparing the subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | MICU Infection rates | t-test | Mean follow-up: 4.2 | <0.001 | p-values are comparing the subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | MICU Infection rates | segmented regression | Initial change from baseline to post-intervention: -2.291 | 0.6307 | Difference between the last point in baseline is not significantly different than the first point in post-intervention.
Apisarnthanarak, Thailand - 2007 | MICU Infection rates | segmented regression | Initial change from post-intervention to follow-up: -1.594 | 0.7007 | Difference between the last point in post-intervention is not significantly different than the first point in follow-up.
Apisarnthanarak, Thailand - 2007 | MICU Infection rates | segmented regression | Difference in trends from baseline and post-intervention: -1.171 | 0.0018 | Trend during post-intervention is significantly different than the trend during baseline.
Apisarnthanarak, Thailand - 2007 | MICU Infection rates | segmented regression | Difference in trends from post-intervention and follow-up: -1.115 | 0.07 | Trend during follow-up is marginally significantly different than the trend during post-intervention.
Bouadma, France - 2010 | Infection rates | Wilcoxon rank sum test | Overall baseline: 22.6
Bouadma, France - 2010 | Infection rates | Wilcoxon rank sum test | Overall post-intervention: 13.1 | <0.001
Bouadma, France - 2010 | Infection rates | segmented regression | Trend during baseline | 0.11 | There was a non-significant change in trend during the baseline period.
Bouadma, France - 2010 | Infection rates | segmented regression | Trend during post-intervention | 0.001 | There was a significant decrease in trend during the post-intervention period.
Marra, Brazil - 2009 | Infection rates | ANOVA | Mean baseline: 16.4
Marra, Brazil - 2009 | Infection rates | ANOVA | Mean post-intervention 1: 15.0
Marra, Brazil - 2009 | Infection rates | ANOVA | Mean post-intervention 2: 10.4 | 0.05
Marra, Brazil - 2009 | Infection rates | segmented regression | Trend part 1 of Phase 3: 2.59 | 0.001 | There was a significant increase in the trend during the first part of Phase 3.
Marra, Brazil - 2009 | Infection rates | segmented regression | Trend during part 2 of Phase 3: -2.30 | 0.27 | There was a nonsignificant change in trend during the second part of Phase 3.
Marra, Brazil - 2009 | Infection rates | segmented regression | Trend during part 3 of Phase 3: -0.76 | 0.18 | There was a nonsignificant change in trend during the last part of Phase 3.
Papadimos, United States - 2008 | Infection rates | 2-tailed z-test/Wilcoxon rank sum test | Overall baseline: 19.3
Papadimos, United States - 2008 | Infection rates | 2-tailed z-test/Wilcoxon rank sum test | Overall pre-FASTHUG: 16.6 | 0.62
Papadimos, United States - 2008 | Infection rates | 2-tailed z-test/Wilcoxon rank sum test | Overall post-FASTHUG: 7.3 | <0.01
Papadimos, United States - 2008 | Infection rates | ARIMA model | Baseline vs pre-FASTHUG period | 0.5909 | Authors combined baseline and pre-FASTHUG periods since they were non-significantly different.
Papadimos, United States - 2008 | Infection rates | ARIMA model | Combined pre-FASTHUG period vs post-FASTHUG period | 0.0004 | The mean monthly infection rates are significantly lower in the post-FASTHUG period

Appendix Table G2 Description of interrupted time series results for CLABSI studies

Author, Country-Year | Outcome | Test | Values | p-value | Comment
Apisarnthanarak, Thailand - 2007 | Medical Ward Infection Rates | t-test | Mean baseline: 16 | | p-values are comparing subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | Medical Ward Infection Rates | t-test | Mean post-intervention: 6.8 | <0.05 | p-values are comparing subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | Medical Ward Infection Rates | t-test | Mean follow-up: 1.5 | <0.05 | p-values are comparing subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | Medical Ward Infection Rates | segmented regression | Initial change from baseline to post-intervention: -7.72 | 0.03 | Difference between the last point in baseline is significantly different than the first point in post-intervention.
Apisarnthanarak, Thailand - 2007 | Medical Ward Infection Rates | segmented regression | Initial change from post-intervention to follow-up: -4.15 | 0.02 | Difference between the last point in post-intervention is significantly different than the first point in follow-up.
Apisarnthanarak, Thailand - 2007 | Medical Ward Infection Rates | segmented regression | Difference in trends from baseline and post-intervention: -1.18 | 0.48 | Trend during post-intervention is not significantly different than the trend during baseline.
Apisarnthanarak, Thailand - 2007 | Medical Ward Infection Rates | segmented regression | Difference in trends from post-intervention and follow-up: -1.15 | 0.07 | Trend during follow-up is marginally significantly different than the trend during post-intervention.
Apisarnthanarak, Thailand - 2007 | Surgical Ward Infection Rates | t-test | Mean baseline: 11 | | p-values are comparing subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | Surgical Ward Infection Rates | t-test | Mean post-intervention: 5.5 | <0.05 | p-values are comparing subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | Surgical Ward Infection Rates | t-test | Mean follow-up: 0.8 | <0.05 | p-values are comparing subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | Surgical Ward Infection Rates | segmented regression | Initial change from baseline to post-intervention: -8.36 | 0.001 | Difference between the last point in baseline is significantly different than the first point in post-intervention.
Apisarnthanarak, Thailand - 2007 | Surgical Ward Infection Rates | segmented regression | Initial change from post-intervention to follow-up: -4.04 | 0.05 | Difference between the last point in post-intervention is significantly different than the first point in follow-up.
Apisarnthanarak, Thailand - 2007 | Surgical Ward Infection Rates | segmented regression | Difference in trends from baseline and post-intervention: 0.08 | 0.45 | Trend during post-intervention is not significantly different than the trend during baseline.
Apisarnthanarak, Thailand - 2007 | Surgical Ward Infection Rates | segmented regression | Difference in trends from post-intervention and follow-up: -0.22 | 0.40 | Trend during follow-up is not significantly different than the trend during post-intervention.
Apisarnthanarak, Thailand - 2007 | ICU Infection Rates | t-test | Mean baseline: 17 | | p-values are comparing subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | ICU Infection Rates | t-test | Mean post-intervention: 7.1 | <0.05 | p-values are comparing subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | ICU Infection Rates | t-test | Mean follow-up: 2.1 | <0.05 | p-values are comparing subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | ICU Infection Rates | segmented regression | Initial change from baseline to post-intervention: -12.25 | 0.005 | Difference between the last point in baseline is significantly different than the first point in post-intervention.
Apisarnthanarak, Thailand - 2007 | ICU Infection Rates | segmented regression | Initial change from post-intervention to follow-up: -8.13 | 0.001 | Difference between the last point in post-intervention is significantly different than the first point in follow-up.
Apisarnthanarak, Thailand - 2007 | ICU Infection Rates | segmented regression | Difference in trends from baseline and post-intervention: 0.24 | 0.36 | Trend during post-intervention is not significantly different than the trend during baseline.
Apisarnthanarak, Thailand - 2007 | ICU Infection Rates | segmented regression | Difference in trends from post-intervention and follow-up: -1.54 | 0.06 | Trend during follow-up is marginally significantly different than the trend during post-intervention.
Apisarnthanarak, Thailand - 2007 | Other Units Infection Rates | t-test | Mean baseline: 9 | | p-values are comparing subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | Other Units Infection Rates | t-test | Mean post-intervention: 5.2 | <0.05 | p-values are comparing subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | Other Units Infection Rates | t-test | Mean follow-up: 0.9 | <0.05 | p-values are comparing subsequent period to baseline.
Apisarnthanarak, Thailand - 2007 | Other Units Infection Rates | segmented regression | Initial change from baseline to post-intervention: -3.36 | 0.04 | Difference between the last point in baseline is significantly different than the first point in post-intervention.
Apisarnthanarak, Thailand - 2007 | Other Units Infection Rates | segmented regression | Initial change from post-intervention to follow-up: -1.45 | 0.14 | Difference between the last point in post-intervention is not significantly different than the first point in follow-up.
Apisarnthanarak, Thailand - 2007 | Other Units Infection Rates | segmented regression | Difference in trends from baseline and post-intervention: 0.14 | 0.24 | Trend during post-intervention is not significantly different than the trend during baseline.
Apisarnthanarak, Thailand - 2007 | Other Units Infection Rates | segmented regression | Difference in trends from post-intervention and follow-up: -0.04 | 0.2 | Trend during follow-up is not significantly different than the trend during post-intervention.

Appendix Table G3 Description of interrupted time series results for SSI studies

Author, Country-Year | Outcome | Test | Values | p-value | Comment
Mannien, Netherlands - 2006 | Overall Infection rates | t-test | Mean baseline: 21.5
Mannien, Netherlands - 2006 | Overall Infection rates | t-test | Mean post-intervention 5.2 | <0.001
Mannien, Netherlands - 2006 | Overall Infection rates | segmented regression | Initial change from baseline to post-intervention: 13.71 | <0.001 | Difference between the last point in baseline is significantly different than the first point in post-intervention.
Mannien, Netherlands - 2006 | Overall Infection rates | segmented regression | Difference in trends from baseline and post-intervention: 0.27 | 0.5 | Trend during post-intervention is not significantly different than the trend during baseline.
Mannien, Netherlands - 2006 | Medical Ward Infection rates | t-test | Mean baseline: 21.5
Mannien, Netherlands - 2006 | Medical Ward Infection rates | t-test | Mean post-intervention 6.5 | 0.02
Mannien, Netherlands - 2006 | Medical Ward Infection rates | segmented regression | Initial change from baseline to post-intervention: 11.23 | 0.04 | Difference between the last point in baseline is significantly different than the first point in post-intervention.
Mannien, Netherlands - 2006 | Medical Ward Infection rates | segmented regression | Difference in trends from baseline and post-intervention: 0.67 | 0.24 | Trend during post-intervention is not significantly different than the trend during baseline.
Mannien, Netherlands - 2006 | Surgical Ward Infection rates | t-test | Mean baseline: 19.4
Mannien, Netherlands - 2006 | Surgical Ward Infection rates | t-test | Mean post-intervention 7.8 | 0.03
Mannien, Netherlands - 2006 | Surgical Ward Infection rates | segmented regression | Initial change from baseline to post-intervention: 7.61 | 0.03 | Difference between the last point in baseline is significantly different than the first point in post-intervention.
Mannien, Netherlands - 2006 | Surgical Ward Infection rates | segmented regression | Difference in trends from baseline and post-intervention: 0.97 | 0.06 | Trend during post-intervention is marginally significantly different than the trend during baseline.
Mannien, Netherlands - 2006 | ICU Infection rates | t-test | Mean baseline: 23.4
Mannien, Netherlands - 2006 | ICU Infection rates | t-test | Mean post-intervention 3.5 | 0.01
Mannien, Netherlands - 2006 | ICU Infection rates | segmented regression | Initial change from baseline to post-intervention: 11.23 | 0.003 | Difference between the last point in baseline is significantly different than the first point in post-intervention.
Mannien, Netherlands - 2006 | ICU Infection rates | segmented regression | Difference in trends from baseline and post-intervention: 0.67 | 0.5 | Trend during post-intervention is not significantly different than the trend during baseline.

Appendix Table G4 Description of interrupted time series results for CAUTI studies

Author, Country-Year | Outcome | Test | Values | p-value | Comment
Apisarnthanarak, Thailand - 2007 | Overall Infection rates | t-test | Mean baseline: 21.5
Apisarnthanarak, Thailand - 2007 | Overall Infection rates | t-test | Mean post-intervention 5.2 | <0.001
Apisarnthanarak, Thailand - 2007 | Overall Infection rates | segmented regression | Initial change from baseline to post-intervention: 13.71 | <0.001 | Difference between the last point in baseline is significantly different than the first point in post-intervention.
Apisarnthanarak, Thailand - 2007 | Overall Infection rates | segmented regression | Difference in trends from baseline and post-intervention: 0.27 | 0.5 | Trend during post-intervention is not significantly different than the trend during baseline.
Apisarnthanarak, Thailand - 2007 | Medical Ward Infection rates | t-test | Mean baseline: 21.5
Apisarnthanarak, Thailand - 2007 | Medical Ward Infection rates | t-test | Mean post-intervention 6.5 | 0.02
Apisarnthanarak, Thailand - 2007 | Medical Ward Infection rates | segmented regression | Initial change from baseline to post-intervention: 11.23 | 0.04 | Difference between the last point in baseline is significantly different than the first point in post-intervention.
Apisarnthanarak, Thailand - 2007 | Medical Ward Infection rates | segmented regression | Difference in trends from baseline and post-intervention: 0.67 | 0.24 | Trend during post-intervention is not significantly different than the trend during baseline.
Apisarnthanarak, Thailand - 2007 | Surgical Ward Infection rates | t-test | Mean baseline: 19.4
Apisarnthanarak, Thailand - 2007 | Surgical Ward Infection rates | t-test | Mean post-intervention 7.8 | 0.03
Apisarnthanarak, Thailand - 2007 | Surgical Ward Infection rates | segmented regression | Initial change from baseline to post-intervention: 7.61 | 0.03 | Difference between the last point in baseline is significantly different than the first point in post-intervention.
Apisarnthanarak, Thailand - 2007 | Surgical Ward Infection rates | segmented regression | Difference in trends from baseline and post-intervention: 0.97 | 0.06 | Trend during post-intervention is marginally significantly different than the trend during baseline.
Apisarnthanarak, Thailand - 2007 | ICU Infection rates | t-test | Mean baseline: 23.4
Apisarnthanarak, Thailand - 2007 | ICU Infection rates | t-test | Mean post-intervention 3.5 | 0.01
Apisarnthanarak, Thailand - 2007 | ICU Infection rates | segmented regression | Initial change from baseline to post-intervention: 11.23 | 0.003 | Difference between the last point in baseline is significantly different than the first point in post-intervention.
Apisarnthanarak, Thailand - 2007 | ICU Infection rates | segmented regression | Difference in trends from baseline and post-intervention: 0.67 | 0.5 | Trend during post-intervention is not significantly different than the trend during baseline.