# Overview Tables for Articles Not Included in Analysis

Appendix Table F1 VAP studies not included in analysis

Author, Location-Year | Sample Size (Infections) | Intervention | Audit and Feedback | Financial Incentives | Organizational Change | Patient Education | Promotion of Self-Management | Provider Education | Provider Reminder Systems
Assanasen, United States - 2008 | pre: 450 post: 2435 | Feedback Program | •
Bigham, United States - 2009 | pre: 617 (77) post1: 447 (22) post2: 1782 (3) | VAP Bundle | • | | • | | | • | •
Rogers, Ireland - 2010 | pre: 8 (10) post: 5 (6) | Plan-Do-Study-Act (PDSA) cycle | | | | | | •
Venkatram, United States - 2010 | pre: 549 (5) post: 1165 (3) | VAP bundle | • | | • | • | | •
Sona, United States - 2009 | pre: 777 (24) post: 871 (10) | Oral Care Protocol | • | | • | | | •
Garcia, United States - 2009 | pre: 779 (67) post: 759 (31) | VAP Education and Oral Care Protocol | | | • | | | •
Rosenthal, Argentina - 2006 | pre: 435 (84) post: 366 (54) | Nurse-Implemented Sedation Protocol | • | | | | | •
Gurskis, Lithuania - 2009 | pre: 270 (15) post: 322 (6) | VAP Education | | | | | | •
Landrum, Afghanistan - 2008 | total: 475 (25) | Infection Control Protocol | • | | • | | | •
Heimes, United States - 2011 | pre: 215 (8) post1: 240 (4) post2 : 241 (3) | VAP Prevention Protocol (VAPP) | • | | • | | | •
Quenot, France - 2007 | pre: 226 (34) post: 197 (12) | VAP Bundle | | | •
Jain, United States - 2006 | pre: (260) post: (70) | IMPACT initiative | • | | •
Bloos, Germany - 2009 | pre: 133 (44) post: 141 (45) | Educational Program | • | | • | | | •
Jimenez, United States - 2009 | pre: 102 post: 86 | VAP Bundle | • | | | | | • | •
Ross, United States - 2007 | pre: 55 post: 61 | Multifaceted Infection Control Program | • | | | | | •
Abbott, United States - 2006 | pre: (9) post: (9) total: 106 (18) | Academic Center of Evidence-based Practice (ACE) Star Model | • | | • | | | • | •
Berriel-Cass, United States - 2006 | | VAP bundle | • | | • | | | •
Bird, United States - 2010 | | VAP Bundle | • | | • | | | | •
Blamoun, United States - 2009 | | Expanded VAP bundle | | | •
Cocanour, United States - 2006 | | VAP Bundle | • | | • | • | | •
Ban, Korea, (South) Republic of - 2011 | | multi-dimensional program for VAP prevention | • | | • | | | • | •
Kastrup, Germany - 2011 | pre: 111 post: 94 | Visual feedback system of daily goals for ventilator weaning | • | | | | | •
Rosenthal, Colombia* - 2011 | pre: 1272 (61) post: 3067 (80) | VAP bundle, education and feedback | • | | • | | | •
Stone, United States - 2011 | pre: 85 (15) post: 89 (5) | VAP bundle with daily goal rounds and checklist | | | • | | | | •
Garcia-Vazquez, Spain - 2011 | pre: 395 post: 411 (Total: 35) | hand hygiene program | | | | | | •

Appendix Table F2 CLABSI articles not included in analysis

Author, Location-Year | Sample Size (Infections) | Intervention | Audit and Feedback | Financial Incentives | Organizational Change | Patient Education | Promotion of Self-Management | Provider Education | Provider Reminder Systems
Lobo, Brazil - 2010 | pre: 519 (41) post: 303 (12) | Continuous Education | • | | | | | • | •
Venkatram, United States - 2010 | pre: 1096 (18) post: 3749 (8) | CLABSI bundle | • | | • | • | | •
Shannon, United States - 2006 | pre: 1067 (49) post: 1832 (3) | Toyota Production System adaptation | | | • | | | •
Assanasen, United States - 2008 | pre: 450 post: 2435 | Feedback Program | •
Warren, United States - 2006 | pre: (229) post: (508) | Multifaceted, education-based intervention | | | | | | •
Koll, United States - 2008 | pre: (364) post: (349) | Central line bundle | • | | • | | | •
Wicker, United States - 2011 | pre: 334 (103) post: 303 (59) | Comprehensive Infection Control Measures | • | | • | | | •
Bizzarro, United States - 2010 | pre: 417 (83) post: 159 (6) | Bundle - CLABSI | • | | • | | • | •
Yilmaz, Turkey - 2007 | pre: 241 (71) post: 193 (45) | Education | • | | • | | | •
Sannoh, United States - 2010 | pre: 163 (45) post: 210 (35) | Bundle - CLABSI | • | | | | | • | •
Gurskis, Lithuania - 2009 | pre: 95 (5) post: 108 (2) | CLABSI Education | | | | | | •
Marra, Brazil - 2010 | pre: (134) post: (64) | IHI Bundle - CLABSI | • | | • | | | | •
Santana, Brazil - 2008 | total: 186 | Education | | | | | | •
Rogers, Ireland - 2010 | pre: (31) post: (19) | Plan-Do-Study-Act (PDSA) cycle | | | | | | •
Guerin, United States - 2010 | pre: (25) post: (3) | Post-insertion CVC care bundle | | | | | | •
Jeffries, United States - 2009 | | CVC Insertion and Maintenance Bundle | • | | • | | | •
Berriel-Cass, United States - 2006 | | CLABSI Bundle | • | | • | | | •
Bhutta, United States - 2007 | | Bundle CLABSI | | | • | | | • | •
Galpern, United States - 2008 | | CLABSI Bundle | • | | • | | | •
Jain, United States - 2006 | | IMPACT initiative | • | | •
Render, United States - 2006 | | CLABSI Bundle | • | | • | | | | •
Cherry, United States - 2011 | pre: (202); post: (121) | CVC insertion and maintenance training for nurses and residents | | | • | | | •
Gozu, United States - 2011 | ICU Pre: (10); NON-ICU Pre (9); ICU Post (6); Non-ICU Post (14) | CLABSI Audit and Feedback and Checklist | • | | • | | | | •
Lopez, United States - 2011 | | CLABSI bundle | • | | • | | | | •
Garcia-Vazquez, Spain - 2011 | pre: 395; post: 411 (total: VAP: 35, CAUTI: 33, CLABSI: 6, SSI: 16) | hand hygiene program | | | | | | •
McHugh, Ireland - 2011 | | Web-based education program with podcasts, best practice videos, interactive cases, and tutorials | • | | | | | •
Bakke, United States - 2010 | Total: 385 | CLABSI Bundle | • | | • | | | • | •

Appendix Table F3 SSI articles not included in analysis

Author, Location-Year | Sample Size (Infections) | Intervention | Audit and Feedback | Financial Incentives | Organizational Change | Patient Education | Promotion of Self-Management | Provider Education | Provider Reminder Systems
Wax, United States - 2007 | pre: 4987 post: 9478 | Electronic reminder for provider | | | | | | | •
Gomez, Argentina - 2006 | pre: 3496 (111) post: 3982 (75) | automatic stop prophylaxis form | | | • | | | • | •
Graf, Germany - 2009 | pre: 3150 (114) post: 980 (80) | bundle - SSI | • | | | | | • | •
Takahashi, Japan - 2010 | pre: 1627 post: 1627 | Departmental Education | • | | • | | | •
Kramer, United States - 2008 | pre: 1677 (44*) post: 1388 (14*) | nomogram for glycemic control | | | • | | | • | •
Liau, Singapore - 2010 | post: 2408 (12*) | bundle - antibiotic, glucose control, clippers, normothermia | | | • | | | • | •
Parker, United States - 2007 | pre: 615 post: 1716 | Six Sigma methodology and antibiotic prophylaxis | | | • | | | •
Suchitra, India - 2009 | pre: 1125 (136) post: 1119 (45) | Education Program | | | | | | •
Shimoni, Israel - 2009 | pre: 1104 (186) post: 1089 (137) | Empowering surgical nurses | | | •
Ichikawa, Japan - 2007 | pre: 721 (27) post: 1313 (22) | Implementation of Antibiotic Protocols | • | | | | | •
Whitman, United States - 2008 | total: 1622 | Multiple ‘forced functions’ | • | | • | | | • | •
Potenza, United States - 2009 | total: 1359 | bundle - antibiotic prophylaxis | | | • | | | | •
Kable, Australia - 2008 | pre: 659 (50) post: 518 (42) | bundle - antibiotic prophylaxis | | | • | | | • | •
Rauk, United States - 2010 | pre: 441 (33) post: 436 (5) | bundle - skin prep and instrument sterilization | | | • | | | •
Hermsen, United States - 2008 | pre: 406 post: 396 | Standardized order form | • | | • | | | • | •
Ozgun, Turkey - 2010 | pre: 312 post: 322 | antibiotic prophylaxis education | | | | | | •
Pastor, United States - 2010 | pre: 238 (45) post: 253 (49) | task force to meet SCIP process measures | | | • | | | •
Carles, France - 2006 | pre: 210 post: 210 | surgical antibiotic prophylaxis kit (SAPK) | | | •
Acklin, Switzerland - 2011 | pre: 217 (15) post: 153 (3) | bundle - antibiotic prophylaxis, skin prep, sterile dressing | • | | | | | •
Nemeth, United States - 2010 | pre: 97 post: 193 | Education program | | | | | | • | •
Willemsen, Netherlands - 2007 | pre: 153 post: 147 | standardized antibiotic protocol | | | • | | | •
Berry, United States - 2009 | pre: 137 post: 117 | ProvenCare | • | | • | | | • | •
Forbes, Canada - 2008 | pre: 105 (superficial: 15*, organ space: 8*) post: 103 (superficial: 9*, organ space: 7*) | bundle - antibiotic administration in OR, pre-printed order form to standardize choice of antibiotic, monthly performance figures posted in OR; bundle - maintain normothermia by warming OR to 22 C, standardizing IV warmers and forced air devices, monthly performance figures posted in OR; bundle - glucose control by screening all pts prior to surgery, administering weight-based regimen of insulin to diabetics, monthly performance figures posted in OR | • | | • | | | •
Berenguer, United States - 2010 | pre: 113 (15) post: 84 (7) | implementing SCIP measures | | | • | | | •
Awad, United States - 2009 | | MRSA bundle | • | | • | | | •
Paull, United States - 2010 | | The Briefing Guide (BiG) | | | • | | | • | •
Zvonar, Canada - 2008 | | Appropriate antibiotic prophylaxis administration | • | | • | | | •
Barchitta, Italy - 2011 | pre: 134 (22); post1: 160 (18) post2: 159 (9) post3: 147 (12) | Infection control bundle and extensive dissemination of information | • | | • | | | •
Bull, Australia - 2011 | post1: 133 (12); post2: 142 (10) | Surgical care bundle with checklist and regular focus groups | | | • | | | | •
Lingard, Canada - 2011 | pre: 340 post: 340 | pre-surgery team briefing | | | • | | | | •
Sewell, United Kingdom - 2011 | pre: 480 (21*); post: 485 (17*) | Implementation of and training on use of WHO surgical checklist | | | • | | | • | •
Sun, Taiwan - 2011 | pre: 55 (0) post: 78 (0) | PDSA cycles to improve antibiotic prophylaxis | • | | • | | | • | •
Garcia-Vazquez, Spain - 2011 | pre: 395 post: 411 (total: SSI: 16) | hand hygiene program | | | | | | •
McHugh, Ireland - 2011 | | Web-based education program with podcasts, best practice videos, interactive cases, and tutorials | • | | | | | •

Appendix Table F4 CAUTI articles not included in analysis

Author, Location-Year | Sample Size (Infections) | Intervention | Audit and Feedback | Financial Incentives | Organizational Change | Patient Education | Promotion of Self-Management | Provider Education | Provider Reminder Systems
Stephan, Switzerland - 2006 | pre: 280 post: 300 | CAUTI guidelines, education and posters | • | | | | | •
Venkatram, United States - 2010 | pre: 1096 (18) post: 2669 (5) | CAUTI bundle | • | | • | • | | •
Suchitra, India - 2009 | pre: 1125 (74) post: 1119 (30) | Education Program | | | | | | •
Wald, United States - 2011 | pre orthopedic: 206 (3) post orthopedic: 290 (0) pre general: 167 (3) post general: 183 (3) | Audit and feedback on catheter duration | • | | | | | •
Gurskis, Lithuania - 2009 | pre: 270 (3) post: 322 (6) | CAUTI Education | | | • | | | • | •
Gokula, United States - 2007 | pre: 100 post: 100 | Education | • | | | | | • | •
Rothfeld, United States - 2010 | pre: (51) post: (26) | Appropriate Catheter Use Protocol | | | • | | | •
Jain, United States - 2006 | | IMPACT initiative | • | | •
Biese, United States - 2011 | | Geriatric specific curriculum with simulations for emergency medicine residents | | | | | | •
Dyc, United States - 2011 | | Peer-to-peer education and pocket card of proper urinary catheter indications | | | | | | • | •
Fuchs, United States - 2011 | | Nurse driven checklist for catheter use | • | | • | | | • | •
Knoll, United States - 2011 | | Phase 3: daily urinary catheter audit w discussion of necessity of nonindicated Ucs and pager reminders for expired orders. | • | | • | | | • | •
Oman, United States - 2011 | pre: 219; post1: 238; post2: 238 | Nurse driven incorporation of evidence-based practice for urinary catheters | • | | • | • | | • | •
Titsworth, United States - 2012 | | CAUTI bundle | • | | • | | | • | •
Wright, United States - 2011 | pre: 12,172 (312); post: 9,366 (247) | Use of physician order, daily nurse assessment of need, physician reminder every 48 hrs, and targeted education in high use areas to decrease urinary catheter use | | | • | | | • | •
Garcia-Vazquez, Spain - 2011 | pre: 395; post: 411 (total: 33) | hand hygiene program | | | | | | •