# Items on Data Abstraction Forms

Study and Patient Characteristics Form
- Authors
- Country
- Year Published
- Infections
- Study Design
- Healthcare Setting
- Clinical Setting
- Intervention Start Year
- Intervention End Year
- Follow-up months
- Comments

Intervention Characteristics Form
- Intervention
- Comparator
- Number of Hospitals
- Number of Patients
- Number of Patients lost to follow-up
- Number of healthcare staff
- Type of QI strategy
- Clinical Characteristics
- Age
- Age distribution
- Percent Male
- Percent White
- Interventionists
- Participants
- Intervention Specifics
- Intervention expected influence on behavior
- Outcomes
- Comments

Intervention Context Form
- Were expectations made clear to interveners and intervenees?
- What positive and negative incentives were used?
- Describe feedback or consequences given to interveners and or intervenes?
- Description of theory behind patient safety practice
- Influence of context on processes and outcomes
  ○ Organizational characteristics
    ■ Size
    ■ Location
    ■ Financial Status
    ■ Existing patient safety infrastructure
    ■ External Factors
- Patient safety culture, teamwork, leadership at the unit level
- Availability of implementation and management tools
- Comments

Intervention Outcomes Form
- Outcome value (95% CI) and statistical results for all outcomes
- Rate of infection
  ○ Units of Measurement
  ○ Months since intervention
- Adherence
  ○ Months since intervention
- Costs
- Savings
- Type of univariate model used and variables controlled for
- Type of multivariate model used and variables controlled for
- Comments

Quality Form
- Did the execution of the study vary from the original protocol?
- Is the intervention assessed using valid and reliable measures, implemented consistently across all study participants?
- Are outcomes assessed using valid and reliable measures, implemented consistently across all study participants?
- Is the length of follow up sufficient to support the evaluation of primary outcomes and harms?
- Are any important primary outcomes missing from the results?
- Is the source of funding identified?
- If infection rates reported, did study also report adherence rates?
- If infection rate was reported, was CDC/NNIS methodology used?
- For CLABSI, VAP, CAUTI - were infection rates adjusted for device utilization?
- For SSI- was post-discharge surveillance for infections performed?
- Was the intervention performed independent of other QI efforts or other changes?
- Did the study report data at more than one time point both before and after the intervention?
- If the study reported infection rates, were process measurements also reported?
- Were study subjects randomized?
- Was the randomization process described?
- For non-randomized studies, was rationale for comparison group selection explained?
- Were outcome assessor blinded to treatment group assignment?
- Was a unit of analysis error present?
- Was it corrected by appropriate statistical methods?
- Comments