# Evidence-Based Preventive Interventions Used in Study Selection

The following evidence-based preventive interventions, identified from 2007 report (Ranji et al. 2007), HICPAC guidelines, IDSA/SHEA Compendium, and input from the Technical Expert Panel, were used for identifying studies from all settings for inclusion in this evidence review.

All HAIs: Hand hygiene

Surgical site infection:

- appropriate perioperative antibiotic prophylaxis (including appropriate antibiotic selection, timing, and duration) (2007 report)
- perioperative glucose control (2007 report)
- decreasing shaving [or hair removal] of the operative site (2007 report)
- specific technique for clinicians when washing hands prior to surgery (CDC/HICPAC IB)
- treat infections prior to surgery (CDC/HICPAC IA)
- encourage tobacco cessation (CDC/HICPAC IB)
- bathe and prepare skin with antiseptic agent (CDC/HICPAC IB)
- develop policies to manage infected surgical team (CDC/HICPAC IB)
- maintain positive pressure ventilation and minimal 15 air changes per hr during surgery (CDC/HICPAC IB)
- disinfect environmental surfaces (CDC/HICPAC IB)
- sterile instruments and surgical wear (CDC/HICPAC IB)
- after surgery, protect incision with sterile dressing (CDC/HICPAC IB)
- normothermia [recommended by Technical Expert Panel]
- intraoperative administration of oxygen (FIO2), for abdominal or colorectal cases [recommended by Technical Expert Panel]

Central line-associated bloodstream infection:

- adherence to maximal sterile barrier precautions (2007 report)
- use of chlorhexidine for skin antisepsis (2007 report); If there is a contraindication to chlorhexidine, tincture of iodine, an iodophor, or 70% alcohol can be used as alternatives. (CDC/HICPAC IA)
- avoidance of femoral catheterization (2007 report)
- decontaminate hands before donning sterile gloves when inserting a central intravascular catheter (CDC/HICPAC IB)
- do not use arterial or venous cutdown procedures during insertion (CDC/HICPAC IA)
- do not use organic solvents on skin (CDC/HICPAC IA)
- clean injection ports with 70% alcohol before accessing (CDC/HICPAC IA)
- prepare admixtures using sterile technique (CDC/HICPAC IB)
- do not use in-line filters for infection-control purposes (CDC/HICPAC IA)
- do not administer systemic antimicrobial prophylaxis routinely prior to catheter insertion (CDC/HICPAC IA)
- after insertion, remove nonessential catheters (SHEA/IDSA A-II); Promptly remove any intravascular catheter that is no longer essential (CDC/HICPAC IA)
- After insertion, change dressings and perform site care every 5-7 days and change gauze every 2 days (SHEA/IDSA A-I); Replace dressings used on short-term CVC sites at least every 7 days for transparent dressings, except in those pediatric patients in which the risk for dislodging the catheter may outweigh the benefit of changing the dressing. (CDC/HICPAC IB)
- after insertion, use antimicrobial ointments (SHEA/IDSA A-I); Do not use topical antibiotic ointment or creams on insertion sites, except for dialysis catheters, because of their potential to promote fungal infections and antimicrobial resistance. (CDC/HICPAC IB) (Need to resolve inconsistency based on TEP advice.)
- Weigh the risks and benefits of placing a central venous device at a recommended site to reduce infectious complications against the risk for mechanical complications (e.g., pneumothorax, subclavian artery puncture, subclavian vein laceration, subclavian vein stenosis, hemothorax, thrombosis, air embolism, and catheter misplacement) (CDC/HICPAC IA)
- Avoid the subclavian site in hemodialysis patients and patients with advanced kidney disease, to avoid subclavian vein stenosis (CDC/HICPAC IA)
- Use a fistula or graft in patients with chronic renal failure instead of a CVC for permanent access for dialysis (CDC/HICPAC IA)
- Use ultrasound guidance to place central venous catheters (if this technology is available) to reduce the number of cannulation attempts and mechanical complications. Ultrasound guidance should only be used by those fully trained in its technique. (CDC/HICPAC IB)
- Use a CVC with the minimum number of ports or lumens essential for the management of the patient. (CDC/HICPAC IB)
- When adherence to aseptic technique cannot be ensured (i.e. catheters inserted during a medical emergency), replace the catheter as soon as possible, that is, within 48 hours. (CDC/HICPAC IB)
- Maintain aseptic technique for the insertion and care of intravascular catheters. (CDC/HICPAC IB)
- Antiseptics should be allowed to dry according to the manufacturer's recommendation prior to placing the catheter. (CDC/HICPAC IB)
- Use either sterile gauze or sterile, transparent, semipermeable dressing to cover the catheter site. (CDC/HICPAC IA)
- Replace catheter site dressing if the dressing becomes damp, loosened, or visibly soiled. (CDC/HICPAC IB)
- Do not submerge the catheter or catheter site in water. Showering should be permitted if precautions can be taken to reduce the likelihood of introducing organisms into the catheter (e.g., if the catheter and connecting device are protected with an impermeable cover during the shower). (CDC/HICPAC IB)
- Ensure that catheter site care is compatible with the catheter material. (CDC/HICPAC IB)
- Monitor the catheter sites visually when changing the dressing or by palpation through an intact dressing on a regular basis, depending on the clinical situation of the individual patient. If patients have tenderness at the insertion site, fever without obvious source, or other manifestations suggesting local or bloodstream infection, the dressing should be removed to allow thorough examination of the site. (CDC/HICPAC IB)
- Do not routinely replace CVCs, PICCs, hemodialysis catheters, or pulmonary artery catheters to prevent catheter-related infections. (CDC/HICPAC IB)
- Do not use guidewire exchanges routinely for non-tunneled catheters to prevent infection. (CDC/HICPAC IB)
- Do not use guidewire exchanges to replace a non-tunneled catheter suspected of infection. (CDC/HICPAC IB)
- Use a guidewire exchange to replace a malfunctioning non-tunneled catheter if no evidence of infection is present. (CDC/HICPAC IB)
- Ventilator-associated pneumonia:
- semirecumbent patient positioning (2007 report)
- daily assessment of readiness for ventilator weaning (2007 report)
- perform antiseptic oral care (CDC/HICPAC A-I)
- Catheter-associated urinary tract infection
- reduction in unnecessary catheter use (2007 report)
- adherence to aseptic catheter insertion and catheter care (2007 report)
- maintain a closed drainage system and maintain unobstructed urine flow (CDC/HICPAC IB); do not disconnect unless irrigation needed (SHEA/IDSA A-I)

[underlined: CDC/HICPAC definitions for rating recommendations in above list]:

Category IA. Strongly recommended for implementation and strongly supported by well-designed experimental, clinical, or epidemiologic studies.

Category IB. Strongly recommended for implementation and supported by certain experimental, clinical, or epidemiologic studies and a strong theoretical rationale.

[underlined: SHEA/IDSA definitions for rating recommendations in above list]:

Strength of recommendation:

A. good evidence to support recommendation

Quality of evidence:

I. evidence from ≥ 1 properly randomized controlled trial
II. evidence from ≥ 1 well-designed clinical trial w/out randomization; cohort or case-control analytic studies (preferably from > 1 center); multiple time series; or dramatic results from uncontrolled experiments