# Evidence Tables^3^ 3 Tables for studies identified during the updated search are found in the tables at the end of this appendix.

Appendix Table C1a Study characteristics for VAP which control for secular trend or confounding

Appendix Table C1b Study characteristics for CLABSI which control for secular trend or confounding

Appendix Table C1c Study characteristics for SSI which control for secular trend or confounding

Appendix Table C1d Study characteristics for CAUTI which control for secular trend or confounding

Appendix Table C2a Patient characteristics for VAP which control for secular trend or confounding

Appendix Table C2b Patient characteristics for CLABSI which control for secular trend or confounding

Appendix Table C2c Patient characteristics for SSI which control for secular trend or confounding

Appendix Table C2d Patient characteristics for CAUTI which control for secular trend or confounding

Appendix Table C3a Intervention characteristics for VAP which control for secular trend or confounding

Appendix Table C3b Intervention characteristics for CLABSI which control for secular trend or confounding

Appendix Table C3c Intervention characteristics for SSI which control for secular trend or confounding

Appendix Table C3d Intervention characteristics for CAUTI which control for secular trend or confounding

Appendix Table C4a Study context for VAP which control for secular trend or confounding

Appendix Table C4b Study context for CLABSI which control for secular trend or confounding

Appendix Table C4c Study context for SSI which control for secular trend or confounding

Appendix Table C4d Study context for CAUTI which control for secular trend or confounding

Appendix Table C5a(1) Infection rate outcomes for VAP which control for secular trend or confounding

Appendix Table C5a(2) Infection rate outcomes for CLABSI which control for secular trend or confounding

Appendix Table C5a(3) Infection rate outcomes for SSI which control for secular trend or confounding

Appendix Table C5a(4) Infection rate outcomes for CAUTI which control for secular trend or confounding

Appendix Table C5b(1) Adherence outcomes for VAP which control for secular trend or confounding

Appendix Table C5b(2) Adherence outcomes for CLABSI which control for secular trend or confounding

Appendix Table C5b(3) Adherence outcomes for SSI which control for secular trend or confounding

Appendix Table C5b(4) Adherence outcomes for CAUTI which control for secular trend or confounding

Appendix Table C5c(1) Cost/savings outcomes for VAP which control for secular trend or confounding

Appendix Table C5c(2) Cost/savings outcomes for CLABSI which control for secular trend or confounding

Appendix Table C5c(3) Cost/savings outcomes for SSI which control for secular trend or confounding

Appendix Table C5c(4) Cost/savings outcomes for CAUTI which control for secular trend or confounding

Appendix Table C6a(1) Quality ratings for nonrandomized studies on VAP which control for secular trend or confounding

Appendix Table C6a(2) Quality ratings for randomized study on VAP

Appendix Table C6b(1) Quality ratings for nonrandomized studies on CLABSI which control for secular trend or confounding

Appendix Table C6b(2) Quality ratings for randomized study on CLABSI

Appendix Table C6c(1) Quality ratings for nonrandomized studies on SSI which control for secular trend or confounding

Appendix Table C6c(2) Quality ratings for randomized study on SSI

Appendix Table C6d(1) Quality ratings for nonrandomized studies on CAUTI which control for secular trend or confounding

Appendix Table C6d(2) Quality ratings for randomized study on CAUTI

Appendix Table C1-LQ-a Study characteristics for VAP which do not control for secular trend or confounding

Appendix Table C1-LQ-b Study characteristics for CLABSI which do not control for secular trend or confounding

Appendix Table C1-LQ-c Study characteristics for SSI which do not control for secular trend or confounding

Appendix Table C1-LQ-d Study characteristics for CAUTI which do not control for secular trend or confounding

Appendix Table C2-LQ-a Patient characteristics for VAP which do not control for secular trend or confounding

Appendix Table C2-LQ-b Patient characteristics for CLABSI which do not control for secular trend or confounding

Appendix Table C2-LQ-c Patient characteristics for SSI which do not control for secular trend or confounding

Appendix Table C2-LQ-d Patient characteristics for CAUTI which do not control for secular trend or confounding

Appendix Table C3-LQ-a Intervention characteristics for VAP which do not control for secular trend or confounding

Appendix Table C3-LQ-b Intervention characteristics for CLABSI which do not control for secular trend or confounding

Appendix Table C3-LQ-c Intervention characteristics for SSI which do not control for secular trend or confounding

Appendix Table C3-LQ-d Intervention characteristics for CAUTI which do not control for secular trend or confounding

Appendix Table C4-LQ-a Study context for VAP which do not control for secular trend or confounding

Appendix Table C4-LQ-b Study context for CLABSI which do not control for secular trend or confounding

Appendix Table C4-LQ-c Study context for SSI which do not control for secular trend or confounding

Appendix Table C4-LQ-d Study context for CAUTI which do not control for secular trend or confounding

Appendix Table C5a-LQ(1) Infection rate outcomes for VAP which do not control for secular trend or confounding

Appendix Table C5a-LQ(2) Infection rate outcomes for CLABSI which do not control for secular trend or confounding

Appendix Table C5a-LQ(3) Infection rate outcomes for SSI which do not control for secular trend or confounding

Appendix Table C5a-LQ(4) Infection rate outcomes for CAUTI which do not control for secular trend or confounding

Appendix Table C5b-LQ(1) Adherence outcomes for VAP which do not control for secular trend or confounding

Appendix Table C5b-LQ(2) Adherence outcomes for CLABSI which do not control for secular trend or confounding

Appendix Table C5b-LQ(3) Adherence outcomes for SSI which do not control for secular trend or confounding

Appendix Table C5b-LQ(4) Adherence outcomes for CAUTI which do not control for secular trend or confounding

Appendix Table C5c-LQ(1) Cost/savings outcomes for VAP which do not control for secular trend or confounding

Appendix Table C5c-LQ(2) Cost/savings outcomes for CLABSI which do not control for secular trend or confounding

Appendix Table C5c-LQ(3) Cost/savings outcomes for SSI which do not control for secular trend or confounding

Appendix Table C5c-LQ(4) Cost/savings outcomes for CAUTI which do not control for secular trend or confounding

Appendix Table C6-LQ-a Quality ratings for VAP which do not control for secular trend or confounding

Appendix Table C6-LQ-b Quality ratings for CLABSI which do not control for secular trend or confounding

Appendix Table C6-LQ-c Quality ratings for SSI which do not control for secular trend or confounding

Appendix Table C6-LQ-d Quality ratings for CAUTI which do not control for secular trend or confounding

AppendixTable C1a-Update Study characteristics for VAP which control for secular trend or confounding from the update search

AppendixTable C1b-Update Study characteristics for CLABSI which control for secular trend or confounding from the update search

Appendix Table C1c-Update Study characteristics for SSI which control for secular trend or confounding from the update search

Appendix Table C1d-Update Study characteristics for CAUTI which control for secular trend or confounding from the update search

Appendix Table C2a-Update Patient characteristics for VAP which control for secular trend or confounding from the update search

Appendix Table C2b-Update Patient characteristics for CLABSI which control for secular trend or confounding from the update search

Appendix Table C2c-Update Patient characteristics for SSI which control for secular trend or confounding from the update search

Appendix Table C2d-Update Patient characteristics for CAUTI which control for secular trend or confounding from the update search

Appendix Table C3a-Update Intervention characteristics for VAP which control for secular trend or confounding from the update search

Appendix Table C3b-Update Intervention characteristics for CLABSI which control for secular trend or confounding from the update search

Appendix Table C3c-Update Intervention characteristics for SSI which control for secular trend or confounding from the update search

Appendix Table C3d-Update Intervention characteristics for CAUTI which control for secular trend or confounding from the update search

Appendix Table C4a-Update Study context for VAP which control for secular trend or confounding from the update search

Appendix Table C4b-Update Study context for CLABSI which control for secular trend or confounding from the update search

Appendix Table C4c-Update Study context for SSI which control for secular trend or confounding from the update search

Appendix Table C4d-Update Study context for CAUTI which control for secular trend or confounding from the update search

Appendix Table C5a(1)-Update Infection outcomes for VAP which control for secular trend or confounding from the update search

Appendix Table C5a(2)-Update Infection outcomes for CLABSI which control for secular trend or confounding from the update search

Appendix Table C5a(3)-Update Infection outcomes for SSI which control for secular trend or confounding from the update search

Appendix Table C5a(4)-Update Infection outcomes for CAUTI which control for secular trend or confounding from the update search

Appendix Table C5b(1)-Update Adherence outcomes for VAP which control for secular trend or confounding from the update search

Appendix Table C5b(2)-Update Adherence outcomes for CLABSI which control for secular trend or confounding from the update search

Appendix Table C5b(3)-Update Adherence outcomes for SSI which control for secular trend or confounding from the update search

Appendix Table C5b(4)-Update Adherence outcomes for CAUTI which control for secular trend or confounding from the update search

Appendix Table C5c(1)-Update Cost/savings outcomes for VAP which control for secular trend or confounding from the update search

Appendix Table C5c(2)-Update Cost/savings outcomes for CLABSI which control for secular trend or confounding from the update search

Appendix Table C5c(3)-Update Cost/savings outcomes for SSI which control for secular trend or confounding from the update search

Appendix Table C5c(4)-Update Cost/savings outcomes for CAUTI which control for secular trend or confounding from the update search

Appendix Table C6a-Update Study quality for VAP which control for secular trend or confounding from the update search

Appendix Table C6b-Update Study quality for CLABSI which control for secular trend or confounding from the update search

Appendix Table C6c-Update Study quality for SSI which control for secular trend or confounding from the update search

Appendix Table C6d-Update Study quality for CAUTI which control for secular trend or confounding from the update search

Appendix Table C1-Update LQ-a Study characteristics for VAP which do not control for secular trend or confounding from the update search

Appendix Table C1-Update LQ-b Study characteristics for CLABSI which do not control for secular trend or confounding from the update search

Appendix Table C1-Update LQ-c Study characteristics for SSI which do not control for secular trend or confounding from the update search

Appendix Table C1-Update LQ-d Study characteristics for CAUTI which do not control for secular trend or confounding from the update search