# Excluded Studies

[No Author]. Case study. Implementing IHI's six interventions: contributing to the campaign to save 100,000 lives. Joint Commission Perspectives on Patient Safety. 2006;6(2):9-10. Exclusion Codes: COMMENTARY.
[No Author]. New York hospitals cut central line infections in half. Perform Improv Advis. 2006;10(6):61-7. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 16848366].
[No Author]. Using computer's data to guide OR QI. OR Manager. 2006;22(7):18. Exclusion Codes: GUIDELINE.
[No Author]. Decreasing surgical site infections in ambulatory care: using data to identify and address issues. Joint Commission Perspectives on Patient Safety. 2007;7(2):9. Exclusion Codes: NOT RELEVANT QUESTION.
[No Author]. Hospital factors bigger than patient severity of illness: HAIs ‘not necessarily inevitable’. Hospital Infection Control. 2007;34(1):3-3. Exclusion Codes: COMMENTARY.
[No Author]. Link seen between working conditions, infections: higher staffing numbers yield improved outcomes. Healthcare Benchmarks & Quality Improvement. 2007;14(9):106-108. Exclusion Codes: COMMENTARY. [pmid: 17849657].
[No Author]. Ventilator-associated pneumonia. Crit Care Nurse. 2008;28(3):83-5. Exclusion Codes: GUIDELINE. [pmid: 18515611].
[No Author]. Antimicrobial prophylaxis for surgery. Treat Guidel Med Lett. 2009;7(82):47-52. Exclusion Codes: GUIDELINE. [pmid: 19461558].
[No Author]. Intervention leads to reduction in central venous catheter-associated blood stream infections for pediatric patients. AHRQ Research Activities. 2009;(351):4-5. Exclusion Codes: COMMENTARY.
[No Author]. Quality improvement collaborative fails to improve infection prevention in surgical patients. AHRQ Research Activities. 2009;(344):6-6. Exclusion Codes: LETTER.
[No Author]. Methodology for a study of structured co-management of high-risk postoperative patients in a teaching hospital. Crit Care Resusc. 2010;12(4):277-86. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21143090].
[No author]. In brief. Nursing Standard. 2011;26(4):8-8. Exclusion Codes: LETTER TO EDITOR.
[No author]. University of Kansas Improves compliance with the SCIP Infection Antibiotic Core Measures. Joint Commission Benchmark. 2011;13(4):4-6. Exclusion Codes: EDITORIAL.
Abdel-Galil K. The WHO Surgical Safety Checklist: are we measuring up?. British Journal of Oral and Maxillofacial Surgery. 2010;48(5):397-398. Exclusion Codes: LETTER. [pmid: 20153096].
Abouzari M, Sodagari N, Hasibi M, et al. Re: Nonshaved cranial surgery in black Africans: a short-term prospective preliminary study (Adeleye and Olowookere, Surg Neurol 2008;69-72). Effect of hair on surgical wound infection after cranial surgery: a 3-armed randomized clinical trial. Surgical Neurology. 2009;71(2):261-262. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18440617].
Abreu M, Kawagoe JY, De Menezes FG, et al. Continuous quality improvement program on healthcare-associated infections in a neonatal intensive care unit: A 16-year experience. American Journal of Infection Control. 2011;39(5):E84-E85. Exclusion Codes: NO STATISTICAL ANALYSIS.
Acosta-Escribano J, Fernandez-Vivas M, Grau, et al. Gastric versus transpyloric feeding in severe traumatic brain injury: A prospective, randomized trial. Intensive Care Medicine. 2010;36(9):1532-1539. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20495781].
Agodi A, Auxilia F, Barchitta M, et al. Risk factors for surgical site infections in hip and knee arthroprosthesis: Role of microbial air contamination and adherence to guidelines for antimicrobial prophylaxis. Clinical Microbiology and Infection. 2011;17:S757-S758. Exclusion Codes: ABSTRACT ONLY.
Agrawal S, Williams A. Implementing the ventilator bundle from Patient Safety First to improve critical care. Nurs Times. 2009;105(36):19. Exclusion Codes: GUIDELINE. [pmid: 19835195].
Aguilar-Nascimento JE, Marra JG, Slhessarenko N, et al. Efficacy of National Nosocomial Infection Surveillance score, acute-phase proteins, and interleukin-6 for predicting postoperative infections following major gastrointestinal surgery. Sao Paulo Med J. 2007;125(1):34-41. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17505683].
Aguilar-Nascimento JE, Salomao AB, Caporossi C, et al. Clinical benefits after the implementation of a multimodal perioperative protocol in elderly patients. Arq Gastroenterol. 2010;47(2):178-83. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20721464].
al Awa B, de Wever A, Almazrooa A, et al. The impact of accreditation on patient safety and quality of care indicators at King Abdulaziz University Hospital in Saudi Arabia. Research Journal of Medical Sciences. 2011;5(1):43-51. Exclusion Codes: NOT RELEVANT QUESTION.
Al Raiy B, Fakih MG, Bryan-Nomides N, et al. Peripherally inserted central venous catheters in the acute care setting: a safe alternative to high-risk short-term central venous catheters. American Journal of Infection Control. 2010;38(2):149-153. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19836854].
Alberato Rosalind, Delatte Holly, Steele-Moses Susan, Murphree Paul. Decreasing urinary tract infections one indwelling catheter at a time: a hospital based skilled nursing unit performance improvement program. Pelican News. 2010;66(4):8-8. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS.
Alexandrou E, Spencer T, Davidson P. Nursing central line service prevents catheter related infections. Australian Nursing Journal. 2008;15(11):49-49. Exclusion Codes: EDITORIAL.
Alexiou VG, Ierodiakonou V, Dimopoulos G, et al. Impact of patient position on the incidence of ventilator-associated pneumonia: a Meta-analysis of randomized controlled trials. J Crit Care. 2009;24(4):515-22. Exclusion Codes: META-ANALYSIS. [pmid: 19327314].
Alp E, Leblebicioglu H, Doganay M, et al. Infection control practice in countries with limited resources. Annals of Clinical Microbiology and Antimicrobials. 2011;10. Exclusion Codes: SYSTEMATIC REVIEW.
Al-Momany NH, Al-Bakri AG, Makahleh ZM, et al. Adherence to international antimicrobial prophylaxis guidelines in cardia surgery: A Jordanian study demonstrates need for quality improvement. Journal of Managed Care Pharmacy. 2009;15(3):262-271. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 19326957].
Al-Momany NH, Al-Bakri AG, Makahleh ZM, et al. Adherence to international antimicrobial prophylaxis guidelines in cardiac surgery: a jordanian study demonstrates need for quality improvement. Journal of Managed Care Pharmacy. 2009;15(3):262-271. Exclusion Codes: EDITORIAL. [pmid: 19326957].
Alsaghir AH, Martin CM. Effect of prone positioning in patients with acute respiratory distress syndrome: a Meta-analysis. Crit Care Med. 2008;36(2):603-9. Exclusion Codes: META-ANALYSIS. [pmid: 18216609].
Al-Tawfiq JA, Abed MS. Decreasing ventilator-associated pneumonia in adult intensive care units using the Institute for Healthcare Improvement bundle. Am J Infect Control. 2010;38(7):552-6. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 20400203].
Aly H, Badawy M, El-Kholy A, et al. Randomized, controlled trial on tracheal colonization of ventilated infants: can gravity prevent ventilator-associated pneumonia?. Pediatrics. 2008;122(4):770-4. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18829800].
Amarasingham R, Pronovost PJ, Diener-West M, et al. Measuring clinical information technology in the ICU setting: application in a quality improvement collaborative. J Am Med Inform Assoc. 2007;14(3):288-94. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17329726].
Ames NJ. Evidence to support tooth brushing in critically ill patients. Am J Crit Care. 2011;20(3):242-50. Exclusion Codes: SYSTEMATIC REVIEW. [pmid: 21532045].
Anchalia MM, D'Ambruoso L. Seeking solutions: scaling-up audit as a quality improvement tool for infection control in Gujarat, India. Int J Qual Health Care. 2011;23(4):464-70. Exclusion Codes: NO STATISTICAL ANALYSIS. [pmid: 21486857].
Anderson DJ, Kaye KS, Classen D, et al. Strategies to prevent surgical site infections in acute care hospitals. Infect Control Hosp Epidemiol. Suppl 1. 2008;29:S51-61. Exclusion Codes: GUIDELINE. [pmid: 18840089].
Anderson Deverick J, Miller Becky A, Chen Luke F, et al. The network approach for prevention of healthcare-associated infections: long-term effect of participation in the duke infection control outreach network. Infection Control & Hospital Epidemiology. 2011;32(4):315-322. Exclusion Codes: NO BASELINE DATA. [pmid: 21460482].
Anderson DJ, Miller BA, Chen LF, et al. The network approach for prevention of healthcare-associated infections: Long-term effect of participation in the Duke Infection Control Outreach Network. Infection Control and Hospital Epidemiology. 2011;32(4):315-322. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 21460482].
Andrews A, Valente A. Accelerating best care in Pennsylvania: the Hazleton General Hospital experience. American Journal of Medical Quality. 2008;23(4):259-265. Exclusion Codes: COMMENTARY. [pmid: 18658098].
Ang L, Laskar R, Gray JW. A point prevalence study of infection and antimicrobial use at a UK children's hospital. Journal of Hospital Infection. 2008;68(4):372-374. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18353500].
Anthony T, Murray BW, Sum-Ping JT, et al. Evaluating an evidence-based bundle for preventing surgical site infection: a randomized trial. Arch Surg. 2011;146(3):263-9. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21079110].
Apisarnthanarak A, Srichomkwun P, Sutepvarnon A, et al. The long-term outcomes of an antibiotic control program with and without education [6]. Clinical Infectious Diseases. 2007;45(9):1245-1247. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17918096].
Apisarnthanarak A, Suwannakin A, Maungboon P, et al. Long-term outcome of an intervention to remove unnecessary urinary catheters, with and without a quality improvement team, in a Thai tertiary care center. Infect Control Hosp Epidemiol. 2008;29(11):1094-5. Exclusion Codes: LETTER. [pmid: 18947323].
Arabi Y, Haddad S, Hawes R, et al. Changing sedation practices in the intensive care unit--protocol implementation, multifaceted multidisciplinary approach and teamwork. Middle East J Anesthesiol. 2007;19(2):429-47. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17684883].
Arriaga AF, Lancaster RT, Berry WR, et al. The better colectomy project: Association of evidence-based best-practice adherence rates to outcomes in colorectal surgery. Annals of Surgery. 2009;250(4):507-512. Exclusion Codes: NOT RELEVANT DESIGN. [pmid: 19734778].
Arroliga AC, Pollard CL, Wilde CD, et al. Reduction in the Incidence of Ventilator-Associated Pneumonia (VAP): A Multidisciplinary Approach. Respir Care. 2011. Exclusion Codes: NOT RELEVANT DESIGN.
Astle CM, Jensen L. A trial of EXSEPT for hemodialysis central venous catheters. Nephrology Nursing Journal. 2005;32([5]):517-525. Exclusion Codes: NOT RELEVANT QUESTION.
Augustyn B. Ventilator-associated pneumonia: risk factors and prevention. Crit Care Nurse. 2007;27(4):32-6. 38. 9. quiz 40. Exclusion Codes: REVIEW ARTICLE. [pmid: 17671243].
Babayan RK. Re: Evaluating an evidence-based bundle for preventing surgical site infection: a randomized trial. J Urol. 2011;186(6):2266. Exclusion Codes: COMMENTARY. [pmid: 22078592].
Babayan RK. Improving surgical site infections: Using national surgical quality improvement program data to institute surgical care improvement project protocols in improving surgical outcomes. Journal of Urology. 2011;185(2):541. Exclusion Codes: LETTER.
Balamongkhon B, Thamlikitkul V. Implementation of chlorhexidine gluconate for central venous catheter site care at Siriraj Hospital, Bangkok, Thailand. Am J Infect Control. 2007;35(9):585-8. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17980236].
Balonov K, Miller AD, Lisbon A, et al. A novel Method of continuous measurement of head of bed elevation in ventilated patients. Intensive Care Med. 2007;33(6):1050-4. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17393138].
Banerjee S, Shen B, Baron TH, et al. Antibiotic prophylaxis for GI endoscopy. Gastrointest Endosc. 2008;67(6):791-8. Exclusion Codes: GUIDELINE. [pmid: 18374919].
Barie PS. Breaking with tradition: Evidence-based antibiotic prophylaxis of open fractures. Surgical Infections. 2006;7(4):327-329. Exclusion Codes: EDITORIAL. [pmid: 16978075].
Barie PS. Infection control practices in ambulatory surgical centers. JAMA - Journal of the American Medical Association. 2010;303(22):2295-2297. Exclusion Codes: LETTER.
Barrell C, Covington L, Bhatia M, et al. Preventive strategies for central line-associated bloodstream infections in pediatric hematopoietic stem cell transplant recipients. Am J Infect Control. 2011. Exclusion Codes: SAMPLE SIZE UNDER 100.
Barria RM, Lorca P, Munoz S. Randomized controlled trial of vascular access in newborns in the neonatal intensive care unit. J Obstet Gynecol Neonatal Nurs. 2007;36(5):450-6. Exclusion Codes: NOT RELEVANT INTERVENTION.
Barrow C. A patient's journey through the operating department from an infection control perspective. J Perioper Pract. 2009;19(3):94-8. Exclusion Codes: EDITORIAL. [pmid: 19397060].
Barwolff S, Sohr D, Geffers C, et al. Reduction of surgical site infections after Caesarean delivery using surveillance. J Hosp Infect. 2006;64(2):156-61. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16899325].
Battistella M, Bhola C, Lok CE. Long-term follow-up of the Hemodialysis Infection Prevention with Polysporin Ointment (HIPPO) study: A quality improvement report. American Journal of Kidney Diseases. 2011;57(3):432-441. Exclusion Codes: NOT RELEVANT INTERVENTION STRATEGY. [pmid: 21216512].
Bearfield P, McDonald I, Carrington M, et al. Ventilator associated pneumonia and adherence to a high impact ventilator care bundle-an observational study. Intensive Care Medicine. 2011;37:S275. Exclusion Codes: ABSTRACT ONLY.
Bearman LGM, Munro C, Sessler CN, Wenzel RP. Infection control and the prevention of nosocomial infections in the intensive care unit. Seminars in Respiratory and Critical Care Medicine. 2006;27(3):310-324. Exclusion Codes: GUIDELINE. [pmid: 16791763].
Bearman LGM, Marra AR, Sessler CN, Smith WR, Rosato A, Laplante JK, Wenzel RP, Edmond MB. A controlled trial of universal gloving versus contact precautions for preventing the transmission of multidrug-resistant organisms. American Journal of Infection Control. 2007;35(10):650-655. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18063129].
Behta M, Ross B, Hong F, et al. Automated identification, tracking and reporting of central line-associated blood streams infection to comply with required New York State reporting. AMIA Annu Symp Proc. 2007:869. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18693970].
Beldi G, Bisch-Knaden S, Banz V, et al. Impact of intraoperative behavior on surgical site infections. Am J Surg. 2009;198(2):157-62. Exclusion Codes: focus on preventative intervention. [pmid: 19285307].
Bellissimo-Rodrigues F, Bellissimo-Rodrigues WT, Viana JM, et al. Effectiveness of oral rinse with chlorhexidine in preventing nosocomial respiratory tract infections among intensive care unit patients. Infection Control and Hospital Epidemiology. 2009;30(10):952-958. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19743899].
Beltramini AM, Salata RA, Ray AJ. Thermoregulation and risk of surgical site infection. Infection Control & Hospital Epidemiology. 2011;32(6):603-610. Exclusion Codes: SYSTEMATIC REVIEW. [pmid: 21558774].
Berenholtz SM, Pham JC, Thompson DA, et al. Collaborative cohort study of an intervention to reduce ventilator-associated pneumonia in the intensive care unit. Infection Control & Hospital Epidemiology. 2011;32(4):305-314. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 21460481].
Berger E. Value over volume: Value-based purchasing brings financial incentives for 13 core quality measures. Annals of Emergency Medicine. 2011;58(6):19A-21A. Exclusion Codes: LETTER TO EDITOR.
Berger RE. Evaluating an evidence-based bundle for preventing surgical site infection: A randomized trial. Journal of Urology. 2011;185(6):2178. Exclusion Codes: COMMENTARY.
Bernstein J, Meller MM. Antimicrobial prophylaxis to prevent surgical site infection. J Bone Joint Surg Am. 2006;88(5):1149-50. discussion 1150-2. Exclusion Codes: LETTER. [pmid: 16651591].
Berra L, Cressoni M, Li Bassi G, et al. Continuous lateral rotation therapy to prevent ventilator-associated pneumonia: the neglected effects of gravity on pathogenesis of ventilator-associated pneumonia. Crit Care Med. 2010;38(3):1018-9. author reply 1019. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20168183].
Berriel-Cass D, Adkins FW, Jones P, et al. Clinical excellence series. Eliminating nosocomial infections at Ascension Health. Joint Commission Journal on Quality & Patient Safety. 2006;32(11):612-620. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 17120920].
Betts P, Brink S, Silink M, et al. Management of children and adolescents with diabetes requiring surgery. Pediatr Diabetes. Suppl 12. 2009;10:169-74. Exclusion Codes: GUIDELINE. [pmid: 19754627].
Biese KJ, Roberts E, LaMantia M, et al. Effect of a geriatric curriculum on emergency medicine resident attitudes, knowledge, and decision-making. Acad Emerg Med. Suppl 2. 2011;18:S92-6. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 21999564].
Bigsby E, Lindsay W, Pentlow A, et al. Communication and adherence to prophylactic antibiotic guidelines in patients with a proximal femoral fracture. J Hosp Infect. 2010;76(2):185-7. Exclusion Codes: LETTER TO EDITOR. [pmid: 20705363].
Bingham M, Ashley J, De Jong M, et al. Implementing a unit-level intervention to reduce the probability of ventilator-associated pneumonia. Nurs Res. 2010;59(1 Suppl):S40-7. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 20010277].
Birch P, Ogden S, Hewson M. A randomised, controlled trial of heparin in total parenteral nutrition to prevent sepsis associated with neonatal long lines: the Heparin in Long Line Total Parenteral Nutrition (HILLTOP) trial. Arch Dis Child Fetal Neonatal Ed. 2010;95(4):F252-7. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20530110].
Bizzarro MJ, Sabo B, Noonan M, et al. A quality improvement initiative to reduce central line-associated bloodstream infections in a neonatal intensive care unit. Infection Control & Hospital Epidemiology. 2010;31(3):241-248. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 20102278].
Blot F, Gachot B, Nitenberg G. Are urokinase rinses needed to reduce catheter-related bloodstream infections when standard preventive guidelines are observed?. J Clin Oncol. 2008;26(14):2415-6. author reply 2416. Exclusion Codes: EDITORIAL. [pmid: 18467738].
Blot S, Labeau S, Vandijck D. Implementation of guidelines for the prevention of ventilator-associated pneumonia. Am Surg. 2008;74(2):183-4. author reply 184. Exclusion Codes: LETTER. [pmid: 18306875].
Boltz MM, Hollenbeak CS, Julian KG, et al. Hospital costs associated with surgical site infections in general and vascular surgery patients. Surgery. 2011;150(5):934-42. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21676424].
Bonello RS, Fletcher CE, Becker WK, et al. An intensive care unit quality improvement collaborative in nine Department of Veterans Affairs hospitals: reducing ventilator-associated pneumonia and catheter-related bloodstream infection rates. Joint Commission Journal on Quality & Patient Safety. 2008;34(11):639-645. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 19025084].
Bonten MJ. Prevention of ventilator-associated pneumonia: bugs or drugs?. Am J Respir Crit Care Med. 2010;182(8):993-4. Exclusion Codes: EDITORIAL. [pmid: 20947907].
Bopp M, Darby M, Loftin KC, Broscious S. Effects of daily oral care with 0.12% chlorhexidine gluconate and a standard oral care protocol on the development of nosocomial pneumonia in intubated patients: a pilot study. J Dent Hyg. 2006;80(3):9. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 16953990].
Borghesi A, Stronati M. Strategies for the prevention of hospital-acquired infections in the neonatal intensive care unit. Journal of Hospital Infection. 2009;71(1):96-97. Exclusion Codes: LETTER.
Boriboonhirunsarn D, Lauwahutanont P, Kaewmanee K, et al. Usage of prophylactic antibiotics in uncomplicated gynecologic abdominal surgery in Siriraj hospital. J Med Assoc Thai. 2007;90(6):1068-73. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17624198].
Borschel DM, Chenoweth CE, Kaufman SR, et al. Are antiseptic-coated central venous catheters effective in a real-world setting?. Am J Infect Control. 2006;34(6):388-93. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16877109].
Bouadma L, Mourvillier B, Deiler V, et al. Changes in knowledge, beliefs, and perceptions throughout a multifaceted behavioral program aimed at preventing ventilator-associated pneumonia. Intensive Care Med. 2010;36(8):1341-7. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20431867].
Bouadma L, Mourvillier B, Deiler V, et al. A multifaceted program to prevent ventilator-associated pneumonia: impact on compliance with preventive measures. Crit Care Med. 2010;38(3):789-96. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 20068461].
Bowater RJ, Stirling SA, Lilford RJ. Is antibiotic prophylaxis in surgery a generally effective intervention? Testing a generic hypothesis over a set of Meta-analyses. Ann Surg. 2009;249(4):551-6. Exclusion Codes: META-ANALYSIS. [pmid: 19300236].
Bowton DL. Resolution of ventilator-associated pneumonia: is my patient getting better?. Crit Care Med. 2010;38(1):308-9. Exclusion Codes: EDITORIAL. [pmid: 20023475].
Boyer DR, Steltzer N, Larrabee JH. Implementation of an evidence-based bladder scanner protocol. J Nurs Care Qual. 2009;24(1):10-6. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19092473].
Bozikis MR, Braun BI, Kritchevsky SB. How accurately are starting times documented in the medical record? Implications for surgical infection prevention performance measurement. Infection Control and Hospital Epidemiology. 2010;31(3):307-309. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 20102277].
Brandt C, Sohr D, Behnke M, et al. Reduction of surgical site infection rates associated with active surveillance. Infect Control Hosp Epidemiol. 2006;27(12):1347-51. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17152033].
Brandt C, Hott U, Sohr D, et al. Operating room ventilation with laminar airflow shows no protective effect on the surgical site infection rate in orthopedic and abdominal surgery. Ann Surg. 2008;248(5):695-700. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18948793].
Brandt C, Ruden H, Gastmeier P. Protective Effect of HEPA-Filtered Operating Room Air Ventilation With or Without Laminar Airflow on Surgical Site Infections. Ann Surg. 2009. Exclusion Codes: NOT RELEVANT INTERVENTION.
Braudis N, Franey K, Ahern J, et al. Establishing nurse-sensitive quality metrics for the pediatric cardiovascular ICU. Pediatric Critical Care Medicine. 2011;12(4):S91. Exclusion Codes: ABSTRACT ONLY.
Brilli RJ, Sparling KW, Lake MR, et al. The business case for preventing ventilator-associated pneumonia in pediatric intensive care unit patients. Jt Comm J Qual Patient Saf. 2008;34(11):629-38. Exclusion Codes: NOT RELEVANT DESIGN. [pmid: 19025083].
Brito V, Niederman MS. Standardized care for nosocomial pneumonia is a valuable tool to improve patient outcomes: How do we get intensivists to listen?. Critical Care Medicine. 2009;37(1):350-352. Exclusion Codes: COMMENTARY. [pmid: 19112300].
Brokenshire E, Plank LD, Gillanders LK, et al. Adult total parenteral nutrition at Auckland City Hospital: a 6-year review. N Z Med J. 2009;122(1297):17-24. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19648998].
Brooke BS, Meguid RA, Makary MA, et al. Improving surgical outcomes through adoption of evidence-based process measures: intervention specific or associated with overall hospital quality?. Surgery. 2010;147(4):481-90. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20004443].
Brun-Buisson C. Preventing ventilator associated pneumonia. BMJ. 2007;334(7599):861-2. Exclusion Codes: EDITORIAL. [pmid: 17463422].
Brungs SM, Render ML. Using evidence-based practice to reduce central line infections. Clin J Oncol Nurs. 2006;10(6):723-5. Exclusion Codes: GUIDELINE. [pmid: 17193938].
Buffet-Bataillon S, Haegelen C, Riffaud L, et al. Impact of surgical site infection surveillance in a neurosurgical unit. Journal of Hospital Infection. 2011;77(4):352-355. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21277651].
Bull AL, Russo PL, Friedman ND, et al. Compliance with surgical antibiotic prophylaxis--reporting from a Statewide surveillance programme in Victoria, Australia. J Hosp Infect. 2006;63(2):140-7. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 16621135].
Burden N. Some is not a number, soon is not a time: saving lives in America's health care facilities. J Perianesth Nurs. 2006;21(3):200-3. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16769529].
Burger CD, Resar RK. “Ventilator bundle” approach to prevention of ventilator-associated pneumonia. Mayo Clin Proc. 2006;81(6):849-50. Exclusion Codes: LETTER. [pmid: 16770987].
Burgher AH, Barnett CF, Obray JB, et al. Introduction of infection control measures to reduce infection associated with implantable pain therapy devices. Pain Pract. 2007;7(3):279-84. Exclusion Codes: N<100. [pmid: 17714108].
Burns A, Bowers L, Pak N, et al. The excess cost associated with healthcare-associated bloodstream infections at Auckland City Hospital. New Zealand Medical Journal. 2010;123(1324):17-24. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20953218].
Burton DC, Edwards JR, Srinivasan A, et al. Trends in catheter-associated urinary tract infections in adult intensive care units-United states, 1990-2007. Infection Control & Hospital Epidemiology. 2011;32(8):748-756. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21768757].
Butler T. Professional nurses can and must prevent urinary tract infections. Okla Nurse. 2010;55(4):10. Exclusion Codes: COMMENTARY. [pmid: 21322328].
Butler-O'Hara M, D'Angio CT, Hoey H, et al. An Evidence-Based Catheter Bundle Alters Central Venous Catheter Strategy in Newborn Infants. Journal of Pediatrics. 2012. Exclusion Codes: NOT RELEVANT OUTCOME.
Cabassa Sylvia Colon. Nurse-generated reminder system to reduce catheter associated urinary tract infection. D.N.P. 2010:48. Exclusion Codes: NOT RELEVANT QUESTION.
Caffrey AR, Woodmansee SB, Crandall N, et al. Low Adherence to Outpatient Preoperative Methicillin-Resistant Staphylococcus aureus Decolonization Therapy. Infection Control & Hospital Epidemiology. 2011;32(9):930-932. Exclusion Codes: LETTER TO EDITOR. [pmid: 21828980].
Calfee DP, Salgado CD, Classen D, et al. Strategies to prevent transmission of Methicillin-resistant Staphylococcus aureus in acute care hospitals. Infect Control Hosp Epidemiol. Suppl 1. 2008;29:S62-80. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 18840090].
Callcut RA. What is the best position for preventing ventilator-associated pneumonia?. Respir Care. 2010;55(3):353-4. Exclusion Codes: COMMENTARY. [pmid: 20196888].
Campbell DA Jr, Kubus JJ, Henke PK, et al. The Michigan Surgical Quality Collaborative: a legacy of Shukri Khuri. American Journal of Surgery. 2009;198(5 SUPPL):S49-S55. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 19874935].
Campbell DA Jr, Englesbe MJ, Kubus JJ, et al. Accelerating the pace of surgical quality improvement: The power of hospital collaboration. Archives of Surgery. 2010;145(10):985-991. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20956768].
Canning DA. Teaching children clean intermittent self-catheterization (CISC) in a group setting. Journal of Urology. 2011;185(5):1905. Exclusion Codes: COMMENTARY. [pmid: 22088738].
Carlet J. Anti-, pre-, or … probiotics to prevent ventilator-associated pneumonia in the intensive care unit?. Crit Care Med. 2010;38(3):1009-10. Exclusion Codes: EDITORIAL. [pmid: 20168172].
Carling P, Po J, Jeffferson J, et al. Objectively improving operating theatre disinfection cleaning in 12 hospitals. Clinical Microbiology and Infection. 2011;17:S325. Exclusion Codes: ABSTRACT ONLY.
Casey AL, Burnell S, Whinn H, et al. A prospective clinical trial to evaluate the microbial barrier of a needleless connector. J Hosp Infect. 2007;65(3):212-8. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17241691].
Casey J, Davies J, Balshaw-Greer A, et al. Inserting tunnelled hemodialysis catheters using elective guidewire exchange from nontunnelled catheters: is there a greater risk of infection when compared with new-site replacement?. Hemodial Int. 2008;12(1):52-4. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18271841].
Cason CL, Tyner T, Saunders S, et al. Nurses' implementation of guidelines for ventilator-associated pneumonia from the Centers for Disease Control and Prevention. Am J Crit Care. 2007;16(1):28-36. discussion 37; quiz 38. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17192524].
Castella A, Argentero PA, Farina EC, et al. Surgical site infections surveillance in Northern Italy. Infection. 2009;37(1):70-74. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18974927].
Castello FV, Maher A, Cable G. Reducing bloodstream infections in pediatric rehabilitation patients receiving parenteral nutrition. Pediatrics. 2011;128(5):e1273-e1278. Exclusion Codes: NO STATISTICAL ANALYSIS. [pmid: 22025596].
Centofanti P, Savia F, La Torre M, et al. A prospective study of prevalence of 60-days postoperative wound infections after cardiac surgery. An updated risk factor analysis. J Cardiovasc Surg (Torino). 2007;48(5):641-6. Exclusion Codes: NOT RELEVANT QUESTION.
Chaberny IF, Schwab F, Ziesing S, Suerbaum S, Gastmeier P. Impact of routine surgical ward and intensive care unit admission surveillance cultures on hospital-wide nosocomial Methicillin-resistant Staphylococcus aureus infections in a university hospital: an interrupted time-series analysis. J Antimicrob Chemother. 2008;62(6):1422-9. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18765411].
Chaberny IF, Ruseva E, Sohr D, et al. Surveillance with successful reduction of central line-associated bloodstream infections among neutropenic patients with hematologic or oncologic malignancies. Ann Hematol. 2009;88(9):907-12. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 19139891].
Chan EY, Ruest A, Meade MO, et al. Oral decontamination for prevention of pneumonia in mechanically ventilated adults: systematic review and Meta-analysis. BMJ. 2007;334(7599):889. Exclusion Codes: META-ANALYSIS, REVIEW ARTICLE. [pmid: 17387118].
Chan EY. Oral decontamination for ventilator-associated pneumonia prevention. Aust Crit Care. 2009;22(1):3-4. Exclusion Codes: EDITORIAL. [pmid: 19144537].
Chao YF, Chen YY, Wang KW, et al. Removal of oral secretion prior to position change can reduce the incidence of ventilator-associated pneumonia for adult ICU patients: a clinical controlled trial study. J Clin Nurs. 2009;18(1):22-8. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19120729].
Chaplow R, Palmer B, Heyderman R, et al. Stenotrophomonas maltophilia bacteraemia in 40 haematology patients: Risk factors, therapy and outcome. Bone Marrow Transplantation. 2010;45(6):1109-1110. Exclusion Codes: NOT RELEVANT INTERVENTION, LETTER. [pmid: 19802036].
Charron K. Decreasing central line infection rates: The combination of best practice and the introduction of an antimicrobial IV connector. Canadian Journal of Cardiology. 2011;27(5):S358. Exclusion Codes: ABSTRACT ONLY.
Chastre J. Preventing ventilator-associated pneumonia: could silver-coated endotracheal tubes be the answer?. JAMA. 2008;300(7):842-4. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18714067].
Chelliah A, Heydon KH, Zaoutis TE, et al. Observational trial of antibiotic-coated central venous catheters in critically ill pediatric patients. Pediatr Infect Dis J. 2007;26(9):816-20. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17721377].
Cheung K, Leung P, Wong Y, et al. Water versus antiseptic periurethral cleansing before catheterization among home care patients: a randomized controlled trial. American Journal of Infection Control. 2008;36(5):375-380. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18538705].
Chlebicki MP, Safdar N. Topical chlorhexidine for prevention of ventilator-associated pneumonia: a Meta-analysis. Crit Care Med. 2007;35(2):595-602. Exclusion Codes: META-ANALYSIS. [pmid: 17205028].
Chow KM, Poon YL, Lam MP, et al. Antibiotic lock solutions for the prevention of catheter-related bacteraemia in haemodialysis patients. Hong Kong Medical Journal. 2010;16(4):269-274. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 20683069].
Chow KM, Poon YL, Lam MP, et al. Antibiotic lock solutions for the prevention of catheter-related bacteraemia in haemodialysis patients. Hong Kong Med J. 2010;16(4):269-74. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20683069].
Christensen RD, Henry E, Baer VL, et al. A low-sodium solution for airway care: results of a multicenter trial. Respir Care. 2010;55(12):1680-5. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 21122176].
Cimiotti JP, Haas J, Saiman L, et al. Impact of staffing on bloodstream infections in the neonatal intensive care unit. Arch Pediatr Adolesc Med. 2006;160(8):832-6. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16894083].
Cobrado L, Espinar MJ, Costa-de-Oliveira S, et al. Colonization of central venous catheters in intensive care patients: A 1-year survey in a Portuguese university hospital. American Journal of Infection Control. 2010;38(1):83-84. Exclusion Codes: LETTER. [pmid: 20116041].
Coffin SE, Klompas M, Classen D, et al. Strategies to prevent ventilator-associated pneumonia in acute care hospitals. Infect Control Hosp Epidemiol. Suppl 1. 2008;29:S31-40. Exclusion Codes: GUIDELINE. [pmid: 18840087].
Coignard-Biehler H, Lanternier F, Hot A, et al. Adherence to preventive measures after splenectomy in the hospital setting and in the community. Journal of Infection and Public Health. 2011;4(4):187-194. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 22000846].
Comer A, Harris AD, Shardell M, et al. Web-based training improves knowledge about central line bloodstream infections. Infect Control Hosp Epidemiol. 2011;32(12):1219-22. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 22080663].
Conley DM, Singer SJ, Edmondson L, et al. Effective surgical safety checklist implementation. J Am Coll Surg. 2011;212(5):873-9. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21398154].
Cool LR, Riddell B. Information technology and the clinical nurse specialist. Value of interdisciplinary teams in improving central line infection rates. Clinical Nurse Specialist: The Journal for Advanced Nursing Practice. 2006;20(6):283-284. Exclusion Codes: COMMENTARY.
Cooper BS, Cookson BD, Davey PG, et al. Introducing the ORION Statement, a CONSORT equivalent for infection control studies. J Hosp Infect. Suppl 2. 2007;65:85-7. Exclusion Codes: GUIDELINE. [pmid: 17540248].
Cornacchiari M, Heidempergher M, Stasi A, et al. Effectiveness of a protocol for the prevention of hemodialysis venous catheter-related infections. Journal of Vascular Access. 2011;12(4):313-317. Exclusion Codes: NO STATISTICAL ANALYSIS. [pmid: 21534231].
Cotton PB, Connor P, Rawls E, et al. Infection after ERCP, and antibiotic prophylaxis: a sequential quality-improvement approach over 11 years. Gastrointest Endosc. 2008;67(3):471-5. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18061594].
Cox E, Flaspohler T, Jennings A, et al. Attempts to change culture in a line-obsessed pediatric world: The Riley Heart Center line initiative. American Journal of Infection Control. 2011;39(8):690-692. Exclusion Codes: NO STATISTICAL ANALYSIS. [pmid: 21664006].
Craven DE, Hjalmarson K. Prophylaxis of ventilator-associated pneumonia: changing culture and strategies to trump disease. Chest. 2008;134(5):898-900. Exclusion Codes: COMMENTARY. [pmid: 18988773].
Dailly S. Prevention of indwelling catheter-associated urinary tract infections. Nurs Older People. 2011;23(2):14-9. Exclusion Codes: GUIDELINE. [pmid: 21413662].
Dallas J, Kollef M. Oral decontamination to prevent ventilator-associated pneumonia: is it a sound strategy?. Chest. 2009;135(5):1116-8. Exclusion Codes: COMMENTARY. [pmid: 19420189].
Dallas J, Kollef M. VAT vs VAP: are we heading toward clarity or confusion?. Chest. 2009;135(2):252-5. Exclusion Codes: COMMENTARY. [pmid: 19201703].
Damschroder LJ, Banaszak-Holl J, Kowalski CP, et al. The role of the champion in infection prevention: results from a multisite qualitative study. Qual Saf Health Care. 2009;18(6):434-40. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 19955453].
Darden BV 2nd, Duncan J. Postoperative lumbar spine infection. Orthopedics. 2006;29(5):425-9. quiz 430-1. Exclusion Codes: COMMENTARY. [pmid: 16729743].
Darouiche RO, Mosier MC, Berger DH. Prevention of surgical-site infections. New England Journal of Medicine. 2010;362(16):1543-1544. Exclusion Codes: LETTER.
Datta P, Rani H, Chauhan R, et al. Device-associated nosocomial infection in the intensive care units of a tertiary care hospital in northern India. Journal of Hospital Infection. 2010;76(2):184-185. Exclusion Codes: LETTER. [pmid: 20708301].
Davis J. Central-line-associated bloodstream infection: comprehensive, data-drive prevention. Pennsylvania Patient Safety Advisory. 2011;8(3):100-104. Exclusion Codes: NO STATISTICAL ANALYSIS.
Dawes A, Perrecone M. Article spreads the word about VAP prevention. Am J Crit Care. 2007;16(6):532-3. Exclusion Codes: LETTER. [pmid: 17962495].
Dawson D, Endacott R. Implementing quality initiatives using a bundled approach. Intensive Crit Care Nurs. 2011;27(3):117-20. Exclusion Codes: SYSTEMATIC REVIEW. [pmid: 21511476].
Day C. Engaging the nursing workforce: an evidence-based tool kit. Nurs Adm Q. 2009;33(3):239-44. Exclusion Codes: REVIEW ARTICLE. [pmid: 19546743].
Daymont C. Sometimes zero risk is not an option. Archives of Pediatrics and Adolescent Medicine. 2011;165(6):574. Exclusion Codes: COMMENTARY. [pmid: 21646595].
de Carvalho CR. Ventilator-associated pneumonia. J Bras Pneumol. 2006;32(4):xx-xxii. Exclusion Codes: EDITORIAL. [pmid: 17278314].
De Rosa FG, Michelazzo M, Pagani N, et al. Prevention and diagnosis of ventilator-associated pneumonia: a regional survey in Italy. Chest. 2009;135(3):881-2. Exclusion Codes: LETTER. [pmid: 19265103].
Dechelotte P, Hasselmann M, Cynober L, et al. L-alanyl-L-glutamine dipeptide-supplemented total parenteral nutrition reduces infectious complications and glucose intolerance in critically ill patients: the French controlled, randomized, double-blind, multicenter study. Critical Care Medicine. 2006;34(3):598-604. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16505644].
Deja M, Spies C. Prevention measures of ventilator-associated pneumonia. Crit Care Med. 2009;37(1):330-2. Exclusion Codes: EDITORIAL. [pmid: 19112287].
Delaney A, Gray H, Laupland KB, et al. Kinetic bed therapy to prevent nosocomial pneumonia in mechanically ventilated patients: a systematic review and Meta-analysis. Crit Care. 2006;10(3):R70. Exclusion Codes: META-ANALYSIS, REVIEW ARTICLE. [pmid: 16684365].
Dellinger EP. Adherence to Surgical Care Improvement Project measures: The whole is greater than the parts. Future Microbiology. 2010;5(12):1781-1785. Exclusion Codes: COMMENTARY. [pmid: 21155661].
Demir F. A survey on prevention of surgical infections in operating theaters. Worldviews Evid Based Nurs. 2009;6(2):102-13. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 19422673].
DePalo VA, McNicoll L, et al. The Rhode Island ICU Collaborative: a model for reducing central line-associated bloodstream infection and ventilator-associated pneumonia Statewide. Quality & Safety in Health Care. 2010;19(6):555-561. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 21127114].
Dettenkofer M, Wilson C, Gratwohl A, et al. Skin disinfection with octenidine dihydrochloride for central venous catheter site care: a double-blind, randomized, controlled trial. Clin Microbiol Infect. 2010;16(6):600-6. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19686276].
DiNardo M, Donihi AC, Forte P, et al. Standardized glycemic management and perioperative glycemic outcomes in patients with diabetes mellitus who undergo same-day surgery. Endocr Pract. 2011;17(3):404-11. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21247843].
Dixon JM, Carver RL. Daily chlorohexidine gluconate bathing with impregnated cloths results in Statistically significant reduction in central line-associated bloodstream infections. Am J Infect Control. 2010;38(10):817-21. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 21093698].
Dixon-Woods M, Bosk CL, Aveling EL, et al. Explaining Michigan: developing an ex post theory of a quality improvement program. Milbank Q. 2011;89(2):167-205. Exclusion Codes: COMMENTARY. [pmid: 21676020].
Doyle A, Hodd J, Young P. Blowing the pipes clean works!. Respir Care. 2010;55(8):1103. author reply 1103-4. Exclusion Codes: LETTER. [pmid: 20731073].
Drake K. SCIP core measures: Deep impact. Nursing Management. 2011;42(5):24-31. Exclusion Codes: NOT RELEVANT INTERVENTION STRATEGY. [pmid: 21471851].
Drekonja DM, Kuskowski MA, Wilt TJ, et al. Antimicrobial urinary catheters: A systematic review. Expert Review of Medical Devices. 2008;5(4):495-506. Exclusion Codes: REVIEW ARTICLE. [pmid: 18573048].
Dubose J, Teixeira PG, Inaba K, et al. Measurable outcomes of quality improvement using a daily quality rounds checklist: one-year analysis in a trauma intensive care unit with sustained ventilator-associated pneumonia reduction. J Trauma. 2010;69(4):855-60. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 20032792].
DuBose JJ, Inaba K, Shiflett A, et al. Measurable outcomes of quality improvement in the trauma intensive care unit: the impact of a daily quality rounding checklist. Journal of Trauma. 2008;64(1):22-29. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 18188094].
Duenas L, Bran de Casares A, Rosenthal VD, et al. Device-associated infections rates in pediatrics and neonatal intensive care units in El Salvador: findings of the INICC. J Infect Dev Ctries. 2011;5(6):445-51. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21727643].
Duerden BI. Confronting infection in the English National Health Service. Journal of Hospital Infection. 2007;65(SUPPL. 2):23-26. Exclusion Codes: COMMENTARY. [pmid: 17540236].
Dy CJ, Dossous PM, Ton QV, et al. Does a multidisciplinary team decrease complications in male patients with hip fractures?. Clin Orthop Relat Res. 2011;469(7):1919-24. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21350887].
Eckmanns T, Bessert J, Behnke M, et al. Compliance with antiseptic hand rub use in intensive care units: the Hawthorne effect. Infect Control Hosp Epidemiol. 2006;27(9):931-4. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16941318].
Edden AC, Willan JL. A local response to implementing Saving Lives in a large acute Trust. Br J Nurs. 2009;18(18):1138-42. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 19966735].
Elder NC, Brungs SM, Nagy M, et al. Intensive care unit nurses' perceptions of safety after a highly specific safety intervention. Qual Saf Health Care. 2008;17(1):25-30. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18245216].
Elpern EH, Killeen K, Ketchem A, et al. Reducing use of indwelling urinary catheters and associated urinary tract infections. American Journal of Critical Care. 2009;18(6):535-542. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 19880955].
Esmail R, Duchscherer G, Giesbrecht J, et al. Prevention of ventilator-associated pneumonia in the calgary health region: a Canadian success story!. Healthc Q. 2008;11(3 Spec No.):129-36. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 18382174].
Esposito S, Noviello S, Leone S, et al. A pilot study on prevention of catheter-related urinary tract infections with fluoroquinolones. J Chemother. 2006;18(5):494-501. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17127226].
Esteban E, Ferrer R, Jordan I, et al. Educational intervention to reduce nosocomial infection rates in the pediatric intensive care unit. Intensive Care Medicine. 2011;37:S175. Exclusion Codes: ABSTRACT ONLY.
Esteve F, Pujol M, Limon E, et al. Bloodstream infection related to catheter connections: a prospective trial of two connection systems. J Hosp Infect. 2007;67(1):30-4. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17719682].
Etzioni DA. Quality of care in surgery: The health services research perspective. Surgery. 2011;150(5):881-886. Exclusion Codes: COMMENTARY. [pmid: 22018283].
Evans HL, Dellit TH, Chan J, et al. Effect of chlorhexidine whole-body bathing on hospital-acquired infections among trauma patients. Archives of Surgery. 2010;145(3):240-246. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20231624].
Ewing H, Bruder G, Baroco P, et al. Eliminating perioperative adverse events at Ascension Health. Joint Commission Journal on Quality & Patient Safety. 2007;33(5):256-266. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 17503681].
Fakih MG, Dueweke C, Meisner S, et al. Effect of nurse-led multidisciplinary rounds on reducing the unnecessary use of urinary catheterization in hospitalized patients. Infect Control Hosp Epidemiol. 2008;29(9):815-9. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18700831].
Fakih MG, Pena ME, Shemes S, et al. Effect of establishing guidelines on appropriate urinary catheter placement. Acad Emerg Med. 2010;17(3):337-40. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 20370769].
Fakih MG, Todd Greene M, Kennedy EH, et al. Introducing a population-based outcome measure to evaluate the effect of interventions to reduce catheter-associated urinary tract infection. Am J Infect Control. 2011. Exclusion Codes: NOT RELEVANT OUTCOME.
Falagas ME, Siempos II. Prevention of ventilator-associated pneumonia: possible role of antimicrobials administered via the respiratory tract. Eur Respir J. 2008;31(5):1138-9. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18448511].
Fauerbach LL, Williams ML, Archibald LK. A neurosurgical multidisciplinary infection prevention team: Adverse event review and assessment to reduce class i surgical site infections (SSI). American Journal of Infection Control. 2009;37(5):E144. Exclusion Codes: NOT RELEVANT QUESTION.
Fennessy BG, O'Sullivan MJ, Fulton GJ, et al. Prospective study of use of perioperative antimicrobial therapy in general surgery. Surg Infect (Larchmt). 2006;7(4):355-60. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 16978078].
Fernandez-Hidalgo N, Almirante B, Calleja R, et al. Antibiotic-lock therapy for long-term intravascular catheter-related bacteraemia: results of an open, non-comparative study. J Antimicrob Chemother. 2006;57(6):1172-80. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16597634].
Ferrer R, Artigas A, Levy MM, et al. Improvement in process of care and outcome after a multicenter severe sepsis educational program in Spain. JAMA - Journal of the American Medical Association. 2008;299(19):2294-2303. Exclusion Codes: NOT RELEVANT INFECTION.
Ferrer M, Menendez R, Amaro R, et al. The impact of guidelines on the outcomes of community-acquired and ventilator-associated pneumonia. Clinics in Chest Medicine. 2011;32(3):491-505. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21867818].
File TM Jr., Solomkin JS, Cosgrove SE. Strategies for improving antimicrobial use and the role of antimicrobial stewardship programs. Clin Infect Dis. Suppl 1. 2011;53:S15-22. Exclusion Codes: SYSTEMATIC REVIEW. [pmid: 21795724].
Filippi L, Pezzati M, Di Amario S, et al. Fusidic acid and heparin lock solution for the prevention of catheter-related bloodstream infections in critically ill neonates: a retrospective study and a prospective, randomized trial. Pediatr Crit Care Med. 2007;8(6):556-62. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17914310].
Fitzgerald J, Kanter G, Benjamin E, 5 Million Lives Campaign. Case study: preventing surgical complications at BayState Medical Center. Joint Commission Journal on Quality & Patient Safety. 2007;33(11):666-671. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 18074714].
Fitzgerald J, Kanter G, Benjamin E. Case study: preventing surgical complications at BayState Medical Center. Jt Comm J Qual Patient Saf. 2007;33(11):666-71. 645. Exclusion Codes: COMMENTARY. [pmid: 18074714].
Fitzgerald J, Kanter G, Trelease R, et al. Reducing surgical complications. Nurs Manage. 2007;38(11):35-9. Exclusion Codes: GUIDELINE. [pmid: 17992133].
Flaatten H. When will we ever learn?. Acta Anaesthesiologica Scandinavica. 2012;56(1):1-2. Exclusion Codes: EDITORIAL. [pmid: 22150408].
Foxley S, Addison R. Your role in urinary catheter management. British Journal of Healthcare Assistants. 2008;2(2):58-62. Exclusion Codes: GUIDELINE.
Foxley S. Driving down catheter associated infection rates. Nurs Times. 2011;107(29):14. 16. 18. Exclusion Codes: COMMENTARY. [pmid: 21941729].
Fraher MH, Collins CJ, Bourke J, et al. Cost-effectiveness of employing a total parenteral nutrition surveillance nurse for the prevention of catheter-related bloodstream infections. J Hosp Infect. 2009;73(2):129-34. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19709776].
Frankhouse JH. Role of hyperglycemia in SSIs: postoperative hyperglycemia and SSI in general surgery patients. Arch Surg. 2010;145(9):864. Exclusion Codes: LETTER. [pmid: 20873006].
Franzetti F, Borghi B, Raimondi F, et al. Impact on rates and time to first central vascular-associated bloodstream infection when switching from open to closed intravenous infusion containers in a hospital setting. Epidemiology & Infection. 2009;137(7):1041-1048. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19144245].
Fraser TG, Fatica C, Scarpelli M, et al. Decrease in staphylococcus aureus colonization and hospital-acquired infection in a medical intensive care unit after institution of an active surveillance and decolonization program. Infection Control and Hospital Epidemiology. 2010;31(8):779-783. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20594110].
Fraser TG, Gordon SM. CLABSI rates in mmunocompromised patients: a valuable patient centered outcome?. Clin Infect Dis. 2011;52(12):1446-50. Exclusion Codes: EDITORIAL. [pmid: 21628486].
Frost P, Wise MP. Tracheotomy and ventilator-associated pneumonia: the importance of oral care. Eur Respir J. 2008;31(1):221. author reply 221-2. Exclusion Codes: LETTER. [pmid: 18166602].
Fung-Kee-Fung M, Watters J, Crossley C, et al. Regional collaborations as a tool for quality improvements in surgery: A systematic review of the literature. Annals of Surgery. 2009;249(4):565-572. Exclusion Codes: REVIEW ARTICLE. [pmid: 19300234].
Furuya EY, Dick A, Perencevich EN, et al. Central line bundle implementation in US intensive care units and impact on bloodstream infections. PLoS One. 2011;6(1):e15452. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21267440].
Gagliardi AR, Eskicioglu C, McKenzie M, et al. Identifying opportunities for quality improvement in surgical site infection prevention. American Journal of Infection Control. 2009;37(5):398-402. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19201509].
Garat M, Moser CL, Martin-Baranera M, Alonso-Tarres C, et al. Prophylactic intracameral cefazolin after cataract surgery. Endophthalmitis risk reduction and safety results in a 6-year study. Journal of Cataract and Refractive Surgery. 2009;35(4):637-642. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19304083].
Gastmeier P, Geffers C, Brandt C, et al. Effectiveness of a nationwide nosocomial infection surveillance system for reducing nosocomial infections. J Hosp Infect. 2006;64(1):16-22. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16820247].
Gastmeier P, Schwab F, Sohr D, et al. Reproducibility of the surveillance effect to decrease nosocomial infection rates. Infection Control & Hospital Epidemiology. 2009;30(10):993-999. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19719414].
Gastmeier P, Behnke M, Schwab F, et al. Benchmarking of urinary tract infection rates: experiences from the intensive care unit component of the German national nosocomial infections surveillance system. J Hosp Infect. 2011;78(1):41-4. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21481490].
Gattinoni L, Protti A. Ventilation in the prone position: for some but not for all?. CMAJ. 2008;178(9):1174-6. Exclusion Codes: COMMENTARY. [pmid: 18427093].
Geffers C, Meyer E. No reason to conclude that maximal sterile barrier precautions do not reduce catheter-related blood stream infections. Ann Surg. 2011;253(1):212-3. Exclusion Codes: EDITORIAL. [pmid: 21135688].
Geubbels EL, Nagelkerke NJ, Mintjes-De, et al. Reduced risk of surgical site infections through surveillance in a network. Int J Qual Health Care. 2006;18(2):127-33. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16484315].
Ghide S, Jiang Y, Hachem R, et al. Catheter-related Corynebacterium bacteremia: Should the catheter be removed and vancomycin administered?. European Journal of Clinical Microbiology and Infectious Diseases. 2010;29(2):153-156. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20016995].
Gifford C, Christelis N, Cheng A. Preventing postoperative infection: the anaesthetist's role. Continuing Education in Anaesthesia, Critical Care & Pain. 2011;11(5):151-156. Exclusion Codes: EDITORIAL.
Gillespie R. Improving the quality of care of the critically ill patient: Implementing the central venous line care bundle in the ICU. Southern African Journal of Critical Care. 2008;24(1):26-31. Exclusion Codes: GUIDELINE.
Goeschel CA, Bourgault A, Palleschi M, et al. Nursing lessons from the MHA keystone ICU project: developing and implementing an innovative approach to patient safety. Crit Care Nurs Clin North Am. 2006;18(4):481-92. x. Exclusion Codes: GUIDELINE. [pmid: 17118302].
Goeschel CA, Holzmueller CG, Berenholtz SM, et al. Executive/Senior Leader Checklist to improve culture and reduce central line-associated bloodstream infections. Jt Comm J Qual Patient Saf. 2010;36(11):519-24. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 21090023].
Goeschel CA, Holzmueller CG, Berenholtz SM, et al. Executive/senior leader checklist to improve culture and reduce central line--associated bloodstream infections. Joint Commission Journal on Quality & Patient Safety. 2010;36(11):519-524. Exclusion Codes: GUIDELINE. [pmid: 21090023].
Goeschel CA, Holzmueller CG, Pronovost PJ. Hospital Board Checklist to improve culture and reduce central line-associated bloodstream infections. Jt Comm J Qual Patient Saf. 2010;36(11):525-8. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 21090024].
Goeschel CA, Holzmueller CG, Pronovost PJ. Hospital board checklist to improve culture and reduce central line--associated bloodstream infections. Joint Commission Journal on Quality & Patient Safety. 2010;36(11):525-528. Exclusion Codes: GUIDELINE. [pmid: 21090024].
Goeschel CA, Holzmueller CG, Cosgrove SE, et al. Infection preventionist checklist to improve culture and reduce central line-associated bloodstream infections. Joint Commission Journal on Quality & Patient Safety. 2010;36(12):571-575. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 21222359].
Goeschel CA, Holzmueller CG, Cosgrove SE, et al. Infection preventionist checklist to improve culture and reduce central line-associated bloodstream infections. Jt Comm J Qual Patient Saf. 2010;36(12):571-5. Exclusion Codes: GUIDELINE. [pmid: 21222359].
Goes-Silva E, Abreu TF, Frota AC, et al. Use of peripherally inserted central catheters to prevent catheter-associated bloodstream infection in children. Infect Control Hosp Epidemiol. 2009;30(10):1024-6. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 19719412].
Goldhill DR, Imhoff M, McLean B, et al. Rotational bed therapy to prevent and treat respiratory complications: a review and Meta-analysis. Am J Crit Care. 2007;16(1):50-61. quiz 62. Exclusion Codes: REVIEW. [pmid: 17192526].
Gowardman JR, Robertson IK, Parkes S, et al. Influence of insertion site on central venous catheter colonization and bloodstream infection rates. Intensive Care Medicine. 2008;34(6):1038-1045. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18317732].
Graham PL Iii, Begg MD, Larson E, et al. Risk factors for late onset gram-negative sepsis in low birth weight infants hospitalized in the neonatal intensive care unit. Pediatric Infectious Disease Journal. 2006;25(2):113-117. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 16462286].
Grajales Cuesy P, Lavielle Sotomayor P, et al. Talavera Reduction in the Incidence of Poststroke Nosocomial Pneumonia by Using the “Turn-mob” Program. Journal of Stroke and Cerebrovascular Diseases. 2010;19(1):23-28. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20123223].
Greco D, Magombe I. Hospital acquired infections in a large north Ugandan hospital. J Prev Med Hyg. 2011;52(2):55-8. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21842706].
Gregson H. Reducing surgical site infection following caesarean section. Nursing Standard. 2011;25(50):35-40. Exclusion Codes: NO STATISTICAL ANALYSIS. [pmid: 21928589].
Grenier C, Pepin J, Nault V, et al. Impact of guideline-consistent therapy on outcome of patients with healthcare-associated and community-acquired pneumonia. Journal of Antimicrobial Chemotherapy. 2011;66(7):1617-1624. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21586592].
Grudzinski L, Quinan P, Kwok S, et al. Sodium citrate 4% locking solution for central venous dialysis catheters - An effective, more cost-efficient alternative to heparin. Nephrology Dialysis Transplantation. 2007;22(2):471-476. Exclusion Codes: NOT RELEVANT INTERVENTION.
Guanche-Garcell H, Requejo-Pino O, Rosenthal VD, et al. Device-associated infection rates in adult intensive care units of Cuban university hospitals: International Nosocomial Infection Control Consortium (INICC) findings. Int J Infect Dis. 2011;15(5):e357-62. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21450505].
Guerin CK, Gama J. Nursing satisfaction survey and infection rate results from conversion of insulin vials to pens in a hospital setting. Diabetes. 2011;60:A255-A256. Exclusion Codes: ABSTRACT ONLY.
Guner R, Hasanoglu I, Keske S, et al. Educational approach to reduce catheter-related bloodstream infections and catheter-related urinary tract infection rates in intensive care unit. Clinical Microbiology and Infection. 2011;17:S775. Exclusion Codes: ABSTRACT ONLY.
Gurses AP, Murphy DJ, Martinez EA, et al. A practical tool to identify and eliminate barriers to compliance with evidence-based guidelines. Jt Comm J Qual Patient Saf. 2009;35(10):526-32. 485. Exclusion Codes: GUIDELINE. [pmid: 19886092].
Gustafsson UO, Hausel J, Thorell A, et al. Adherence to the enhanced recovery after surgery protocol and outcomes after colorectal cancer surgery. Arch Surg. 2011;146(5):571-7. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 21242424].
Haessler S, Connelly NR, Kanter G, et al. A surgical site infection cluster: The process and outcome of an investigation-the impact of an alcohol-based surgical antisepsis product and human behavior. Anesthesia and Analgesia. 2010;110(4):1044-1048. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 20103542].
Haessler S, Connelly NR, Kanter G, et al. A surgical site infection cluster: the process and outcome of an investigation--the impact of an alcohol-based surgical antisepsis product and human behavior. Anesth Analg. 2010;110(4):1044-8. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 20103542].
Halm MA, Armola R. Effect of oral care on bacterial colonization and ventilator-associated pneumonia. Am J Crit Care. 2009;18(3):275-8. Exclusion Codes: REVIEW ARTICLE. [pmid: 19411586].
Halpern NA, Hale KE, Sepkowitz KA, et al. A world without ventilator-associated pneumonia: Time to abandon surveillance and deconstruct the bundle. Critical Care Medicine. 2012;40(1):267-270. Exclusion Codes: COMMENTARY. [pmid: 22179342].
Halpin H, Shortell SM, Milstein A, et al. Hospital adoption of automated surveillance technology and the implementation of infection prevention and control programs. American Journal of Infection Control. 2011;39(4):270-276. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 21531272].
Halton KA, Cook D, Paterson DL, et al. Cost-effectiveness of a central venous catheter care bundle. PLoS One. 2010;5(9). Exclusion Codes: NOT RELEVANT OUTCOME.
Hamad GG, Brown MT, Clavijo-Alvarez JA. Postoperative video debriefing reduces technical errors in laparoscopic surgery. Am J Surg. 2007;194(1):110-4. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17560921].
Hameed A, Chinegwundoh F, Thwaini A. Prevention of catheter-related urinary tract infections. Br J Hosp Med (Lond). 2010;71(3):148-50. 151. 2. Exclusion Codes: REVIEW ARTICLE. [pmid: 20220720].
Hanazaki K, Munekage M, Okabayashi T. What is the best way to guarantee postoperative glycemic control?. Journal of the American College of Surgeons. 2011;212(5):915-916. Exclusion Codes: LETTER TO EDITOR. [pmid: 21530859].
Hansen S, Schwab F, Behnke M, et al. National influences on catheter-associated bloodstream infection rates: practices among national surveillance networks participating in the European HELICS project. J Hosp Infect. 2009;71(1):66-73. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18799236].
Harbarth S, Fankhauser C, Schrenzel J, et al. Universal screening for Methicillin-resistant Staphylococcus aureus at hospital admission and nosocomial infection in surgical patients. JAMA. 2008;299(10):1149-57. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 18334690].
Harnage SA. Achieving Zero Catheter Related Blood Stream Infections: 15 months success in a community based medical center. JAVA - Journal of the Association for Vascular Access. 2007;12(4):218-224. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS.
Harnage SA. A PICC team ends CRBSIs. RN. 2008;71(5):34-6. 38. 9. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 18564776].
Harrigan S, Hurst D, Lee C, et al. Developing and implementing quality initiatives in the ICU: strategies and outcomes. Crit Care Nurs Clin North Am. 2006;18(4):469-79. ix. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 17118301].
Harris TA. Changing practice to reduce the use of urinary catheters. Nursing. 2010;40(2):18-20. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 20083972].
Harter P, Muallem ZM, Buhrmann C, et al. Impact of a structured quality management program on surgical outcome in primary advanced ovarian cancer. Gynecologic Oncology. 2011;121(3):615-619. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21414656].
Hatler CW, Mast D, Corderella J, et al. Using evidence and process improvement strategies to enhance healthcare outcomes for the critically ill: a pilot project. Am J Crit Care. 2006;15(6):549-55. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 17053262].
Hawe CS, Ellis KS, Cairns CJ, et al. Reduction of ventilator-associated pneumonia: active versus passive guideline implementation. Intensive Care Med. 2009;35(7):1180-6. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 19308354].
Hawn MT, Vick CC, Richman J, et al. Surgical site infection prevention: time to move beyond the surgical care improvement program. Ann Surg. 2011;254(3):494-9. discussion 499-501. Exclusion Codes: NOT RELEVANT INTERVENTION STRATEGY. [pmid: 21817889].
Haynes K, Linkin DR, Fishman NO, et al. Effectiveness of an information technology intervention to improve prophylactic antibacterial use in the postoperative period. J Am Med Inform Assoc. 2011;18(2):164-8. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21262922].
Hedrick TL, Smith PW, Gazoni LM, et al. The appropriate use of antibiotics in surgery: a review of surgical infections. Curr Probl Surg. 2007;44(10):635-75. Exclusion Codes: REVIEW ARTICLE. [pmid: 18021817].
Hedrick TL, Heckman JA, Smith RL, et al. Efficacy of protocol implementation on incidence of wound infection in colorectal operations. J Am Coll Surg. 2007;205(3):432-8. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 17765159].
Helmio P, Blomgren K, Takala A, et al. Towards better patient safety: WHO Surgical Safety Checklist in otorhinolaryngology. Clin Otolaryngol. 2011;36(3):242-7. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21481197].
Hemmelgarn BR, Moist LM, Lok CE, et al. Prevention of dialysis catheter malfunction with recombinant tissue plasminogen activator. N Engl J Med. 2011;364(4):303-12. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21268722].
Hemsworth S, Selwood K, van Saene R, et al. Does the number of exogenous infections increase in paediatric oncology patients when sterile surgical gloves are not worn for accessing central venous access devices?. Eur J Oncol Nurs. 2007;11(5):442-7. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17584528].
Henry D, Muriel FR, Hirway P. Sustaining improvement in surgical infection prevention measures for hysterectomy. Journal for Healthcare Quality: Promoting Excellence in Healthcare. 2007;29(5):50-56. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS.
Hermsen ED, Smith Shull S, Puumala SE, et al. Improvement in prescribing habits and economic outcomes associated with the introduction of a standardized approach for surgical antimicrobial prophylaxis. Infect Control Hosp Epidemiol. 2008;29(5):457-61. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 18419372].
Hess DR, MacIntyre NR. Ventilator discontinuation: Why are we still weaning?. American Journal of Respiratory and Critical Care Medicine. 2011;184(4):392-394. Exclusion Codes: EDITORIAL. [pmid: 21844511].
Hilinski AM, Stark ML. Memory aide to reduce the incidence of ventilator-associated pneumonia. Crit Care Nurse. 2006;26(5):80. 79. Exclusion Codes: GUIDELINE. [pmid: 16988290].
Ho VP, Barie PS, Stein SL, et al. Antibiotic regimen and the timing of prophylaxis are important for reducing surgical site infection after elective abdominal colorectal surgery. Surg Infect (Larchmt). 2011;12(4):255-60. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21790479].
Hogg W, Huston P, Martin C, et al. Promoting best practices for control of respiratory infections: collaboration between primary care and public health services. Can Fam Physician. 2006;52(9):1110-1. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 17279223].
Hohmann C, Eickhoff C, Radziwill R, et al. Adherence to guidelines for antibiotic prophylaxis in surgery patients in German hospitals: a multicentre evaluation involving pharmacy interns. Infection. 2011. Exclusion Codes: NO STATISTICAL ANALYSIS.
Hope WW, Newcomb WL, Schmelzer TM, et al. Antibiotic prophylaxis in colon surgery. J Am Coll Surg. 2007;205(1):189-90. Exclusion Codes: LETTER. [pmid: 17617351].
Horvath B, Norville R, Lee D, et al. Reducing central venous catheter-related bloodstream infections in children with cancer. Oncol Nurs Forum. 2009;36(2):232-8. Exclusion Codes: N<100. [pmid: 19273413].
Hota B, Lin M, Doherty JA, et al. Formulation of a model for automating infection surveillance: algorithmic detection of central-line associated bloodstream infection. Journal of the American Medical Informatics Association. 2010;17(1):42-48. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20064800].
Huang YC, Lien RI, Su LH, et al. Successful control of methicillin-resistant Staphylococcus aureus in endemic neonatal intensive care units-A 7-year campaign. PLoS ONE. 2011;6(8). Exclusion Codes: NOT RELEVANT OUTCOME.
Huddleston PM, Clyburn TA, Evans RP, et al. Surgical site infection prevention and control: An emerging paradigm. Journal of Bone and Joint Surgery - Series A. 2009;91(SUPPL. 6):2-9. Exclusion Codes: NOT RELEVANT INTERVENTION.
Hupkens P, Lauret GJ, Dubelaar IJM, et al. Prevention of wound dehiscence in palatal surgery by preoperative identification of group A Streptococcus and Staphylococcus aureus. European Journal of Plastic Surgery. 2007;29(7):321-325. Exclusion Codes: NOT RELEVANT QUESTION.
Hutchins K, Karras G, Erwin J, et al. Ventilator-associated pneumonia and oral care: a successful quality improvement project. Am J Infect Control. 2009;37(7):590-7. Exclusion Codes: NOT RELEVANT DESIGN. [pmid: 19716460].
Hyder JA. Surgical care improvement project adherence and postoperative infections. JAMA. 2010;304(15):1669. author reply 1671-2. Exclusion Codes: LETTER. [pmid: 20959572].
Iglesias M, Fernandez-Sein A, Puig-Ramos A, et al. Ventilator-associated pneumonia in critically ill children: An assessment of prevention strategies. Chest. 2011;140(4). Exclusion Codes: ABSTRACT ONLY.
Imai-Kamata S, Fushimi K. Factors associated with adherence to prophylactic antibiotic therapy for elective general surgeries in Japan. International Journal for Quality in Health Care. 2011;23(2):167-172. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21233110].
Imamura H, Furukawa H, Iijima S, et al. Multicenter phase II study of antimicrobial prophylaxis in low-risk patients undergoing distal gastrectomy for gastric cancer. Gastric Cancer. 2006;9(1):32-35. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 16557434].
Indraratna PL, Lucewicz A. Impact of the 4-hour emergency department target on medical student education. EMA - Emergency Medicine Australasia. 2011;23(6):784. Exclusion Codes: LETTER TO EDITOR.
Ingraham AM, Cohen ME, Bilimoria KY, et al. Association of surgical care improvement project infection-related process measure compliance with risk-adjusted outcomes: implications for quality measurement. Journal of the American College of Surgeons. 2010;211(6):705-714. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21109157].
Ishikawa Y, Kiyama T, Haga Y, et al. Maximal sterile barrier precautions do not reduce catheter-related bloodstream infections in general surgery units: a multi-institutional randomized controlled trial. Ann Surg. 2010;251(4):620-3. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20224364].
Ivy DD, Calderbank M, Wagner BD, et al. Closed-hub systems with protected connections and the reduction of risk of catheter-related bloodstream infection in pediatric patients receiving intravenous prostanoid therapy for pulmonary hypertension. Infect Control Hosp Epidemiol. 2009;30(9):823-9. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19637961].
Jamulitrat S, Panmanee A. Inappropriate use of the indwelling urinary tract catheter in hospitalized patients. American Journal of Infection Control. 2007;35(2):138-139. Exclusion Codes: LETTER. [pmid: 17327195].
Jardine LA, Inglis GD, Davies MW. Prophylactic systemic antibiotics to reduce morbidity and mortality in neonates with central venous catheters. Cochrane Database of Systematic Reviews. 2008;(1). Exclusion Codes: REVIEW ARTICLE.
Jarvis WR, Murphy C, Hall KK, et al. Health care-associated bloodstream infections associated with negative- or positive-pressure or displacement mechanical valve needleless connectors. Clin Infect Dis. 2009;49(12):1821-7. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19911973].
Jeffries HE, Mason W, Brewer M, et al. Prevention of central venous catheter--associated bloodstream infections in pediatric intensive care units: a performance improvement collaborative. Infection Control & Hospital Epidemiology. 2009;30(7):645-651. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 19496731].
Jenkins I. Postoperative septic shock. Cleve Clin J Med. 2006;73(7):607. author reply 607-8. Exclusion Codes: LETTER. [pmid: 16845972].
Jeyanathan J, Hawksley OJ, Sliders E. Preventing infections associated with the insertion of central venous catheters: are we getting it right?. J Hosp Infect. 2008;69(2):191-2. Exclusion Codes: LETTER. [pmid: 18387694].
Jill, Rustagi K, Gray T, et al. The .1 Billion Problem: The Annual Cost Of Measurable Errors. Health Affairs. 2011;30(4):596-603. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21471478].
Johnson AJ, Daley JA, Zywiel MG, et al. Preoperative chlorhexidine preparation and the incidence of surgical site infections after hip arthroplasty. J Arthroplasty. 2010;25(6 Suppl):98-102. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20570089].
Johnson EK. Antimicrobial prophylaxis for colorectal surgery. Diseases of the Colon and Rectum. 2010;53(3):368-369. Exclusion Codes: META-ANALYSIS.
Johnson JR, Kuskowski MA, Wilt TJ. Systematic review: antimicrobial urinary catheters to prevent catheter-associated urinary tract infection in hospitalized patients. Annals of Internal Medicine. 2006;144(2):116-126. Exclusion Codes: REVIEW ARTICLE. [pmid: 16418411].
Johnston BL, Conly JM. Central venous catheter-associated bloodstream infections in hemodialysis patients: Another patient safety bundle?. Can J Infect Dis Med Microbiol. 2006;17(2):99-102. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18418482].
Kage A, Barry P. Audit on prevention of ventilator associated pneumonia in children. Intensive Care Medicine. 2011;37:S363. Exclusion Codes: ABSTRACT ONLY.
Kalra S, Nelson Y, Dave P, et al. Student assessment of teaching effectiveness of “bundle of changes”-A paired, controlled trial. J Anaesthesiol Clin Pharmacol. 2011;27(4):506-10. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 22096285].
Kampf G, Loffler H, Gastmeier P. Hand hygiene for the prevention of nosocomial infections. Dtsch Arztebl Int. 2009;106(40):649-55. Exclusion Codes: GUIDELINE. [pmid: 19890431].
Kanayama M, Hashimoto T, Shigenobu K, et al. Effective prevention of surgical site infection using a Centers for Disease Control and Prevention guideline-based antimicrobial prophylaxis in lumbar spine surgery. J Neurosurg Spine. 2007;6(4):327-9. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 17436921].
Kanter G, Connelly NR, Fitzgerald J. A system and process redesign to improve perioperative antibiotic administration. Anesthesia and Analgesia. 2006;103(6):1517-1521. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 17122232].
Kao LS, Ghaferi AA, Ko CY, et al. Reliability of superficial surgical site infections as a hospital quality measure. Journal of the American College of Surgeons. 2011;213(2):231-235. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21622011].
Kass N, Pronovost PJ, Sugarman J, et al. Controversy and quality improvement: lingering questions about ethics, oversight, and patient safety research. Jt Comm J Qual Patient Saf. 2008;34(6):349-53. Exclusion Codes: EDITORIAL. [pmid: 18595381].
Kassler J, Barnett J. A rehabilitation hospital's experience with ionic silver Foley catheters. Urol Nurs. 2008;28(2):97-9. quiz 100. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18488582].
Kawagoe JY, Dal Forno CB, Dornaus MF, et al. Cultural and clinical changes in the NICU: Impact of a multi-faceted program on reduction of CVC associated BSI. American Journal of Infection Control. 2009;37(5):E121-E123. Exclusion Codes: COMMENTARY.
Kaye KS, Engemann JJ, Fulmer EM, et al. Favorable impact of an infection control network on nosocomial infection rates in community hospitals. Infection Control and Hospital Epidemiology. 2006;27(3):228-232. Exclusion Codes: NOT RELEVANT DESIGN. [pmid: 16532408].
Kayton ML, Garmey EG, Ishill NM, et al. Preliminary results of a phase I trial of prophylactic ethanol-lock administration to prevent mediport catheter-related bloodstream infections. J Pediatr Surg. 2010;45(10):1961-6. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20920713].
Keeley L. Reducing the risk of ventilator-acquired pneumonia through head of bed elevation. Nurs Crit Care. 2007;12(6):287-94. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 17983363].
Kellie S, Scott M, Saad M, et al. Procedural and educational interventions reduce ventilator associated pneumonia (VAP) and central line associated bloodstream infections (CLABSI). Chest. 2011;140(4). Exclusion Codes: ABSTRACT ONLY.
Kendrick M, Ercolano E, McCorkle R. Interventions to revent Postoperative complications in Women With Ovarian Cancer. Clinical Journal of Oncology Nursing. 2011;15(2):195-202. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21444287].
Keramidas E. Zero breast implant infection rate and 0.05% hematoma rate following 1720 silicone implant placements for primary breast augmentation: surgical technique or surgeon luck?. Aesthetic Plast Surg. 2009;33(1):123-4. Exclusion Codes: COMMENTARY. [pmid: 19030921].
Keshtgar MR, Khalili A, Coen PG, et al. Impact of rapid molecular screening for Meticillin-resistant Staphylococcus aureus in surgical wards. Br J Surg. 2008;95(3):381-6. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 18041109].
Khan MS, Siddiqui SZ, Haider S, et al. Infection control education: impact on ventilator-associated pneumonia rates in a public sector intensive care unit in Pakistan. Trans R Soc Trop Med Hyg. 2009;103(8):807-11. Exclusion Codes: INSUFFICIENT SAMPLE SIZE. [pmid: 19342068].
Khan SA, Rodrigues G, Kumar P, et al. Current challenges in adherence to clinical guidelines for antibiotic prophylaxis in surgery. Journal of the College of Physicians and Surgeons Pakistan. 2006;16(6):435-437. Exclusion Codes: REVIEW ARTICLE. [pmid: 16787628].
Khare MD, Bukhari SS, Swann A, et al. Reduction of catheter-related colonisation by the use of a silver zeolite-impregnated central vascular catheter in adult critical care. J Infect. 2007;54(2):146-50. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16678904].
Kidd KM, Sinkowitz-Cochran RL, Giblin TB, et al. Barriers to and facilitators of implementing an intervention to reduce the incidence of catheter-associated bloodstream infections. Infect Control Hosp Epidemiol. 2007;28(1):103-5. Exclusion Codes: LETTER. [pmid: 17301938].
Kim DH, Spencer M, Davidson SM, et al. Institutional prescreening for detection and eradication of Methicillin-resistant Staphylococcus aureus in patients undergoing elective orthopaedic surgery. Journal of Bone and Joint Surgery - Series A. 2010;92(9):1820-1826. Exclusion Codes: NOT RELEVANT QUESTION.
Kim LT. Surgical site infection: Still waiting on the revolution. JAMA - Journal of the American Medical Association. 2011;305(14):1478-1479. Exclusion Codes: COMMENTARY.
Kime T, Mohsini K, Nwankwo MU, et al. Central line “attention” is their best prevention. Adv Neonatal Care. 2011;11(4):242-8. quiz 249-50. Exclusion Codes: NO STATISTICAL ANALYSIS. [pmid: 22123344].
Kimura K, Sawa A, Akagi S, et al. Development of a surgical site infection (SSI) surveillance system, calculation of SSI rates and specification of important factors affecting SSI in a digestive organ surgical department. Hiroshima J Med Sci. 2007;56(1-2):1-9. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 17760267].
Kirkland KB. From best to good: Can we “right-size” approaches to reducing healthcare-associated infections. Infection Control and Hospital Epidemiology. 2010;31(8):784-785. Exclusion Codes: COMMENTARY. [pmid: 20594111].
Klompas M. Ventilator-associated pneumonia: is zero possible?. Clin Infect Dis. 2010;51(10):1123-6. Exclusion Codes: COMMENTARY. [pmid: 20936977].
Knight DJ, Gardiner D, Banks A, et al. Effect of synbiotic therapy on the incidence of ventilator associated pneumonia in critically ill patients: a randomised, double-blind, placebo-controlled trial. Intensive Care Med. 2009;35(5):854-61. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 19083199].
Knight WDJ, Gardiner D, Banks A, Snape SE, Weston VC, Bengmark S, Girling KJ. Effect of synbiotic therapy on the incidence of ventilator associated pneumonia in critically ill patients: A randomised, double-blind, placebo-controlled trial. Intensive Care Medicine. 2009;35(5):854-861. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19083199].
Kobayashi M, Inoue Y, Mohri Y, et al. Implementing a standard protocol to decrease the incidence of surgical site infections in rectal cancer surgery. Surgery Today. 2010;40(4):326-333. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20339987].
Koeman M, Van Der Ven AJAM, Hak E, et al. Oral decontamination with chlorhexidine reduces the incidence of ventilator-associated pneumonia. American Journal of Respiratory and Critical Care Medicine. 2006;173(12):1348-1355. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 16603609].
Koeman M, van der Ven AJ, Hak E, et al. Oral decontamination with chlorhexidine reduces the incidence of ventilator-associated pneumonia. Am J Respir Crit Care Med. 2006;173(12):1348-55. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 16603609].
Koff MD, Corwin HL, Beach ML, Surgenor SD, Loftus RW. Reduction in ventilator associated pneumonia in a mixed intensive care unit after initiation of a novel hand hygiene program. J Crit Care. 2011. Exclusion Codes: NOT RELEVANT QUESTION.
Koff MD, Corwin HL, Beach ML, et al. Reduction in ventilator associated pneumonia in a mixed intensive care unit after initiation of a novel hand hygiene program. J Crit Care. 2011;26(5):489-95. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 21439767].
Kola A, Gastmeier P. Efficacy of oral chlorhexidine in preventing lower respiratory tract infections. Meta-analysis of randomized controlled trials. J Hosp Infect. 2007;66(3):207-16. Exclusion Codes: META-ANALYSIS. [pmid: 17544168].
Kollef M. SMART approaches for reducing nosocomial infections in the ICU. Chest. 2008;134(2):447-56. Exclusion Codes: GUIDELINE. [pmid: 18682466].
Kollef MH. Moving towards real-time antimicrobial management of ventilator-associated pneumonia. Clin Infect Dis. 2007;44(3):388-90. Exclusion Codes: COMMENTARY. [pmid: 17205446].
Kollef MH. Healthcare-associated pneumonia. Semin Respir Crit Care Med. 2009;30(1):1-2. Exclusion Codes: LETTER. [pmid: 19199180].
Kollef MH. Prevention of ventilator-associated pneumonia or ventilator-associated complications: A worthy, yet challenging, goal. Critical Care Medicine. 2012;40(1):271-277. Exclusion Codes: GUIDELINE. [pmid: 21946659].
Koopman E, Nix DE, Erstad BL, et al. End-of-procedure cefazolin concentrations after administration for prevention of surgical-site infection. Am J Health Syst Pharm. 2007;64(18):1927-34. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 17823104].
Kopterides P, Siempos II, Armaganidis A. Prone positioning in hypoxemic respiratory failure: Meta-analysis of randomized controlled trials. J Crit Care. 2009;24(1):89-100. Exclusion Codes: META-ANALYSIS. [pmid: 19272544].
Kotsanas D, Al-Souffi MH, Waxman BP, et al. Adherence to guidelines for prevention of postsplenectomy sepsis. Age and sex are risk factors: a five-year retrospective review. ANZ J Surg. 2006;76(7):542-7. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 16813615].
Krein SL, Kowalski CP, Damschroder L, et al. Preventing ventilator-associated pneumonia in the United States: a multicenter mixed-Methods study. Infect Control Hosp Epidemiol. 2008;29(10):933-40. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18715152].
Kritchevsky SB, Braun BI, Bush AJ, et al. The effect of a quality improvement collaborative to improve antimicrobial prophylaxis in surgical patients a randomized trial. Annals of Internal Medicine. 2008;149(7):472-480. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 18838727].
Kritchevsky SB, Braun BI, Kusek L, et al. The impact of hospital practice on central venous catheter associated bloodstream infection rates at the patient and unit level: a multicenter study. Am J Med Qual. 2008;23(1):24-38. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18187588].
Kurien M, Sanders DS. Antibiotic prophylaxis after percutaneous endoscopic gastrostomy. BMJ. 2010;341(7763):55. Exclusion Codes: EDITORIAL.
Labeau S, Vereecke A, Vandijck DM, et al. Critical care nurses' knowledge of evidence-based guidelines for preventing infections associated with central venous catheters: an evaluation questionnaire. Am J Crit Care. 2008;17(1):65-71. quiz 72. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18158392].
Labeau S, Vandijck D, Lizy C, et al. Replacement of administration sets used to administer blood, blood products, or lipid emulsions for the prevention of central line-associated bloodstream infection. Infect Control Hosp Epidemiol. 2009;30(5):494. Exclusion Codes: LETTER. [pmid: 19344267].
Labeau SO, Vandijck DM, Vandewoude KH, et al. Education reduces ventilator-associated pneumonia rates. Clin Infect Dis. 2008;46(3):479. Exclusion Codes: LETTER. [pmid: 18181750].
Labeau SO, Vandijck DM, Brusselaers N, et al. Reduction of ventilator-associated pneumonia: enhancing knowledge is important. Intensive Care Med. 2009;35(10):1818-9. author reply 1820. Exclusion Codes: LETTER. [pmid: 19644672].
Lacherade JC, De Jonghe B, Guezennec P, et al. Intermittent subglottic secretion drainage and ventilator-associated pneumonia: a multicenter trial. Am J Respir Crit Care Med. 2010;182(7):910-7. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20522796].
Lancaster JW, Lawrence KR, Fong JJ, et al. Impact of an institution-specific hospital-acquired pneumonia protocol on the appropriateness of antibiotic therapy and patient outcomes. Pharmacotherapy. 2008;28(7):852-862. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18576900].
The Lancet. Preventing and controlling healthcare-associated infections. The Lancet. 2008;372(9656):2088. Exclusion Codes: LETTER.
Langer M. Perioperative antibiotic prophylaxis in adults: The 2008 update of the Italian Guidelines. How can we as anesthetists contribute to the reduction of surgical site infections?. Minerva Anestesiologica. 2009;75(9):540-542. Exclusion Codes: GUIDELINE. [pmid: 19644437].
Lansford T, Moncure M, Carlton E, et al. Efficacy of a pneumonia prevention protocol in the reduction of ventilator-associated pneumonia in trauma patients. Surg Infect (Larchmt). 2007;8(5):505-10. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 17999583].
Larson EL, Quiros D, Lin SX. Dissemination of the CDC's Hand Hygiene Guideline and impact on infection rates. American Journal of Infection Control. 2007;35(10):666-675. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18063132].
Laupland KB, Fisman DN. Selective digestive tract decontamination: A tough pill to swallow. Canadian Journal of Infectious Diseases and Medical Microbiology. 2009;20(1):9-11. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20190888].
Law MTE, Kenefick NJ, Hoque SN. Surgical site infection rates in robotic and laparoscopic colorectal surgery: A retrospective, case-control audit. Journal of Hospital Infection. 2011;77(4):364-365. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21316810].
Lazennec JY, Fourniols E, Lenoir T, et al. Infections in the operated spine: update on risk management and therapeutic strategies. Orthop Traumatol Surg Res. 2011;97(6 Suppl):S107-16. Exclusion Codes: GUIDELINES. [pmid: 21856262].
Le TA, Dibley MJ, Vo VN, et al. Reduction in surgical site infections in neurosurgical patients associated with a bedside hand hygiene program in Vietnam. Infect Control Hosp Epidemiol. 2007;28(5):583-8. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17464919].
Lee D, Jung KY, Choi Y. Use of maximal sterile barrier precautions and/or antimicrobial-coated catheters to reduce the risk of central venous catheter-related bloodstream infection. Infection Control & Hospital Epidemiology. 2008;29(10):947-950. Exclusion Codes: REV. [pmid: 18754735].
Lee DH, Jung KY, Choi YH. Use of maximal sterile barrier precautions and/or antimicrobial-coated catheters to reduce the risk of central venous catheter-related bloodstream infection. Infect Control Hosp Epidemiol. 2008;29(10):947-50. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 18754735].
Lee JT. Surgical site infection prevention and unwise process leaning. Surg Infect (Larchmt). 2007;8(3):415-9. Exclusion Codes: COMMENTARY. [pmid: 17635065].
Lee MC, Saxinger L, Forgie SE, et al. Trends in nosocomial bloodstream infections following health care restructuring in Alberta between 1999 and 2005. Canadian Journal of Infectious Diseases and Medical Microbiology. 2010;21(1):e1-e5. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21358873].
Lee SK, Aziz K, Singhal N, et al. Improving the quality of care for infants: a cluster randomized controlled trial. CMAJ. 2009;181(8):469-76. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 19667033].
Lesselroth BJ, Yang J, McConnachie J, et al. Addressing the sociotechnical drivers of quality improvement: a case study of post-operative DVT prophylaxis computerised decision support. BMJ Qual Saf. 2011;20(5):381-9. Exclusion Codes: NOT RELEVANT OUTCOME.
Lettieri CJ, Shah AA, Greenburg DL. An intensivist-directed intensive care unit improves clinical outcomes in a combat zone. Crit Care Med. 2009;37(4):1256-60. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 19242318].
Levent T, Vandevelde D, Delobelle JM, et al. Infection risk prevention following total knee arthroplasty. Orthop Traumatol Surg Res. 2010;96(1):49-56. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 20170857].
Levesque BM, Kalish LA, LaPierre J, et al. Impact of implementing 5 potentially better respiratory practices on neonatal outcomes and costs. Pediatrics. 2011;128(1):e218-e226. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21669893].
Leyngold IM, Nanji A, Chuck RS, et al. Perioperative antibiotics for prevention of acute endophthalmitis after cataract surgery. Cochrane Database of Systematic Reviews. 2007;(1). Exclusion Codes: REVIEW ARTICLE.
L'Heriteau F, Olivier M, Maugat S, et al. Impact of a five-year surveillance of central venous catheter infections in the REACAT intensive care unit network in France. Journal of Hospital Infection. 2007;66(2):123-129. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 17517447].
L'Heriteau F, Olivier M, Maugat S, et al. Impact of a five-year surveillance of central venous catheter infections in the REACAT intensive care unit network in France. Journal of Hospital Infection. 2007;66(2):123-129. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17517447].
Lim S. How nurses should help during surgery. Practice Nurse. 2011;41(14):22-25. Exclusion Codes: COMMENTARY.
Lillie P, Moss P, Thaker H, et al. Development, impact and outcomes of the Hull Bacteraemia Service. QJM. 2008;101(11):889-898. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18805904].
Lin DM, Weeks K, Bauer L, et al. Eradicating Central Line-Associated Bloodstream Infections Statewide: The Hawaii Experience. Am J Med Qual. 2011. Exclusion Codes: NO STATISTICAL ANALYSIS.
Lipitz-Snyderman A, Steinwachs D, Needham DM, et al. Impact of a Statewide intensive care unit quality improvement initiative on hospital mortality and length of stay: retrospective comparative analysis. BMJ. 2011;342:d219. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21282262].
Lipitz-Snyderman A, Needham DM, Colantuoni E, et al. The ability of intensive care units to maintain zero central line-associated bloodstream infections. Arch Intern Med. 2011;171(9):856-8. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21555666].
Lipke VL, Hyott AS. Reducing surgical site infections by bundling multiple risk reduction strategies and active surveillance. AORN Journal. 2010;92(3):288-296. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20816102].
Liu SA, Chiu YT, Lin WD, et al. Using information technology to reduce the inappropriate use of surgical prophylactic antibiotic. European Archives of Oto-Rhino-Laryngology. 2008;265(9):1109-1112. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18246363].
Liu SK, Homa K, Batalden P, et al. Do quality improvement collaboratives improve antimicrobial prophylaxis in surgical patients?. Annals of Internal Medicine. 2009;150(5):358-359. Exclusion Codes: LETTER. [pmid: 19258564].
Lizy C, Brusselaers N, Labeau S, et al. Oral care, ventilator-associated pneumonia, and counting cultures. Am J Crit Care. 2009;18(6):507-8. author reply 508-9. Exclusion Codes: LETTER. [pmid: 19880948].
Lobo RD, Levin AS, Oliveira MS, et al. Evaluation of interventions to reduce catheter-associated bloodstream infection: continuous tailored education versus one basic lecture. American Journal of Infection Control. 2010;38(6):440-448. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 20123149].
Lorente L, Jimenez A, Galvan R, et al. Equivalence of posterior internal jugular and subclavian accesses in the incidence of central venous catheter related bacteremia. Intensive Care Med. 2007;33(12):2230-1. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 17885747].
Lorente L, Jimenez A, Galvan R, et al. Equivalence of posterior internal jugular and subclavian accesses in the incidence of central venous catheter related bacteremia [12]. Intensive Care Medicine. 2007;33(12):2230-2231. Exclusion Codes: LETTER. [pmid: 17885747].
Lorente L, Jimenez A, Castedo J, et al. Internal jugular venous catheter-related bacteremia according to central and posterior accesses. Intensive Care Medicine. 2007;33(6):1071-1075. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17457569].
Lorente L, Lecuona M, Ramos MJ, et al. The use of rifampicin-miconazole-impregnated catheters reduces the incidence of femoral and jugular catheter-related bacteremia. Clin Infect Dis. 2008;47(9):1171-5. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18808356].
Lorente L, Jimenez A, Naranjo C, et al. Higher incidence of catheter-related bacteremia in jugular site with tracheostomy than in femoral site. Infect Control Hosp Epidemiol. 2010;31(3):311-3. Exclusion Codes: LETTER. [pmid: 20109074].
Lubomski LH, Marsteller JA, Hsu YJ, et al. The team checkup tool: evaluating QI team activities and giving feedback to senior leaders. Jt Comm J Qual Patient Saf. 2008;34(10):619-23. 561. Exclusion Codes: GUIDELINE. [pmid: 18947123].
Lucas BM. Leading by example: the physician's role in quality improvement. Mich Med. 2011;110(4):5. Exclusion Codes: LETTER TO EDITOR. [pmid: 21957525].
Luttenberger K. Battling VAP from a new angle. Nursing. 2010;40(2):52-5. Exclusion Codes: NOT RELEVANT QUESTION, NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 20083982].
Lyles A, Fanikos J, Jewell K. Aligning pharmacy and health-system objectives to eliminate central-line-associated bacteremias. American Journal of Health-System Pharmacy. 2009;66(24):2189-2197. Exclusion Codes: COMMENTARY. [pmid: 19966087].
Mackain-Bremner AA, Owens K, Wylde V, et al. Adherence to recommendations designed to decrease intra-operative wound contamination. Annals of the Royal College of Surgeons of England. 2008;90(5):412-416. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18634740].
Madden T, Doble A, Aliyu SH, et al. Infective complications after transrectal ultrasound-guided prostate biopsy following a new protocol for antibiotic prophylaxis aimed at reducing hospital-acquired infections. BJU International. 2011;108(10):1597-1602. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21592292].
Madeo M, Barr B, Owen E. A study to determine whether the use of a preconnect urinary catheter system reduces the incidence of nosocomial urinary tract infections. Journal of Infection Prevention. 2009;10(2):76-80. Exclusion Codes: NOT RELEVANT INTERVENTION.
Maegele M. Re: the role of antibiotic prophylaxis in clean incised hand injuries: a prospective randomized placebo controlled double blind trial, Whittaker JP, Nancarrow JD, Sterne GD, Journal of Hand Surgery, 2005, 30B: 162-167. J Hand Surg Br. 2006;31(2):245. author reply 245-6. Exclusion Codes: LETTER. [pmid: 16343712].
Maenthaisong R, Chaiyakunapruk N, Thamlikitkul V. Cost-effectiveness analysis of chlorhexidine gluconate compared with povidone-iodine solution for catheter-site care in Siriraj Hospital, Thailand. J Med Assoc Thai. Suppl 5. 2006;89:S94-101. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17718250].
Maggiore SM. Endotracheal suctioning, ventilator-associated pneumonia, and costs: open or closed issue?. Intensive Care Med. 2006;32(4):485-7. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16511631].
Main DS, Henderson WG, Pratte K, et al. Relationship of processes and structures of care in general surgery to postoperative outcomes: a descriptive analysis. J Am Coll Surg. 2007;204(6):1157-65. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 17544074].
Makary MA, Ibrahim AM. Surgical care improvement project adherence and postoperative infections. JAMA. 2010;304(15):1670-1. author reply 1671-2. Exclusion Codes: LETTER. [pmid: 20959573].
Maki DG, Rosenthal VD, Salomao R, et al. Impact of switching from an open to a closed infusion system on rates of central line-associated bloodstream infection: a Meta-analysis of time-sequence cohort studies in 4 countries. Infection Control & Hospital Epidemiology. 2011;32(1):50-58. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21121815].
Mammina C, Cala C, Plano MR, et al. Ventilator-associated pneumonia and MRSA ST398, Italy. Emerg Infect Dis. 2010;16(4):730-1. Exclusion Codes: LETTER. [pmid: 20350406].
Mangino JE, Peyrani P, Ford KD, et al. Development and implementation of a performance improvement project in adult intensive care units: Overview of the Improving Medicine Through Pathway Assessment of Critical Therapy in Hospital-Acquired Pneumonia (IMPACT-HAP) study. Critical Care. 2011;15(1). Exclusion Codes: NOT RELEVANT INTERVENTION.
Marra AR, Rodrigues D, Marcelino S, et al. Impact of a program to prevent central line-associated bloodstream infection in the zero tolerance era. American Journal of Infection Control. 2010;38(6):434-439. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 20226570].
Marra AR, Cal RGR, Durao MS, et al. Impact of a program to prevent central line-associated bloodstream infection in the zero tolerance era. American Journal of Infection Control. 2010;38(6):434-439. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 20226570].
Marschall J, Mermel LA, Classen D, et al. Strategies to prevent central line -- associated bloodstream infections in acute care hospitals [corrected]. [published erratum appears in INFECT CONTROL HOSP EPIDEMIOL 2009 Aug;30(8):815]. Infection Control & Hospital Epidemiology. 2008;29:S22-30. Exclusion Codes: GUIDELINE. [pmid: 18840085].
Marschall J, Mermel LA, Classen D, et al. Strategies to prevent central line-associated bloodstream infections in acute care hospitals. Infect Control Hosp Epidemiol. Suppl 1. 2008;29:S22-30. Exclusion Codes: GUIDELINE. [pmid: 18840085].
Martin JE, Speyer LA, Schmults CD. Heightened infection-control practices are associated with significantly lower infection rates in office-based Mohs surgery. Dermatol Surg. Oct. 2010;36(10):1529-36. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20698870].
Martinez EA, Williams KA, Pronovost PJ. Thinking like a pancreas: perioperative glycemic control. Anesth Analg. 2007;104(1):4-6. Exclusion Codes: EDITORIAL. [pmid: 17179236].
Martinez-Capolino C, Reyes K, Johnson L, et al. Impact of active surveillance on Meticillin-resistant Staphylococcus aureus transmission and hospital resource utilisation. Journal of Hospital Infection. 2010;74(3):232-237. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20153553].
Mathews SC, Pronovost PJ. Physician autonomy and informed decision making: finding the balance for patient safety and quality. JAMA. 2008;300(24):2913-5. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19109120].
Mathews SC, Pronovost PJ. Establishing Safety Quality as Core Values: A Hospital Road Map. Am J Med Qual. 2011. Exclusion Codes: COMMENTARY.
Mathias JM. Aiming for tighter glucose control. OR Manager. 2006;22(9):21. Exclusion Codes: COMMENTARY.
Mathias JM. Changing practice for preop hair removal… this article is updated from an article in the January 2004 OR Manager. OR Manager. 2007:13-15. Exclusion Codes: COMMENTARY.
Mathias JM. The right antibiotic at the right time… this article originally appeared in the April 2006 OR Manager. OR Manager. 2007:8-9. Exclusion Codes: COMMENTARY.
Matsushima A, Tasaki O, Tomono K, et al. Pre-emptive contact precautions for intubated patients reduced healthcare-associated Meticillin-resistant Staphylococcus aureus transmission and infection in an intensive care unit. J Hosp Infect. 2011. Exclusion Codes: NOT RELEVANT QUESTION.
Matteucci R, Walsh K. 2011:2. Exclusion Codes: GUIDELINE.
Mayhall CG. In pursuit of ventilator-associated pneumonia prevention: the right path. Clin Infect Dis. 2007;45(6):712-4. Exclusion Codes: COMMENTARY. [pmid: 17712754].
Mazi W, Abdullah D, Gasem G, et al. Reduction of healthcare-associated infections after implementation of bundle programmes in a tertiary care teaching hospital in Saudi Arabia. Clinical Microbiology and Infection. 2011;17:S327-S328. Exclusion Codes: ABSTRACT ONLY.
McBride T, Beamer J. Pre-operative patient preparation in the prevention of surgical site infections. Can Oper Room Nurs J. 2007;25(4):26-7. 29. 32. 34. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18193725].
McCahill LE, Ahern JW, Gruppi LA, et al. Enhancing compliance with Medicare guidelines for surgical infection prevention: experience with a cross-disciplinary quality improvement team. Arch Surg. 2007;142(4):355-61. Exclusion Codes: NOT RELEVANT DESIGN. [pmid: 17438170].
McCann M, Moore ZE. Interventions for preventing infectious complications in haemodialysis patients with central venous catheters. Cochrane Database Syst Rev. 2010;(1):CD006894. Exclusion Codes: REVIEW ARTICLE. [pmid: 20091610].
McCullough P, Benson D. Acid-suppressive medication and hospital-acquired pneumonia. JAMA. 2009;302(13):1415-6. author reply 1416-7. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19809018].
McGoldrick M. Device-related infections and the home care and hospice patient. Home Healthcare Nurse. 2010;28(4):207. Exclusion Codes: EDITORIAL. [pmid: 20520259].
McHugh SM, Corrigan M, Dimitrov B, et al. A targeted e-learning program for surgical trainees to enhance patient safety in preventing surgical infection. J Contin Educ Health Prof. 2010;30(4):257-9. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21171032].
McHugh SM, Hill AD, Humphreys H. Intraoperative technique as a factor in the prevention of surgical site infection. J Hosp Infect. 2011;78(1):1-4. Exclusion Codes: NOT RELEVANT INTERVENTION STRATEGY. [pmid: 21367488].
McHugh SM, O'Donnell J, Leahy A, et al. Transforming management of patients undergoing splenectomy in an Irish teaching hospital. Ir J Med Sci. 2011;180(3):655-9. Exclusion Codes: SAMPLE SIZE UNDER 100. [pmid: 21298492].
McLaws ML, Burrell AR. Zero risk for central line-associated bloodstream infection: Are we there yet?. Crit Care Med. 2011. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION.
McNamara E, Adams D, Dellit TH. Improving central venous catheter insertion documentation to facilitate electronic surveillance of bundle compliance. American Journal of Infection Control. 2011;39(9):779-781. Exclusion Codes: NO STATISTICAL ANALYSIS. [pmid: 21664723].
McQueen A. Decreasing surgical site infections with two percent chlorhexidine: A practice change strategy. Canadian Journal of Cardiology. 2011;27(5):S353-S354. Exclusion Codes: ABSTRACT ONLY.
Metais M, Hebrard A, Duparc A, et al. Cardiac implantable devices: surveillance of surgical site infections and assessment of professional practices. Arch Cardiovasc Dis. 2011;104(5):325-31. Exclusion Codes: NOT RELEVANT DESIGN. [pmid: 21693369].
Meyer D, Klarenbeek R, Meyer F. Current concepts in perioperative care for the prevention of deep surgical site infections in elective spinal surgery. Cen Eur Neurosurg. 2010;71(3):117-20. Exclusion Codes: NOT RELEVANT INTERVENTION.
Miliani K, L'Heriteau F, Astagneau P. Non-compliance with recommendations for the practice of antibiotic prophylaxis and risk of surgical site infection: results of a multilevel analysis from the INCISO Surveillance Network. Journal of Antimicrobial Chemotherapy. 2009;64(6):1307-1315. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 19837713].
Miller MR, Griswold M, Harris Ii JM, et al. Decreasing PICU catheter-associated bloodstream infections: NACHRI's quality transformation efforts. Pediatrics. 2010;125(2):206-213. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 20064860].
Miller RS, Norris PR, Jenkins JM, et al. Systems initiatives reduce healthcare-associated infections: A study of 22,928 device days in a single trauma unit. Journal of Trauma - Injury, Infection and Critical Care. 2010;68(1):23-31. Exclusion Codes: NOT RELEVANT DESIGN.
Milliken VE. Process improvement project utilizing antimicrobial dressings with the goal of reducing the surgical site infection rate. American Journal of Infection Control. 2010;38(5):E95-E96. Exclusion Codes: NOT RELEVANT QUESTION.
Mimoz O, Dahyot-Fizelier C. Prevention of ventilator-associated pneumonia: do not forget to disinfect the mouth. Crit Care Med. 2007;35(2):668-9. Exclusion Codes: EDITORIAL. [pmid: 17251727].
Mittal MK, Dhuper S, Sohal H. Simulation-based training to improve patient care. Arch Intern Med. 2010;170(2):212-3. author reply 213. Exclusion Codes: LETTER. [pmid: 20101021].
Mody L, Bradley SF, Galecki A, et al. Conceptual model for reducing infections and antimicrobial resistance in skilled nursing facilities: focusing on residents with indwelling devices. Clin Infect Dis. 2011;52(5):654-61. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21292670].
Moller AH, Hansen L, Jensen MS, et al. A cost-effectiveness analysis of reducing ventilator-associated pneumonia at a Danish ICU with ventilator bundle. J Med Econ. 2011. Exclusion Codes: NOT RELEVANT OUTCOME.
Mori H, Hirasawa H, Oda S, et al. Oral care reduces incidence of ventilator-associated pneumonia in ICU populations. Intensive Care Med. Feb. 2006;32(2):230-6. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16435104].
Morrow LE, Shorr AF. The seven deadly sins of ventilator-associated pneumonia. Chest. 2008;134(2):225-6. Exclusion Codes: COMMENTARY. [pmid: 18682452].
Morrow LE, Kollef MH, Casale TB. Probiotic Prophylaxis of Ventilator-associated Pneumonia: A Blinded, Randomized, Controlled Trial. American Journal of Respiratory & Critical Care Medicine. 2010;182(8):1058-1064. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20522788].
Moureau NL. Reducing the cost of catheter-related bloodstream infections. Nursing. 2009;39(7):14-5. Exclusion Codes: GUIDELINE. [pmid: 19543031].
Muller AC. Catheter associated blood stream infections. Pa Nurse. 2007;62(4):26-7. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18286845].
Munoz-Price LS, Hota B, Stemer A, Weinstein RA. Prevention of bloodstream infections by use of daily chlorhexidine baths for patients at a long-term acute care hospital. Infection Control & Hospital Epidemiology. 2009;30(11):1031-1035. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19751155].
Munro CL, Grap MJ, Elswick RK Jr., et al. Oral health Status and development of ventilator-associated pneumonia: a descriptive study. Am J Crit Care. 2006;15(5):453-60. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 16926366].
Munro CL, Grap MJ, Jones DJ, et al. Chlorhexidine, toothbrushing, and preventing ventilator-associated pneumonia in critically ill adults. Am J Crit Care. 2009;18(5):428-37. quiz 438. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19723863].
Murjaneh S, Waqar S, Hale JE, et al. National survey of the use of intraoperative antibiotics for prophylaxis against postoperative endophthalmitis following cataract surgery in the UK. Br J Ophthalmol. 2010;94(10):1410-1. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 20710049].
Muscedere J. Ventilator-associated pneumonia and mortality: the controversy continues. Crit Care Med. 2009;37(10):2845-6. Exclusion Codes: EDITORIAL. [pmid: 19865010].
Myatra S, Divatia J. Does glutamine-supplemented total parenteral nutrition reduce the incidence of nosocomial pneumonia?. Crit Care Med. 2006;34(11):2871-2. author reply 2872. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17053590].
Nair BG, Newman SF, Peterson GN, et al. Feedback mechanisms including real-time electronic alerts to achieve near 100% timely prophylactic antibiotic administration in surgical cases. Anesth Analg. 2010;111(5):1293-300. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 20841414].
Nasiriani K, Kalani Z, Farnia F, et al. Comparison of the effect of water vs. povidone-iodine solution for periurethral cleaning in women requiring an indwelling catheter prior to gynecologic surgery. Urologic Nursing. 2009;29(2):118. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19507410].
Nickavar A, Sotoudeh K. Treatment and prophylaxis in pediatric urinary tract infection. International Journal of Preventive Medicine. 2011;2(1):4-9. Exclusion Codes: REVIEW ARTICLE. [pmid: 21448397].
Nicolle LE. The prevention of hospital-acquired urinary tract infection. Clinical Infectious Diseases. 2008;46(2):251-253. Exclusion Codes: COMMENTARY. [pmid: 18171257].
Nicolle LE. Catheter-acquired urinary tract infection: the once and future guidelines. Infect Control Hosp Epidemiol. 2010;31(4):327-9. Exclusion Codes: COMMENTARY. [pmid: 20156063].
Niederman MS. Fighting vampires and ventilator-associated pneumonia: is silver the magic bullet?. Chest. 2010;137(5):1007-9. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20442113].
Niel-Weise BS, Stijnen T Pj. Anti-infective-treated central venous catheters for total parenteral nutrition or chemotherapy: a systematic review. Journal of Hospital Infection. 2008;69(2):114-123. Exclusion Codes: REVIEW ARTICLE. [pmid: 18439717].
Nolan SW, Burkard JF, Clark MJ, et al. Effect of morbidity and mortality peer review on nurse accountability and ventilator-associated pneumonia rates. J Nurs Adm. 2010;40(9):374-83. Exclusion Codes: INSUFFICIENT SAMPLE SIZE. [pmid: 20798620].
Novick RJ, Fox SA, Stitt LW, et al. Impact of the opening of a specialized cardiac surgery recovery unit on postoperative outcomes in an academic health sciences centre. Can J Anaesth. 2007;54(9):737-43. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 17766741].
Nucci M, Anaissie E, Betts RF, et al. Early removal of central venous catheter in patients with candidemia does not improve outcome: Analysis of 842 patients from 2 randomized clinical trials. Clinical Infectious Diseases. 2010;51(3):295-303. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20578829].
O'Brien PJ, Joss JA, Crofts SL. Application of a ventilator care bundle and outcome. Br J Anaesth. 2010;104(1):112. author reply 112-3. Exclusion Codes: LETTER. [pmid: 20007796].
Odetola FO, Dechert RE, Vanderelzen K, et al. Antimicrobial-impregnated catheters for reducing nosocomial catheter-associated blood stream infections in the pediatric intensive care unit. Clinical Intensive Care. 2006;17(1-2):33-40. Exclusion Codes: NOT RELEVANT QUESTION.
Ong J, Miller PS, Appleby R, et al. Effect of a preoperative instructional digital video disc on patient knowledge and preparedness for engaging in postoperative care activities. Nurs Clin North Am. 2009;44(1):103-15. xii. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 19167553].
Osma S, Kahveci SF, Kaya FN, et al. Efficacy of antiseptic-impregnated catheters on catheter colonization and catheter-related bloodstream infections in patients in an intensive care unit. Journal of Hospital Infection. 2006;62(2):156-162. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16307824].
Owens RA. Teaming up to improve the quality of surgical care. American Nurse Today. 2008;3(5):25-26. Exclusion Codes: GUIDELINE.
Owens SM, Brozanski BS, Meyn LA, et al. Antimicrobial prophylaxis for cesarean delivery before skin incision. Obstetrics and Gynecology. 2009;114(3):573-579. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19701037].
Oyston J. The role of anesthesiologists in promoting smoking cessation. Canadian Journal of Anesthesia. 2011;58(10):897-901. Exclusion Codes: EDITORIAL. [pmid: 21717277].
Ozhathil DK, Li Y, Smith JK, et al. Colectomy performance improvement within NSQIP 2005-2008. J Surg Res. 2011;171(1):e9-13. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21872886].
Ozkurt Z, Altoparlak U, Iba Yilmaz S, et al. Reducing hospital infection rates in the burn unit by adherence to infection control measures: A six-year experience. Turkish Journal of Medical Sciences. 2012;42(1):17-24. Exclusion Codes: FOREIGN LANGUAGE ARTICLE.
Palmore TN, Henderson DK. Testing the tube: assessing silver as a potential “silver bullet” for preventing ventilator-associated pneumonia. Crit Care Med. 2010;38(4):1220-1. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20335705].
Palumbo AJ, Loveless PA, Moll ME, et al. Evaluation of healthcare-associated infection surveillance in pennsylvania hospitals. Infect Control Hosp Epidemiol. 2012;33(2):105-11. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 22227977].
Panchabhai TS, Dangayach NS, Krishnan A, et al. Oropharyngeal cleansing with 0.2% chlorhexidine for prevention of nosocomial pneumonia in critically ill patients: An open-label randomized trial with 0.01% potassium permanganate as control. Chest. 2009;135(5):1150-1156. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19420193].
Panchabhai TS, Dangayach NS. Role of chlorhexidine gluconate in ventilator-associated pneumonia prevention strategies in ICU patients: where are we headed?. Crit Care. 2009;13(6):427. Exclusion Codes: LETTER. [pmid: 20017886].
Parienti JJ, Thirion M, Megarbane B, et al. Femoral vs jugular venous catheterization and risk of nosocomial events in adults requiring acute renal replacement therapy: a randomized controlled trial. JAMA. 2008;299(20):2413-22. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18505951].
Parikh SN, Grice SS, Schnell BM, et al. Operating room traffic: Is there any role of monitoring it?. Journal of Pediatric Orthopaedics. 2010;30(6):617-623. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20733430].
Park HG, Choi SH. Long-term central venous catheter salvage in patients with bacillus bacteremia. Medicine. 2010;89(5):346-346. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20827112].
Parker D, Callan L, Harwood J, et al. Nursing interventions to reduce the risk of catheter-associated urinary tract infection. Part 1: catheter selection. Journal of Wound, Ostomy & Continence Nursing. 2009;36(1):23-34. Exclusion Codes: REVIEW ARTICLE.
Pasqualotto AC, de Moraes AB, Zanini RR, et al. Analysis of independent risk factors for death among pediatric patients with candidemia and a central venous catheter in place. Infect Control Hosp Epidemiol. 2007;28(7):799-804. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17564981].
Passerini R, Biffi R, Riggio D, et al. Laboratory-based management of microbiological alerts: Effects of an automated system on the surveillance and treatment of nosocomial infections in an oncology hospital. ecancermedicalscience. 2009;3(1). Exclusion Codes: NOT RELEVANT QUESTION.
Patrick S, James C, Ali A, et al. Vascular surgical antibiotic prophylaxis study (VSAPS). Vasc Endovascular Surg. 2010;44(7):521-8. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20675336].
Patrizzi K, Fasnacht A, Manno M. A collaborative, nurse-driven initiative to reduce hospital-acquired urinary tract infections. J Emerg Nurs. 2009;35(6):536-9. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 19914479].
Patterson P. National study probes ties between ‘best practices,’ surgical infection. OR Manager. 2009;25(2):1. Exclusion Codes: GUIDELINE.
Patterson P. Quality reporting: what comes after SCIP?. OR Manager. 2011;27(10):19-20. Exclusion Codes: COMMENTARY.
Paull DE, Mazzia LM, Izu BS, et al. Predictors of successful implementation of preoperative briefings and postoperative debriefings after medical team training. Am J Surg. 2009;198(5):675-8. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 19887198].
Payne NR, Barry J, Berg W, et al. Sustained Reduction in Neonatal Nosocomial Infections Through Quality Improvement Efforts. Pediatrics. 2012;129(1):e165-e173. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 22144702].
Pear S. SCIP: the perioperative leader's key role… Surgical Care Improvement Project. OR Manager. 2007:5-6. Exclusion Codes: GUIDELINE.
Pear SM, Williamson TH. The RN first assistant: an expert resource for surgical site infection prevention. AORN J. 2009;89(6):1093-7. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19500700].
Penel N, Yazdanpanah Y, Chauvet MP, et al. Prevention of surgical site infection after breast cancer surgery by targeted prophylaxis antibiotic in patients at high risk of surgical site infection. J Surg Oncol. 2007;96(2):124-9. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17443747].
Penson DF. Hospital-acquired catheter-associated urinary tract infection: Documentation and coding issues may reduce financial impact of medicares new payment policy. Journal of Urology. 2011;185(2):540-541. Exclusion Codes: EDITORIAL.
Peterson GN, Hennessey S, Westby J, et al. Modifying the universal protocol for effective delivery of perioperative prophylactic antibiotics. Joint Commission Journal on Quality & Patient Safety. 2006;32(2):92-94. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16568922].
Pfefferkorn U, Lea S, Moldenhauer J, et al. Antibiotic prophylaxis at urinary catheter removal prevents urinary tract infections: a prospective randomized trial. Ann Surg. 2009;249(4):573-5. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19300235].
Pineda LA, Saliba RG, El Solh AA. Effect of oral decontamination with chlorhexidine on the incidence of nosocomial pneumonia: A Meta-analysis. Critical Care. 2006;10(1). Exclusion Codes: META-ANALYSIS.
Pittet D, Zingg W. Reducing ventilator-associated pneumonia: when process control allows outcome improvement and even benchmarking. Crit Care Med. 2010;38(3):983-4. Exclusion Codes: EDITORIAL. [pmid: 20168154].
Pobo A, Lisboa T, Rodriguez A, et al. A randomized trial of dental brushing for preventing ventilator-associated pneumonia. Chest. 2009;136(2):433-9. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19482956].
Pofahl WE, Goettler CE, Ramsey KM, et al. Active surveillance screening of MRSA and eradication of the carrier State decreases surgical-site infections caused by MRSA. J Am Coll Surg. 2009;208(5):981-6. discussion 986-8. Exclusion Codes: COMMENTARY. [pmid: 19476875].
Pogorzelska M, Stone PW, Furuya EY, et al. Impact of the ventilator bundle on ventilator-associated pneumonia in intensive care unit. Int J Qual Health Care. 2011;23(5):538-44. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21821603].
Poon H, Ho P, Ng S, et al. Quality and safety care for patients with invasive mechanical ventilation (IMV). Respirology. 2011;16:6. Exclusion Codes: ABSTRACT ONLY.
Popovich KJ, Hota B, Hayes R, et al. Effectiveness of routine patient cleansing with chlorhexidine gluconate for infection prevention in the medical intensive care unit. Infection Control & Hospital Epidemiology. 2009;30(10):959-963. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19712033].
Popovich KJ, Hota B, Hayes R, et al. Daily skin cleansing with chlorhexidine did not reduce the rate of central-line associated bloodstream infection in a surgical intensive care unit. Intensive Care Med. 2010;36(5):854-8. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20213074].
Portigliatti B, Mognetti M, Pecoraro B, et al. Decolonization of orthopedic surgical team S. aureus carriers: impact on surgical-site infections. J Orthop Traumatol. 2010;11(1):47-9. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20119678].
Power A, Duncan N, Singh SK, et al. Sodium citrate versus heparin catheter locks for cuffed central venous catheters: a single-center randomized controlled trial. American Journal of Kidney Diseases. 2009;53(6):1034-1041. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19394731].
Powers J, Brower A, Tolliver S. Impact of oral hygiene on prevention of ventilator-associated pneumonia in neuroscience patients. J Nurs Care Qual. 2007;22(4):316-21. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 17873728].
Prasad A, Cevallos ME, Riosa S, et al. A bacterial interference strategy for prevention of UTI in persons practicing intermittent catheterization. Spinal Cord. 2009;47(7):565-569. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19139758].
Prasad M, Holmboe ES, Lipner RS, et al. Clinical protocols and trainee knowledge about mechanical ventilation. JAMA - Journal of the American Medical Association. 2011;306(9):935-941. Exclusion Codes: NOT RELEVANT QUESTION.
Principi N, Esposito S. Ventilator-associated pneumonia (VAP) in pediatric intensive care units. Pediatr Infect Dis J. 2007;26(9):841-3. discussion 843-4. Exclusion Codes: COMMENTARY. [pmid: 17721382].
Prior AR, Ray R, O'Gorman J, et al. Screening of healthcare workers for meticillin-resistant Staphylococcus aureus: Is it worth it?. Journal of Hospital Infection. 2011;79(3):274-275. Exclusion Codes: LETTER TO EDITOR. [pmid: 21741725].
Pronovost P, Needham D, Berenholtz S, et al. An intervention to decrease catheter-related bloodstream infections in the ICU. N Engl J Med. 2006;355(26):2725-32. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 17192537].
Pronovost P. Interventions to decrease catheter-related bloodstream infections in the ICU: the Keystone Intensive Care Unit Project. Am J Infect Control. 2008;36(10):S171 e1-5. Exclusion Codes: GUIDELINE. [pmid: 19084146].
Pronovost PJ, Martinez EA, Rodriguez-Paz JM. Removing “orange wires”: surfacing and hopefully learning from mistakes. Intensive Care Med. 2006;32(10):1467-9. Exclusion Codes: EDITORIAL. [pmid: 16874491].
Pronovost PJ, Berenholtz SM, Goeschel C, et al. Improving patient safety in intensive care units in Michigan. J Crit Care. 2008;23(2):207-21. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18538214].
Pronovost PJ, Berenholtz SM, Goeschel CA. Improving the quality of measurement and evaluation in quality improvement efforts. Am J Med Qual. 2008;23(2):143-6. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18230870].
Pronovost PJ, Combes J, Joshi M. An executive checklist. Hosp Health Netw. 2009;83(11):52. Exclusion Codes: GUIDELINE. [pmid: 20063604].
Pronovost PJ, Murphy DJ, Needham DM. The science of translating research into practice in intensive care. Am J Respir Crit Care Med. 2010;182(12):1463-4. Exclusion Codes: EDITORIAL. [pmid: 21159904].
Pronovost PJ, Marsteller JA, Goeschel CA. Preventing bloodstream infections: a measurable national success story in quality improvement. Health Aff (Millwood). 2011;30(4):628-34. Exclusion Codes: REVIEW ARTICLE. [pmid: 21471482].
Pronovost PJ. Other voices What's next in the drive to eliminate preventable harm and cut costs?. Hosp Health Netw. 20. 2011;85(10):18-1. Exclusion Codes: COMMENTARY. [pmid: 22111261].
Pronovost P. Zero tolerance. Hospital executives play a key role in defeating deadly infections. Mod Healthc. 2011;(Suppl):58. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21936472].
Prospero E, Barbadoro P, Marigliano A, et al. Perioperative antibiotic prophylaxis: improved compliance and impact on infection rates. Epidemiol Infect. 2010:1-6. Exclusion Codes: NOT RELEVANT DESIGN.
Prospero E, Barbadoro P, Marigliano A, et al. Perioperative antibiotic prophylaxis: improved compliance and impact on infection rates. Epidemiol Infect. 2011;139(9):1326-31. Exclusion Codes: NOT RELEVANT DESIGN. [pmid: 21087536].
Quesada A, Ballesteros MA, Buron FJ, et al. Strategies to optimize care and safety of critically ill patients: Analysis and evaluation of a training course for ICU nurses and physicians. Intensive Care Medicine. 2010;36:S150. Exclusion Codes: NOT RELEVANT INTERVENTION.
Quiles MB, Llanos GS, Gonzalez RF, et al. Ventilator associated pneumonia: Incidence, etiology, and preventive strategies. Critical Care and Shock. 2009;12(1):16-23. Exclusion Codes: NOT RELEVANT INTERVENTION.
Ramos ER, Reitzel R, Jiang Y, et al. Clinical effectiveness and risk of emerging resistance associated with prolonged use of antibiotic-impregnated catheters: More than 0.5 million catheter days and 7 years of clinical experience. Critical Care Medicine. 2011;39(2):245-251. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 21057308].
Ramritu P, Halton K, Collignon P, et al. A systematic review comparing the relative effectiveness of antimicrobial-coated catheters in intensive care units. American Journal of Infection Control. 2008;36(2):104-117. Exclusion Codes: REVIEW ARTICLE. [pmid: 18313512].
Rangachari P, Hutchinson DM. A systems approach to improving core measure outcomes in a small rural facility. Journal for Healthcare Quality: Promoting Excellence in Healthcare. 2006;28(5):37-43. Exclusion Codes: NOT RELEVANT OUTCOME.
Rangel-Frausto MS, Higuera-Ramirez F, Martinez-Soto J, et al. Should we use closed or open infusion containers for prevention of bloodstream infections?. Annals of Clinical Microbiology and Antimicrobials. 2010;9. Exclusion Codes: NOT RELEVANT INTERVENTION.
Rao N, Cannella B, Crossett LS, et al. A preoperative decolonization protocol for staphylococcus aureus prevents orthopaedic infections. Clinical Orthopaedics and Related Research. 2008;466(6):1343-1348. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18404296].
Rebasa P, Mora L, Luna A, et al. Continuous monitoring of adverse events: Influence on the quality of care and the incidence of errors in general surgery. World Journal of Surgery. 2009;33(2):191-198. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19082657].
Reilly L, Sullivan P, Ninni S, et al. Reducing foley catheter device days in an intensive care unit: using the evidence to change practice. AACN Advanced Critical Care. 2006;17(3):272-283. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 16931923].
Render ML, Hasselbeck R, Freyberg RW, et al. Reduction of central line infections in Veterans Administration intensive care units: an observational cohort using a central infrastructure to support learning and improvement. BMJ Qual Saf. Aug. 2011;20(8):725-32. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 21460392].
Rey C, Alvarez F, De-La-Rua V, et al. Intervention to reduce catheter-related bloodstream infections in a pediatric intensive care unit. Intensive Care Medicine. 2011;37(4):678-685. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21271236].
Reyes GE, Chang PS. Prevention of surgical site infections: Being a winner. Operative Techniques in Sports Medicine. 2011;19(4):238-244. Exclusion Codes: COMMENTARY.
Ricard JD. Gold standard for humidification: heat and moisture exchangers, heated humidifiers, or both?. Crit Care Med. 2007;35(12):2875-6. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18043216].
Richards MJ, Russo PL. Surveillance of hospital-acquired infections in Australia - One Nation, Many States. Journal of Hospital Infection. 2007;65(SUPPL. 2):174-181. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17540266].
Richardson A. Minimising central venous catheter-associated bloodstream infections -- ‘Matching Michigan’ in England. Nursing in Critical Care. 2009;14(3):105-106. Exclusion Codes: reason. [pmid: 19366405].
Richter JM, Brilli RJ. It's all about dwell time---reduce it and infection rates decrease?. Sengupta A, Lehmann C, Diener-West M et al. Catheter duration and risk of central line--associated bloodstream infection in NICU patients with peripherally inserted central venous catheters. Pediatrics 2010;125(4):648-653. Pediatrics. 2010;125(4):820-821. Exclusion Codes: EDITORIAL. [pmid: 20308217].
Rijnders ABJ. Replacement of intravascular catheters to prevent infection: Evidence still missing while the question may become irrelevant. Critical Care Medicine. 2010;38(4):1208-1209. Exclusion Codes: EDITORIAL. [pmid: 20335698].
Ristic S, Miljkovic B, Vezmar S, Stanojevic D. Are local clinical guidelines useful in promoting rational use of antibiotic prophylaxis in caesarean delivery?. Pharm World Sci. 2010;32(2):139-45. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 20039207].
Roberts K, Naik R. Urinary catheters. Catheterization options following radical surgery for cervical cancer. British Journal of Nursing (BJN). 2006;15(19):1038. Exclusion Codes: NOT RELEVANT QUESTION.
Robinson LD, Paull DE, Mazzia LM, et al. The role of the operating room nurse manager in the successful implementation of preoperative briefings and postoperative debriefings in the VHA Medical Team Training Program. J Perianesth Nurs. 2010;25(5):302-6. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 20875885].
Robinson S, Allen L, Barnes MR, et al. Development of an evidence-based protocol for reduction of indwelling urinary catheter usage. MEDSURG Nursing. 2007;16(3):157-161. Exclusion Codes: INSUFFICIENT SAMPLE SIZE. [pmid: 17849921].
Rodriguez D, Park BJ, Almirante B, et al. Impact of early central venous catheter removal on outcome in patients with candidaemia. Clin Microbiol Infect. 2007;13(8):788-93. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17610598].
Rodriguez-Paz JM, Pronovost P. Prevention of catheter-related bloodstream infections. Adv Surg. 2008;42:229-48. Exclusion Codes: GUIDELINE. [pmid: 18953821].
Roesler R, Halowell CC, Elias G, et al. Chasing zero: our journey to preventing surgical site infection. AORN Journal. 2010;91(2):224. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 20152196].
Rogues AM, Lasheras A, Amici JM, et al. Infection control practices and infectious complications in dermatological surgery. J Hosp Infect. 2007;65(3):258-63. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 17244515].
Rollow W, Lied TR, McGann P, et al. Assessment of the Medicare Quality Improvement Organization Program. Annals of Internal Medicine. 2006;145(5):342-353. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16908911].
Rose L, Baldwin I, Crawford T, et al. Semirecumbent positioning in ventilator-dependent patients: a multicenter, observational study. Am J Crit Care. 2010;19(6):e100-8. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 21041187].
Rosenberger LH, Politano AD, Sawyer RG. The surgical care improvement project and prevention of post-operative infection, including surgical site infection. Surg Infect (Larchmt). 2011;12(3):163-8. Exclusion Codes: SYSTEMATIC REVIEW. [pmid: 21767148].
Rosenthal VD, Maki DG, Mehta A, et al. International Nosocomial Infection Control Consortium report, data summary for 2002-2007, issued January 2008. American Journal of Infection Control. 2008;36(9):627-637. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18834725].
Rosenthal VD, Maki DG, Rodrigues C, et al. Impact of International Nosocomial Infection Control Consortium (INICC) strategy on central line-associated bloodstream infection rates in the intensive care units of 15 developing countries. Infection Control & Hospital Epidemiology. 2010;31(12):1264-1272. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 21029008].
Rosenthal VD, Maki DG, Rodrigues C, et al. Impact of International Nosocomial Infection Control Consortium (INICC) strategy on central line-associated bloodstream infection rates in the intensive care units of 15 developing countries. Infection Control and Hospital Epidemiology. 2010;31(12):1264-1272. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 21029008].
Rosenthal VD, Maki DG, Rodrigues C, et al. Impact of International Nosocomial Infection Control Consortium (INICC) strategy on central line-associated bloodstream infection rates in the intensive care units of 15 developing countries. Infect Control Hosp Epidemiol. 2010;31(12):1264-72. Exclusion Codes: NO BASELINE DATA. [pmid: 21029008].
Rosenthal VD, Maki DG, Jamulitrat S, et al. International Nosocomial Infection Control Consortium (INICC) report, data summary for 2003-2008, issued June 2009. American Journal of Infection Control. 2010;38(2):95-104.e2. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20176284].
Rosenthal VD, Udwadia FE, Munoz HJ, et al. Time-dependent analysis of extra length of stay and mortality due to ventilator-associated pneumonia in inte sive-care units of ten limited-resources countries: Findings of the International Nosocomial Infection Control Consortium (INICC). Epidemiology and Infection. 2011;139(11):1757-1763. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21320374].
Roumbelaki M, Kritsotakis EI, Tsioutis C, et al. Surveillance of surgical site infections at a tertiary care hospital in Greece: incidence, risk factors, microbiology, and impact. Am J Infect Control. 2008;36(10):732-8. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18834729].
Rowell KS, Turrentine FE, Hutter MM, et al. Use of National Surgical Quality Improvement Program Data as a Catalyst for Quality Improvement. Journal of the American College of Surgeons. 2007;204(6):1293-1300. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17544087].
Rumbak M, Cancio M, Munoz-Price LS, et al. Prevention of infection caused by gram-positive bacteria in the bloodstream and lungs. Munoz-Price LS, Hota B, Stemer A, et al. Prevention of bloodstream infections by use of daily chlorhexidine baths for patients at a long-term acute care hospital. Infect Control Hosp Epidermiol 2009;30(11):1031-1035. Infection Control & Hospital Epidemiology. 2010;31(8):879-880. Exclusion Codes: LETTER. [pmid: 20608829].
Ruschulte H, Franke M, Gastmeier P, et al. Prevention of central venous catheter related infections with chlorhexidine gluconate impregnated wound dressings: a randomized controlled trial. Ann Hematol. 2009;88(3):267-72. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18679683].
Ryckman FC, Schoettker PJ, Hays KR, et al. Reducing surgical site infections at a pediatric academic medical center. Joint Commission Journal on Quality & Patient Safety. 2009;35(4):192-198. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 19435158].
Sabria M, Sopena N. Nosocomial pneumonia outside the intensive care unit. Clinical Pulmonary Medicine. 2011;18(5):215-221. Exclusion Codes: NOT RELEVANT QUESTION.
Safdar N, Abad CL. Adherence to evidence-based recommendations for prevention of ventilator-associated pneumonia: the survey says. Respir Care. 2007;52(12):1678-9. Exclusion Codes: EDITORIAL. [pmid: 18028555].
Saint S, Kaufman SR, Rogers MA, et al. Condom versus indwelling urinary catheters: a randomized trial. J Am Geriatr Soc. 2006;54(7):1055-61. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 16866675].
Salomon J, Denys P, Merle C, et al. Prevention of urinary tract infection in spinal cord-injured patients: safety and efficacy of a weekly oral cyclic antibiotic (WOCA) programme with a 2 year follow-up--an observational prospective study. J Antimicrob Chemother. 2006;57(4):784-8. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16473921].
Samra JS, Bachmann RA, Choi J, et al. One hundred and seventy-eight consecutive pancreatoduodenectomies without mortality: role of the multidisciplinary approach. Hepatobiliary Pancreat Dis Int. 2011;10(4):415-21. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21813392].
Sanders J, Pithie A, Ganly P, et al. A prospective double-blind randomized trial comparing intraluminal ethanol with heparinized saline for the prevention of catheter-associated bloodstream infection in immunosuppressed haematology patients. Journal of Antimicrobial Chemotherapy. 2008;62(4):809-815. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18621987].
Sandifer C. Urinary catheters. Nurs Stand. 2010;24(41):59-60. Exclusion Codes: COMMENTARY. [pmid: 20608341].
Sannoh S, Clones B, Munoz J, et al. A multimodal approach to central venous catheter hub care can decrease catheter-related bloodstream infection. American Journal of Infection Control. 2010;38(6):424-429. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 20137829].
Sannoh S, Clones B, Munoz J, et al. A multimodal approach to central venous catheter hub care can decrease catheter-related bloodstream infection. American Journal of Infection Control. 2010;38(6):424-429. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 20137829].
Santana SL, Furtado GHC, Wey SB, et al. Impact of an education program on the incidence of central line-associated bloodstream infection in 2 medical-surgical intensive care units in Brazil. Infection Control & Hospital Epidemiology. 2008;29(12):1171-1173. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 18956978].
Saramma PP, Krishnakumar K, Sarma PS. Alcohol-based hand rub and surgical site infection after elective neurosurgery: an intervention. Neurol India. 2011;59(1):12-7. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 21339652].
Sato T, Takayama T, Fujii M, et al. Systemic use of antibiotics does not prevent postoperative infection in elective colorectal surgery: a randomized controlled trial. J Infect Chemother. 2009;15(1):34-8. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 19280298].
Sauve KJ, Schultz J. Mind the gap: Port security-identifying potential risk from unprotected intravenous line stopcocks. Anesthesia and Analgesia. 2011;112(5). Exclusion Codes: ABSTRACT ONLY.
Saveli CC, Belknap RW, Morgan SJ, et al. The role of prophylactic antibiotics in open fractures in an era of COMMENTARYmunity-acquired methicillin-resistant Staphylococcus aureus. Orthopedics. 2011;34(8):611-6. quiz 617. Exclusion Codes: SYSTEMATIC REVIEW. [pmid: 21800816].
Saxer F, Widmer A, Fehr J, et al. Benefit of a single preoperative dose of antibiotics in a sub-saharan district hospital: minimal input, massive impact. Ann Surg. 2009;249(2):322-6. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 19212189].
Scales DC, Ferguson ND. Early vs late tracheotomy in ICU patients. JAMA. 2010;303(15):1537-8. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20407065].
Schade VL, Roukis TS. Use of a surgical preparation and sterile dressing change during office visit treatment of chronic foot and ankle wounds decreases the incidence of infection and treatment costs. Foot Ankle Spec. 2008;1(3):147-54. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 19825709].
Schelonka RL, Scruggs S, Nichols K, et al. Sustained reductions in neonatal nosocomial infection rates following a comprehensive infection control intervention. Journal of Perinatology. 2006;26(3):176-179. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 16341027].
Schroth L, Shelly M, Curle A, et al. The Highs And Lows of Perioperative Glycemic Control. Journal of PeriAnesthesia Nursing. 2011;26(3):195-196. Exclusion Codes: NO STATISTICAL ANALYSIS.
Schulman J, Stricof RL, Stevens TP, et al. Development of a Statewide collaborative to decrease NICU central line-associated bloodstream infections. Journal of Perinatology. 2009;29(9):591-599. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 19262569].
Schulman J, Stricof R, Stevens TP, et al. Statewide NICU central-line-associated bloodstream infection rates decline after bundles and checklists. Pediatrics. 2011;127(3):436-444. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 21339265].
Schultz MJ, Determann RM, Juffermans NP. Ventilator-associated pneumonia prevention: WHAP, positive end-expiratory pressure, or both?. Crit Care Med. 2008;36(8):2441-2. Exclusion Codes: EDITORIAL. [pmid: 18664791].
Schultz MJ, Juffermans NP. Prevention of VAP: “WHAP” should we do?. Crit Care Med. 2010;38(2):706-7. Exclusion Codes: COMMENTARY. [pmid: 20083936].
Schultz MJ. Symbiotics as a preventive measure against ventilator-associated pneumonia. Crit Care Med. 2010;38(6):1506-7. author reply 1507. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20502161].
Schumm K, Lam TBL. Types of urethral catheters for management of short-term voiding problems in hospitalised adults. Cochrane Database of Systematic Reviews. 2009;(4). Exclusion Codes: NOT RELEVANT QUESTION.
Schwab F, Geffers C, Barwolff S, et al. Reducing neonatal nosocomial bloodstream infections through participation in a national surveillance system. J Hosp Infect. 2007;65(4):319-25. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17350730].
Schweon S. Stamping out surgical site infections. RN. 2006;69(8):36-40. quiz 41. Exclusion Codes: GUIDELINE. [pmid: 16939134].
Seal DV, Barry P, Gettinby G, et al. ESCRS study of prophylaxis of postoperative endophthalmitis after cataract surgery. Case for a European multicenter study. Journal of Cataract and Refractive Surgery. 2006;32(3):396-406. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16631046].
Seckel M. Is this research ready to be translated into practice?. AACN Adv Crit Care. 2009;20(4):322-4. Exclusion Codes: EDITORIAL. [pmid: 19893369].
Seckel MA. Ask the experts Does the use of a closed suction system help to prevent ventilator-associated pneumonia?O. Crit Care Nurse. 2008;28(1):65-6. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18238938].
Seddon ME, Hocking CJ, Mead P, et al. Aiming for zero: Decreasing central line associated bacteraemia in the intensive care unit. New Zealand Medical Journal. 2011;124(1339):9-21. Exclusion Codes: NO STATISTICAL ANALYSIS. [pmid: 21952326].
Segers P, de Jong AP, Spanjaard L, et al. Randomized clinical trial comparing two options for postoperative incisional care to prevent poststernotomy surgical site infections. Wound Repair Regen. 2007;15(2):192-6. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17352750].
Segers P, de Mol BA. Prevention of ventilator-associated pneumonia after cardiac surgery: prepare and defend!. Intensive Care Med. 2009;35(9):1497-9. Exclusion Codes: EDITORIAL. [pmid: 19557390].
Sekhavat L, Farajkhoda T, Davar R. The effect of early removal of indwelling urinary catheter on postoperative urinary complications in anterior colporrhaphy surgery. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2008;48(3):348-352. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18532970].
Selcuk H, Kanbay M, Korkmaz M, et al. Route of nutrition has no effect on the development of infectious complications. Journal of the National Medical Association. 2006;98(12):1963-1966. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17225842].
Sellier E, Labarere J, Gennai S, et al. Compliance with recommendations and clinical OUTCOMEes for formal and informal infectious disease specialist consultations. European Journal of Clinical Microbiology and Infectious Diseases. 2011;30(7):887-894. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21311942].
Septimus EJ, Owens RC Jr. Need and potential of antimicrobial stewardship in community hospitals. Clinical Infectious Diseases. 2011;53(SUPPL. 1):S8-S14. Exclusion Codes: COMMENTARY. [pmid: 21795728].
Serra-Aracil X, Garcia-Domingo MI, Pares D, et al. Surgical site infection in elective operations for colorectal cancer after the application of preventive measures. Arch Surg. 2011;146(5):606-12. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21576613].
Sevin A, Senen D, Sevin K, et al. Antibiotic use in abdominoplasty: prospective analysis of 207 cases. J Plast Reconstr Aesthet Surg. 2007;60(4):379-82. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 17349592].
Sexton JB, Berenholtz SM, Goeschel CA, et al. Assessing and improving safety climate in a large cohort of intensive care units. Crit Care Med. 2011;39(5):934-9. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21297460].
Shapey IM, Foster MA, Whitehouse T, et al. Central venous catheter-related bloodstream infections: improving post-insertion catheter care. Journal of Hospital Infection. 2009;71(2):117-122. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19013680].
Sharma MS, Vohra A, Thomas P, et al. Effect of risk-stratified, protocol-based perioperative chemoprophylaxis on nosocomial infection rates in a series of 31 927 consecutive neurosurgical procedures (1994-2006). Neurosurgery. 2009;64(6):1123-30. discussion 1130-1. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19487892].
Sharma R. Mouth to tube ventilation. Resuscitation. 2008;79(1):174. Exclusion Codes: LETTER. [pmid: 18678439].
Shelly MA, Concannon C, Dumyati G. Device use ratio measured weekly can reliably estimate central line-days for central line-associated bloodstream infection rates. Infection Control & Hospital Epidemiology. 2011;32(7):727-730. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21666408].
Sheridan-Leos N. Oncology care setting design and planning part II: designing healthcare settings to prevent fungal infections and improve handwashing. Clin J Oncol Nurs. 2008;12(3):521-5. Exclusion Codes: REVIEW ARTICLE. [pmid: 18515252].
Shime N, Morrow LE. Current practices for ventilator-associated pneumonia prevention in Japan: A survey study. Chest. 2012;141(1):281-283. Exclusion Codes: LETTER TO EDITOR. [pmid: 22215846].
Shobha KL, Ramachandra L, Rao SP. Comparison of Povodine-Iodine versus Savlon for pre-catheterization cleansing and the association of bacteriuria with its antibiotic susceptibility in catheterised patients of the surgical ward. Journal of Clinical and Diagnostic Research. 2008;2(4):991-996. Exclusion Codes: NOT RELEVANT QUESTION.
Siddiqui S, Khan MS, Siddiqui SZ, et al. Infection control education: Impact on ventilator - Asscoatied pneumonia rates in a public sector intensive care unit in Pakistan. Anaesthesia, Pain and Intensive Care. 2011;15(2):157. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION.
Siempos II, Vardakas KZ, Kopterides P, et al. Impact of passive humidification on clinical outcomes of mechanically ventilated patients: A Meta-analysis of randomized controlled trials. Critical Care Medicine. 2007;35(12):2843-2851. Exclusion Codes: META-ANALYSIS. [pmid: 18074484].
Siempos II, Falagas ME. Oral decontamination with chlorhexidine reduces the incidence of nosocomial pneumonia [1]. Critical Care. 2007;11. Exclusion Codes: LETTER.
Silva J, Teixeira e Costa, et al. Catheter-related bacteremia in hemodialysis: which preventive measures to take?. Nephron Clin Pract. 2008;110(4):c251-7. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18974657].
Silvestri L, van Saene HK, Sarginson RE, et al. Selective decontamination of the digestive tract and ventilator-associated pneumonia: we cannot let misinformation go uncorrected. J Intensive Care Med. 2007;22(3):181-2. author reply 183. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17562740].
Silvestri L, van Saene JJ, van Saene HK, et al. Topical chlorhexidine and ventilator-associated pneumonia. Crit Care Med. 2007;35(10):2468. Exclusion Codes: LETTER. [pmid: 17885406].
Silvestri L, van Saene HK, de la Cal MA, et al. Prevention of ventilator-associated pneumonia by selective decontamination of the digestive tract. Eur Respir J. 2008;32(1):241-3. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18591346].
Silvestri L, van Saene HK, Milanese M, et al. Prevention of ventilator-associated pneumonia by use of oral chlorhexidine. Infect Control Hosp Epidemiol. 2009;30(1):101-2. author reply 102-3. Exclusion Codes: LETTER. [pmid: 19067601].
Silvestri L, van Saene HK, Gregori D, et al. Probiotics to prevent ventilator-associated pneumonia: no robust evidence from randomized controlled trials. Crit Care Med. 2010;38(7):1616-7. author reply 1617. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20562560].
Silvestri L, Gregori D, van Saene HK, et al. Semirecumbent position to prevent ventilator-associated pneumonia is not evidence based. J Crit Care. 2010;25(1):152-3. author reply 153-4. Exclusion Codes: LETTER. [pmid: 19828285].
Simon A, Fleischhack G, Wiszniewsky G, et al. Influence of prolonged use of intravenous administration sets in paediatric cancer patients on CVAD-related bloodstream infection rates and hospital resources. Infection. 2006;34(5):258-63. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17033749].
Simpson AHRW, Dave J, Cookson B. The value of routine screening of staff for MRSA. Journal of Bone and Joint Surgery - Series B. 2007;89(5):565-566. Exclusion Codes: EDITORIAL.
Sjogren P, Nilsson E, Forsell M, et al. A systematic review of the preventive effect of oral hygiene on pneumonia and respiratory tract infection in elderly people in hospitals and nursing homes: effect estimates and Methodological quality of randomized controlled trials. J Am Geriatr Soc. 2008;56(11):2124-30. Exclusion Codes: REVIEW ARTICLE. [pmid: 18795989].
Skelly J. Automatic stop orders reduced duration of indwelling urinary catheterisation in hospital. Evidence Based Nursing. 2008;11(4):119-119. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 18815331].
Slekovec C, Gbaguidi-Haore H, Coignard B, et al. Relationship between prevalence of device-associated infections and alcohol-based hand-rub consumption: a multi-level approach. J Hosp Infect. 2011. Exclusion Codes: NOT RELEVANT QUESTION.
Slobbe L, Doorduijn JK, Lugtenburg PJ, et al. Prevention of catheter-related bacteremia with a daily ethanol lock in patients with tunnelled catheters: A randomized, placebo-controlled trial. PLoS One. 2010;5(5). Exclusion Codes: NOT RELEVANT INTERVENTION.
Slover J, Haas JP, Quirno M, et al. Cost-Effectiveness of a Staphylococcus aureus Screening and Decolonization Program for High-Risk Orthopedic Patients. J Arthroplasty. 2011;26(3):360-5. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20452175].
Smith SL. Effect of an educational intervention on hospital acquired urinary tract infection rates. D.N.P. 2009:80. Exclusion Codes: NOT RELEVANT QUESTION.
Smith L, Elamin E. Implementation of evidence-based guidelines in reducing catheter related bloodstream infections. Chest. 2011;140(4). Exclusion Codes: ABSTRACT ONLY.
Smith MA, Jacobs L, Rodier L, et al. Clinical quality indicators: infection prophylaxis for total knee arthroplasty. Orthopaedic Nursing. 2011;30(5):301-306. Exclusion Codes: EDITORIAL. [pmid: 21934582].
Snaterse M, Ruger W, Scholte Op, et al. Antibiotic-based catheter lock solutions for prevention of catheter-related bloodstream infection: a systematic review of randomised controlled trials. J Hosp Infect. 2010;75(1):1-11. Exclusion Codes: REV. [pmid: 20227787].
Sona CS, Zack JE, Schallom ME, et al. The impact of a simple, low-cost oral care protocol on ventilator-associated pneumonia rates in a surgical intensive care unit. Journal of Intensive Care Medicine (Sage Publications Inc.). 2009;24(1):54-62. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION.
Souweine B, Heng AE, Aumeran C, et al. Do antibiotics administered at the time of central venous catheter removal interfere with the evaluation of colonization?. Intensive Care Medicine. 2008;34(2):286-291. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17882399].
Spencer M, Gulczynski D. Cut down on SSIs. Nurs Manage. 2010;41(10):26-31. quiz 32. Exclusion Codes: GUIDELINE. [pmid: 20847707].
Springer R. The Surgical Care Improvement Project -- focusing on infection control. Plastic Surgical Nursing. 2007;27(3):163-167. Exclusion Codes: GUIDELINE. [pmid: 17901827].
Spronk PE, Schultz MJ. Slurping at the inside--do not forget to clean the outside too. Crit Care Med. 2007;35(7):1803. author reply 1803-4. Exclusion Codes: LETTER. [pmid: 17581384].
Staudinger T, Bojic A, Holzinger U, et al. Continuous lateral rotation therapy to prevent ventilator-associated pneumonia. Crit Care Med. 2010;38(2):486-90. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19789440].
Steinmann J, Knaust A, Moussa A, et al. Implementation of a novel on-ward computer-assisted surveillance system for device-associated infections in an intensive care unit. Int J Hyg Environ Health. 2008;211(1-2):192-9. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17581784].
Stensballe J, Tvede M, Looms D, et al. Infection risk with nitrofurazone-impregnated urinary catheters in trauma patients: a randomized trial. Annals of Internal Medicine. 2007;147(5):285-293. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17785483].
Stone PW, Pogorzelska M, Graham D, et al. California hospitals response to state and federal policies related to health care-associated infections. Policy Polit Nurs Pract. 2011;12(2):73-81. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 22042613].
Stoodley L, Lillington L, Ansryan L, et al. Sternal wound care to prevent infections in adult cardiac surgery patients. Crit Care Nurs Q. 2012;35(1):76-84. Exclusion Codes: NO STATISTICAL ANALYSIS. [pmid: 22157494].
Stulberg JJ, Delaney CP, Neuhauser DV, et al. Adherence to surgical care improvement project measures and the association with postoperative infections. JAMA. 2010;303(24):2479-85. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20571014].
Suetens C, Morales I, Savey A, et al. European surveillance of ICU-acquired infections (HELICS-ICU): Methods and main results. J Hosp Infect. Suppl 2. 2007;65:171-3. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 17540265].
Suffoletta TJ, Jennings HR, Oh JJ, et al. Continuous versus intermittent infusion of prophylactic cefoxitin after colorectal surgery: a pilot study. Pharmacotherapy. 2008;28(9):1133-9. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18752384].
Suzan MH. Pediatric central line: bundle implementation and outcomes. J Infus Nurs. 2011;34(1):36-48. Exclusion Codes: REVIEW ARTICLE. [pmid: 21239950].
Swadener-Culpepper L. Continuous lateral rotation therapy. Crit Care Nurse. 2010;30(2):S5-7. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20360444].
Swenson BR, Hedrick TL, Metzger R, et al. Effects of preoperative skin preparation on postoperative wound infection rates: a prospective study of 3 skin preparation protocols. Infection Control & Hospital Epidemiology. 2009;30(10):964-971. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19732018].
Szakmany T, Pain T, Beckett P, et al. Eliminating catheter related bloodstream infection on the intensive care unit: Not a Myth!. Intensive Care Medicine. 2011;37:S16. Exclusion Codes: ABSTRACT ONLY.
Takahashi H, Wada A, Iida Y, et al. Antimicrobial prophylaxis for spinal surgery. J Orthop Sci. 2009;14(1):40-4. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19214686].
Talwar S, Choudhary SK, Airan B. Peri-operative antibiotic prophylaxis in paediatric cardiac surgery [2]. Cardiology in the Young. 2007;17(6):695. Exclusion Codes: LETTER. [pmid: 18265448].
Tan JA, Naik VN, Lingard L. Exploring obstacles to proper timing of prophylactic antibiotics for surgical site infections. Quality and Safety in Health Care. 2006;15(1):32-38. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 16456207].
Tantipong H, Morkchareonpong C, Jaiyindee S, et al. Randomized controlled trial and Meta-analysis of oral decontamination with 2% chlorhexidine solution for the prevention of ventilator-associated pneumonia. Infect Control Hosp Epidemiol. 2008;29(2):131-6. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 18179368].
Tao L, Hu B, Rosenthal VD, et al. Device-associated infection rates in 398 intensive care units in Shanghai, China: International Nosocomial Infection Control Consortium (INICC) findings. International Journal of Infectious Diseases. 2011;15(11):e774-e780. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21846591].
Tarricone R, Torbica A, Franzetti F, et al. Hospital costs of central line-associated bloodstream infections and cost-effectiveness of closed vs. open infusion containers. The case of Intensive Care Units in Italy. Cost Effectiveness & Resource Allocation. 2010;8:10. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 20462457].
Tartari E, Mamo J. Pre-educational intervention survey of healthcare practitioners' compliance with infection prevention measures in cardiothoracic surgery: low compliance but internationally comparable surgical site infection rate. J Hosp Infect. 2011;77(4):348-51. Exclusion Codes: NOT RELEVANT OUTCOME/DESIGN. [pmid: 21334097].
Tassan din C, Oltolini C, Scarpellini P, et al. Perioperative antibiotic prophylaxis: results of a second audit in 7 major hospitals in North Italy. Clinical Microbiology and Infection. 2011;17:S367. Exclusion Codes: ABSTRACT ONLY.
Tate A, Yazdany T, Bhatia N. The use of infection prevention practices in female pelvic medicine and reconstructive surgery. Curr Opin Obstet Gynecol. 2010;22(5):408-13. Exclusion Codes: REVIEW ARTICLE. [pmid: 20733484].
Taylor BA. Doing it better; putting research into practice. Cutting surgical-site infection rates for pacemakers and ICDs. Nursing. 2006;36(3):18-19. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 16523069].
Tenke P, Kovacs B, Bjerklund Johansen TE, et al. European and Asian guidelines on management and prevention of catheter-associated urinary tract infections. International Journal of Antimicrobial Agents. 2008;31(SUPPL. 1):68-78. Exclusion Codes: REVIEW ARTICLE.
Terry M, Halstead LS, O'Hare P, et al. Feasibility study of home care wound management using telemedicine. Adv Skin Wound Care. 2009;22(8):358-64. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19638799].
Thomas S, Cantrill S, Waghorn DJ, et al. The role of screening and antibiotic prophylaxis in the prevention of percutaneous gastrostomy site infection caused by Methicillin-resistant Staphylococcus aureus. Alimentary Pharmacology and Therapeutics. 2007;25(5):593-597. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17305760].
Thomas JG, Orr B. The cost of hospital associated infections. Advance for Administrators of the Laboratory. 2011;20(4):24. Exclusion Codes: NOT RELEVANT OUTCOME.
Thompson CA. Nation continues to try to prevent surgical complications, deaths. American Journal of Health-System Pharmacy. 2011;68(19):1766-1767. Exclusion Codes: LETTER TO EDITOR. [pmid: 21930628].
Thompson KM, Oldenburg WA, Deschamps C, et al. Chasing zero: the drive to eliminate surgical site infections. Ann Surg. 2011;254(3):430-6. discussion 436-7. Exclusion Codes: NOT RELEVANT DESIGN. [pmid: 21817888].
Thomsen T, Tonnesen H, Moller AM. Effect of preoperative smoking cessation interventions on postoperative complications and smoking cessation. Br J Surg. 2009;96(5):451-61. Exclusion Codes: META-ANALYSIS. [pmid: 19358172].
Tidswell EC, Rockwell J, Wright MO. Reducing hospital-acquired infection by quantitative risk modeling of intravenous bag preparation. PDA J Pharm Sci Technol. 2010;64(2):82-91. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21502008].
Tissot F, Calandra T, Prod'hom G, et al. Impact of infectious diseases consultation on OUTCOMEe of methicillin-resistant Staphylococcus aureus bacteraemia in a tertiary care centre: A ten-year experience. Clinical Microbiology and Infection. 2011;17:S420-S421. Exclusion Codes: ABSTRACT ONLY.
Tita NAT, Rouse DJ, Blackwell S, et al. Emerging concepts in antibiotic prophylaxis for cesarean delivery: A systematic review. Obstetrics and Gynecology. 2009;113(3):675-682. Exclusion Codes: META-ANALYSIS. [pmid: 19300334].
Tolentino-DelosReyes AF, Ruppert SD, Shiao SY. Evidence-based practice: use of the ventilator bundle to prevent ventilator-associated pneumonia. Am J Crit Care. 2007;16(1):20-7. Exclusion Codes: INSUFFICIENT SAMPLE SIZE. [pmid: 17192523].
Toltzis P. Antibiotic lock technique to reduce central venous catheter-related bacteremia. Pediatr Infect Dis J. 2006;25(5):449-50. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16645511].
Tornero-Campello G. Perioperative epidural analgesia and prevention of ventilator-associated pneumonia. Chest. 2009;136(1):322. author reply 322-3. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19584222].
Trautner BW, Kelly PA, Petersen N, et al. A hospital-site controlled intervention using audit and feedback to implement guidelines concerning inappropriate treatment of catheter-associated asymptomatic bacteriuria. Implement Sci. 2011;6:41. Exclusion Codes: NOT RELEVANT DESIGN. [pmid: 21513539].
Trerotola SO, Patel AA, Shlansky-Goldberg RD, et al. Short-term Infection in Cuffed versus Noncuffed Small Bore Central Catheters: A Randomized Trial. Journal of Vascular and Interventional Radiology. 2010;21(2):203-211. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20036147].
Tribble DR, Lloyd B, Weintrob A, et al. Antimicrobial prescribing practices following publication of guidelines for the prevention of infections associated with combat-related injuries. J Trauma. 2011;71(2 Suppl 2):S299-306. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 21814096].
Trinh JV, Chen LF, Sexton DJ, et al. Risk factors for gram-negative bacterial surgical site infection: do allergies to antibiotics increase risk?. Infection Control & Hospital Epidemiology. 2009;30(5):440-446. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 19317629].
Troidle L, Finkelstein FO. Catheter-related bacteremia in hemodialysis patients: the role of the central venous catheter in prevention and therapy. International Journal of Artificial Organs. 2008;31(9):827-833. Exclusion Codes: REVIEW ARTICLE. [pmid: 18924095].
Tsai HH, Lin FC, Chang SC. Intermittent suction of oral secretions before each positional change may reduce ventilator-associated pneumonia: a pilot study. Am J Med Sci. 2008;336(5):397-401. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19011396].
Uckay I, Harbarth S, Peter R, et al. Preventing surgical site infections. Expert Review of Anti-infective Therapy. 2010;8(6):657-670. Exclusion Codes: REVIEW ARTICLE. [pmid: 20521894].
Ulleryd P, Karlsson L, Arvidsson A, et al. Improved COMMENTARYpliance to antibiotic GUIDELINESdelines in long-term care facilities in Region Vastra Gotaland, Sweden. Clinical Microbiology and Infection. 2011;17:S343-S344. Exclusion Codes: ABSTRACT ONLY.
Unahalekhaka A, Jamulitrat S, Chongsuvivatwong V, et al. Using a collaborative to reduce ventilator-associated pneumonia in Thailand. Jt Comm J Qual Patient Saf. 2007;33(7):387-94. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 17711140].
Valencia M, Ferrer M, Farre R, et al. Automatic control of tracheal tube cuff pressure in ventilated patients in semirecumbent position: a randomized trial. Crit Care Med. 2007;35(6):1543-9. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17452937].
Valles J, Fernandez I, Alcaraz D, et al. Prospective randomized trial of 3 antiseptic solutions for prevention of catheter colonization in an intensive care unit for adult patients. Infection Control & Hospital Epidemiology. 2008;29(9):847-853. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18665819].
van den Heijkant M, Haider N, Taylor C, et al. Efficacy of bladder irrigation and surveillance program in pSYSTEMATIC REVIEWention of urinary tract infections and bladder calculi in children with an ileocystoplasty and bladder neck repair. Pediatr Surg Int. 2011;27(7):781-5. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21553274].
Van Den Hoogen A, Krediet TG, Uiterwaal CSPM, et al. In-line filters in central venous catheters in a neonatal intensive care unit. Journal of Perinatal Medicine. 2006;34(1):71-74. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16489888].
van Kasteren ME, Mannien J, Ott A, et al. Antibiotic prophylaxis and the risk of surgical site infections following total hip arthroplasty: timely administration is the most important factor. Clin Infect Dis. 2007;44(7):921-7. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 17342642].
van Tiel FH, Elenbaas TWO, Voskuilen BMA, et al. Plan-do-study-act cycles as an instrument for improvement of compliance with infection control measures in care of patients after cardiothoracic surgery. Journal of Hospital Infection. 2006;62(1):64-70. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 16309783].
Vandijck DM, Racco M, Horn K. Central catheter-related infections. Crit Care Nurse. 2007;27(4):14. author reply 14. Exclusion Codes: LETTER. [pmid: 17671241].
Vandijck DM, Blot SI, Labeau SO. Reduction of catheter related bloodstream infections in intensive care: one for all, all for one?. Nurs Crit Care. 2009;14(5):273. Exclusion Codes: COMMENTARY. [pmid: 19706078].
Vandijck DM, Labeau SO, Vogelaers DP, Blot SI. Prevention of nosocomial infections in intensive care patients. Nursing in Critical Care. 2010;15(5):251-256. Exclusion Codes: REVIEW ARTICLE. [pmid: 20712670].
Vandijck DM, Labeau SO, Blot SI. Prevention of needlestick injuries among health care workers. American Journal of Infection Control. 2011;39(4):347-348. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21531279].
Vaughan-Shaw PG, Durdey P, Sylvester PA, et al. Timing it right: Prophylactic antibiotics for colorectal resections. Colorectal Disease. 2011;13:23. Exclusion Codes: ABSTRACT ONLY.
Vaz G, Goncnullalves RV. Preventing ventilator-associated pneumonia: A new methodology for bed head control 24 null 7. Critical Care. 2011;15:14. Exclusion Codes: ABSTRACT ONLY.
Verdier R, Parer S, Jean-Pierre H, et al. Impact of an infection control program in an intensive care unit in France. Infection Control & Hospital Epidemiology. 2006;27(1):60-66. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 16418989].
Vigorito MC, McNicoll L, Adams L, et al. Improving safety culture results in Rhode Island ICUs: lessons learned from the development of action-oriented plans. Jt Comm J Qual Patient Saf. 2011;37(11):509-14. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 22132663].
Vilar-Compte D, Roldan-Marin R, Robles-Vidal C, et al. Surgical site infection (SSI) rates among patients who underwent mastectomy after the introduction of SSI prevention policies. Infect Control Hosp Epidemiol. 2006;27(8):829-34. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 16874643].
Vilar-Compte D, Rosales S, Hernandez-Mello N, et al. Surveillance, control, and prevention of surgical site infections in breast cancer surgery: a 5-year experience. Am J Infect Control. 2009;37(8):674-9. Exclusion Codes: NO BASELINE DATA. [pmid: 19556033].
Vilins M, Blecher S, da Silva MAM, et al. Rate and time to develop first central line-associated bloodstream infections when comparing open and closed infusion containers in a Brazilian hospital. Brazilian Journal of Infectious Diseases. 2009;13(5):335-340. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 20428631].
Vilins M, Blecher S, Silva MA, et al. Rate and time to develop first central line-associated bloodstream infections when comparing open and closed infusion containers in a Brazilian Hospital. Braz J Infect Dis. 2009;13(5):335-40. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20428631].
Virtanen M, Kurvinen T, Terho K, et al. Work hours, work stress, and collaboration among ward staff in relation to risk of hospital-associated infection among patients. Medical Care. 2009;47(3):310-318. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19194334].
Vogts N, Hannam JA, Merry AF, et al. Compliance and quality in administration of a Surgical Safety Checklist in a tertiary New Zealand hospital. N Z Med J. 2011;124(1342):48-58. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21963925].
Vonberg RP, Eckmanns T, Welte T, et al. Impact of the suctioning system (open vs. closed) on the incidence of ventilation-associated pneumonia: Meta-analysis of randomized controlled trials. Intensive Care Med. 2006;32(9):1329-35. Exclusion Codes: META-ANALYSIS. [pmid: 16788806].
Wagner D, Nigg A, Sturm L, et al. Implementation of weight-based antimicrobial dosing for surgical site infection prophylaxis. Hospital Pharmacy. 2011;46(7):494-500. Exclusion Codes: NOT RELEVANT QUESTION.
Wakeham MK. Use of a clinical practice guidelines checklist to reduce intravenous catheter-related infections. Nutr Clin Pract. 2011;26(3):346-8. Exclusion Codes: LETTER TO EDITOR. [pmid: 21531736].
Wald HL, Kramer AM. Nonpayment for harms resulting from medical care: catheter-associated urinary tract infections. JAMA. 2007;298(23):2782-4. Exclusion Codes: COMMENTARY. [pmid: 18165672].
Wald HL, Kramer AM. Feasibility of audit and feedback to reduce postoperative urinary catheter duration. Journal of Hospital Medicine. 2011;6(4):115-121. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 21387546].
Walz JM, Memtsoudis SG, Heard SO. Analytic reviews: prevention of central venous catheter bloodstream infections. Journal of Intensive Care Medicine (Sage Publications Inc.). 2010;25(3):131-138. Exclusion Codes: REVIEW ARTICLE.
Walz JM, Avelar RL, Longtine KJ, et al. Anti-infective external coating of central venous catheters: a randomized, noninferiority trial comparing 5-fluorouracil with chlorhexidine/silver sulfadiazine in preventing catheter colonization. Critical Care Medicine. 2010;38(11):2095-2102. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20711070].
Wanderer JP, Sandberg WS, Ehrenfeld JM. Real-time alerts and reminders using information systems. Anesthesiol Clin. 2011;29(3):389-96. Exclusion Codes: SYSTEMATIC REVIEW. [pmid: 21871401].
Ward L, Fenton K, Maher L. The high impact actions for nursing and midwifery 5: protection from infection. Nurs Times. 2010;106(31):20-1. Exclusion Codes: GUIDELINE. [pmid: 20806645].
Waters HR, Korn R Jr., Colantuoni E, et al. The business case for quality: economic analysis of the Michigan Keystone Patient Safety Program in ICUs. Am J Med Qual. 2011;26(5):333-9. Exclusion Codes: DUPLICATE PATIENT POPULATION OR PUBLICATION. [pmid: 21856956].
Watson SR, George C, Martin M, et al. Preventing central line-associated bloodstream infections and improving safety culture: a Statewide experience. Jt Comm J Qual Patient Saf. 2009;35(12):593-7. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 20043498].
Watters Iii WC, Baisden J, Bono CM, et al. Antibiotic prophylaxis in spine surgery: an evidence-based clinical guideline for the use of prophylactic antibiotics in spine surgery. Spine Journal. 2009;9(2):142-146. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18619911].
Webb BAL, Flagg RL, Fink AS. Reducing surgical site infections through a multidisciplinary computerized process for preoperative prophylactic antibiotic administration. American Journal of Surgery. 2006;192(5 SPEC. ISS.):663-668. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 17071203].
Weber DJ, Brown VM, Sickbert-Bennett EE, et al. Sustained and prolonged reduction in central line-associated bloodstream infections as a result of multiple interventions. Infection Control & Hospital Epidemiology. 2010;31(8):875-877. Exclusion Codes: COMMENTARY. [pmid: 20590455].
Weeks KR, Goeschel CA, Cosgrove SE, et al. Prevention of central line-associated bloodstream infections: A journey toward eliminating preventable harm. Current Infectious Disease Reports. 2011;13(4):343-349. Exclusion Codes: COMMENTARY. [pmid: 21556693].
Weinberg MA, Segelnick SL. 2009;34:HS2-HS10. Exclusion Codes: NOT RELEVANT QUESTION.
Weireter LJ Jr., Collins JN, Britt RC, et al. Impact of a monitored program of care on incidence of ventilator-associated pneumonia: results of a longterm performance-improvement project. J Am Coll Surg. 2009;208(5):700-4. discussion 704-5. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 19476819].
Wenger JE. Cultivating quality: reducing rates of catheter-associated urinary tract infection. Am J Nurs. 2010;110(8):40-5. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 20671495].
Westwell S. Implementing a ventilator care bundle in an adult intensive care unit. Nurs Crit Care. 2008;13(4):203-7. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18577172].
Wheeler DS, Giaccone MJ, Hutchinson N, et al. A hospital-wide quality-improvement collaborative to reduce catheter-associated bloodstream infections. Pediatrics. 2011;128(4):e995-e1004. quiz e1004-7. Exclusion Codes: NO STATISTICAL ANALYSIS. [pmid: 21930547].
White A, Schneider T. Improving compliance with prophylactic antibiotic administration guidelines. AORN Journal. 2007;85(1):173-180. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 17223406].
Wick EC, Gibbs L, Indorf LA, et al. Implementation of quality measures to reduce surgical site infection in colorectal patients. Dis Colon Rectum. 2008;51(7):1004-9. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18415649].
Wilke MH, Grube RF, Bodmann KF. Guideline-adherent initial intravenous antibiotic therapy for hospital-acquired/ventilator-associated pneumonia is clinically superior, saves lives and is cheaper than non guideline adherent therapy. European Journal of Medical Research. 2011;16(7):315-323. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 21813372].
Williams Z, Chan R, Kelly E. A simple device to increase rates of compliance in maintaining 30-degree head-of-bed elevation in ventilated patients. Crit Care Med. 2008;36(4):1155-7. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 18379241].
Willson M, Wilde M, Webb M, et al. Nursing interventions to reduce the risk of catheter-associated urinary tract infection: part 2: staff education, monitoring, and care techniques. Journal of Wound, Ostomy & Continence Nursing. 2009;36(2):137-154. Exclusion Codes: REVIEW ARTICLE.
Willson M, Wilde M, Webb ML, et al. Nursing interventions to reduce the risk of catheter-associated urinary tract infection: part 2: staff education, monitoring, and care techniques. J Wound Ostomy Continence Nurs. 2009;36(2):137-54. Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION. [pmid: 19287262].
Wilson AP, Hodgson B, Liu M, et al. Reduction in wound infection rates by wound surveillance with postdischarge follow-up and feedback. Br J Surg. 2006;93(5):630-8. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 16550635].
Wirtschafter DD, Pettit J, Kurtin P, et al. A Statewide quality improvement collaborative to reduce neonatal central line-associated blood stream infections. Journal of Perinatology. 2010;30(3):170-181. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 19940855].
Wirtschafter DD, Powers RJ, Pettit JS, et al. Nosocomial infection reduction in VLBW infants with a Statewide quality-improvement model. Pediatrics. 2011;127(3):419-426. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 21339273].
Wise MP, Cole JM, Williams DW, et al. Efficacy of oral chlorhexidine in critical care. Crit Care. 2008;12(3):419. auhtor reply 419. Exclusion Codes: LETTER. [pmid: 18492223].
Woeltje KF, McMullen KM, Butler AM, et al. Electronic surveillance for healthcare-associated central line-associated bloodstream infections outside the intensive care unit. Infection Control and Hospital Epidemiology. 2011;32(11):1086-1090. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 22011535].
Wojkowska-Mach J, Bulanda M, Kochan P, et al. Surgical site infections surveillance and quality management in Polish hospitals. Chirurgia Polska. 2006;8(2):136-145. Exclusion Codes: NOT RELEVANT INTERVENTION.
Woodward CS, Son M, Calhoon J, et al. Sternal wound infections in pediatric congenital cardiac surgery: A survey of incidence and preventative practice. Annals of Thoracic Surgery. 2011;91(3):799-804. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 21353002].
Woolley I, Jones P, Spelman D, et al. Cost-effectiveness of a post-splenectomy registry for prevention of sepsis in the asplenic. Australian and New Zealand Journal of Public Health. 2006;30(6):558-561. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17209273].
Wren SM, Martin M, Yoon JK, et al. Postoperative pneumonia-prevention program for the inpatient surgical ward. J Am Coll Surg. 2010;210(4):491-5. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 20347742].
Wright MO, Hebden JN, Allen-Bridson K, et al. Health Care-Associated Infections Studies Project: An American Journal of Infection Control and National Healthcare Safety Network Data Quality Collaboration Case Study 6. American Journal of Infection Control. 2011;39(6):515-516. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 21704430].
Wu AW, Sexton JB, Pronovost PJ. Partnership with patients: a prescription for ICU safety. Chest. 2006;130(5):1291-3. Exclusion Codes: COMMENTARY. [pmid: 17099000].
Wu SC, Crews RT, Zelen C, et al. Use of chlorhexidine-impregnated patch at pin site to reduce local morbidity: the ChIPPS Pilot Trial. Int Wound J. 2008;5(3):416-22. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 18205786].
Wunderink RG, Brun-Buisson C. Ventilator-associated pneumonia: Lessons learned from clinical trials. J Crit Care. 2008;23(1):2-4. Exclusion Codes: EDITORIAL. [pmid: 18359414].
Xiao Y, Seagull FJ, Bochicchio GV, et al. Video-based training increases sterile-technique compliance during central venous catheter insertion. Critical Care Medicine. 2007;35(5):1302-1306. Exclusion Codes: INSUFFICIENT SAMPLE SIZE. [pmid: 17414726].
Yahav D, Rozen-Zvi B, Gafter-Gvili A, et al. Antimicrobial lock solutions for the prevention of infections associated with intravascular catheters in patients undergoing hemodialysis: systematic review and Meta-analysis of randomized, controlled trials. Clin Infect Dis. 2008;47(1):83-93. Exclusion Codes: META-ANALYSIS. [pmid: 18498236].
Yap EL, Levine A, Strang T, et al. Should additional antibiotics or an iodine washout be given to all patients who suffer an emergency re-sternotomy on the cardiothoracic intensive care unit?. Interact Cardiovasc Thorac Surg. 2008;7(3):464-9. Exclusion Codes: REVIEW ARTICLE. [pmid: 18258650].
Yngström D, Linström K, Nyström K, et al. Healthcare-associated infections must stop: a breakthrough project aimed at reducing healthcare-associated infections in an intensive-care unit. BMJ Quality & Safety. 2011;20(7):631-636. Exclusion Codes: NO STATISTICAL ANALYSIS. [pmid: 21642444].
Yoko Furuya E, Dick A, Perencevich EN, et al. Central line bundle implementation in US intensive care units and impact on bloodstream infections. PLoS One. 2011;6(1). Exclusion Codes: DUPLICATE STUDY/PATIENT POPULATION.
You SJH, Ip DNC, Wong CTN, et al. Meticillin-resistant Staphylococcus aureus bacteraemia in Hong Kong. Journal of Hospital Infection. 2008;70(4):379-381. Exclusion Codes: NOT RELEVANT INFECTION. [pmid: 18952321].
Young BC, Hacker MR, Dodge LE, et al. Timing of antibiotic administration and infectious morbidity following cesarean delivery: incorporating policy change into workflow. Archives of Gynecology and Obstetrics. 2011:1-6. Exclusion Codes: NOT RELEVANT QUESTION.
Young EM, Commiskey ML, Wilson SJ. Translating evidence into practice to prevent central venous catheter-associated bloodstream infections: A systems-based intervention. American Journal of Infection Control. 2006;34(8):503-506. Exclusion Codes: reason. [pmid: 17015155].
Young LS, Winston LG. Preoperative use of mupirocin for the prevention of healthcare-associated Staphylococcus aureus infections: a cost-effectiveness analysis. Infect Control Hosp Epidemiol. 2006;27(12):1304-12. Exclusion Codes: NOT RELEVANT QUESTION. [pmid: 17152027].
Young P, Wyncoll D. PEEP is protective against pulmonary microaspiration. Crit Care Med. 2009;37(1):380. author reply 381-2. Exclusion Codes: LETTER. [pmid: 19112322].
Young PJ, Wyncoll DL. Continuous cuff pressure control and the prevention of ventilator-associated pneumonia. Crit Care Med. 2007;35(10):2470-1. author reply 2471. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 17885409].
Youngquist P, Carroll M, Farber M, et al. Implementing a ventilator bundle in a community hospital. Jt Comm J Qual Patient Saf. 2007;33(4):219-25. Exclusion Codes: NOT RELEVANT STATISTICAL ANALYSIS. [pmid: 17441560].
Yousefshahi F, Khajavi MR, Anbarafshan M, et al. Sanosil, a more effective agent for preventing the hospital-acquired ventilator associated pneumonia. Int J Health Care Qual Assur. 2010;23(6):583-90. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 20845824].
Zabramski JM, Spetzler RF, Sonntag VKH. Impact of a standardized protocol and antibiotic-impregnated catheters on ventriculostomy infection rates in cerebrovascular patients. Neurosurgery. 2011;69(1):E260. Exclusion Codes: LETTER TO EDITOR. [pmid: 21430594].
Zacharias S, Dwarakanath S, Agarwal M, et al. A comparative study to assess the effect of amikacin sulfate bladder wash on catheter-associated urinary tract infection in neurosurgical patients. Indian J Crit Care Med. 2009;13(1):17-20. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 19881174].
Zack J. Zeroing in on zero tolerance for central line-associated bacteremia. American Journal of Infection Control. 2008;36(10):S176.e1-2. Exclusion Codes: REVIEW ARTICLE. [pmid: 19084157].
Zanotto AR, Heineck I, Ferreira MB. Antibiotic prophylaxis in cholecystectomies in a teaching hospital in Brazil. Ann Pharmacother. 2006;40(11):2003-7. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 17047141].
Zhang Y, Harvey K. Rational antibiotic use in China: Lessons learnt through introducing surgeons to Australian guidelines. Australia and New Zealand Health Policy. 2006;3(1). Exclusion Codes: NOT RELEVANT OUTCOME.
Zhou ZJ, Zheng YL, Hu YH. Effect and cost of perioperative use of antibiotics in coronary artery bypass grafting: A randomized controlled study. Chinese Medical Journal. 2011;124(5):699-703. Exclusion Codes: NOT RELEVANT INTERVENTION. [pmid: 21518561].
Zilberberg MD, Shorr AF. Economic Aspects of Preventing Health Care-Associated Infections in the Intensive Care Unit. Critical Care Clinics. 2012;28(1):89-97. Exclusion Codes: NOT RELEVANT OUTCOME. [pmid: 22123101].
Zywiel MG, Daley JA, Delanois RE, et al. Advance pre-operative chlorhexidine reduces the incidence of surgical site infections in knee arthroplasty. International Orthopaedics. 2011;35(7):1001-1006. Exclusion Codes: NOT RELEVANT INTERVENTION STRATEGY. [pmid: 20563806].