# Search Strategy

(Source: Ranji et al. 2007)

#1 targets QI strategies that tend to be multi-factorial using relevant MeSH terms and title words
  Patient-Centered Care [mh] or Progressive Patient Care [mh] or Critical Pathways [mh] or Delivery of Health Care, Integrated [mh] or Patient Care Team [mh] or Behavior Control [mh] or ((coordination [tw] or coordinated [tw] or Multifactorial [tw] or Multi-factorial [tw] or Multicomponent [tw] or Multi-component [tw] or multidisciplinary [tw] or multi-disciplinary [tw] or interdisciplinary [tw] or interdisciplinary [tw] or integrated [tw] or community-based [tw] or organized [tw] or comprehensive [tw]) and program*[tw] or care [tw] or approach [tw] or intervention [tw] or strategy[tw] or strategies [tw] or management [tw] or managing [tw] or center*[tw])) or Organization and Administration [mh] or bundle*[tw]
#2 targets TQM and CQI
  Total Quality Management [mh] OR Quality control [mh] OR TQM [tw] OR CQI [tw] OR (quality [tw] AND (continuous [tw] OR total [tw]) AND (management [tw] OR mprovement [tw]))
#3 targets provider education
  Education, Continuing [mh] OR Education, Nursing [mh] OR Education, Medical [mh] OR Inservice Training [mh] OR Programmed Instruction [mh] OR ((Education [tw]AND Continuing [tw]) AND (medical [tw] OR professional* [tw] OR nursing [tw] OR physician* [tw] OR nurse* [tw])) OR (outreach [tw] AND (visit* [tw] OR educational [tw]) OR (academic [tw] AND detailing [tw]))
#4 targets diffusion of innovation
  Diffusion of Innovation [mh] OR (Diffusion [ti] AND (Innovation [ti] OR technology [ti]))
#5 targets audit & feedback, reminder systems, and financial incentives
  Medical audit [mh] OR ((Audit [tw] OR feedback [tw] OR compliance [tw] OR adherence [tw] OR training [tw]) AND (improvement* [tw] OR improving [tw] OR improves [tw] OR improve [tw] OR guideline* [tw] OR practice* [tw] OR medical [tw] OR provider* [tw] OR physician* [tw] OR nurse* [tw] OR clinician* [tw] OR academic [tw] OR visit* [tw])) OR Reminder Systems [mh] OR Reminder* [tw] OR ((financial [tw] OR economic [tw] OR physician* [tw] OR patient*) AND incentive* [tw]) OR Reimbursement Mechanisms [mh] or Guideline Adherence [mh] OR practice guidelines [mh]
#6 Medical Informatics [mh] OR computer [tw] OR (decision [tw] AND (support [tw] or analysis [tw))
#7 All QI studies
  #1 or #2 or #3 Or #4 or #5 or #6
#8 Surgical site infection terms
  Surgical wound infection[mh] OR surgical site infection*[tiab] OR postoperative infection*[ti] OR postsurgical infection*[ti] OR wound infection*[ti] OR sternal wound infection*[tiab] OR postoperative[ti] OR postsurgical[ti]
#9 Combination of QI terms with SSI terms
  #7 AND #8
#10 RCT search
  Randomised [ti] OR Randomized [ti] OR Controlled [ti] OR intervention [ti] OR evaluation [ti] OR impact [ti] OR effectiveness [ti] OR Evaluation [ti] OR Studies [ti] OR study [ti] Comparative [ti] OR Feasibility [ti] OR Program [ti] OR Design [ti] OR Clinical Trial [pt] OR Randomized Controlled Trial [pt] OR Epidemiologic Studies [mh] OR Evaluation Studies [mh] OR Comparative Study [mh] OR Feasibility Studies [mh] OR Intervention Studies [mh] OR Program Evaluation [mh] OR Epidemiologic Research Design [mh]
#11 Meta-analysis, systematic review search
  ((meta-analysis [pt] OR meta-analysis [tw] OR metanalysis [tw]) OR ((review [pt] OR guideline [pt] OR consensus [ti] OR guideline* [ti] OR literature [ti] OR overview [ti] OR review [ti] OR Decision Support Techniques [mh]) AND ((Cochrane [tw] OR Medline [tw] OR CINAHL [tw] OR (National [tw] AND Library [tw])) OR (handsearch* [tw] OR search* [tw] OR searching [tw]) AND (hand [tw] OR manual [tw] OR electronic [tw] OR bibliographi* [tw] OR database* OR (Cochrane [tw] OR Medline [tw] OR CINAHL [tw] OR (National [tw] AND Library [tw]))))) OR ((synthesis [ti] OR overview [ti] OR review [ti] OR survey [ti]) AND (systematic [ti] OR critical [ti] OR methodologic [ti] OR quantitative [ti] OR qualitative [ti] OR literature [ti] OR evidence [ti] OR evidence-based [ti]))) BUTNOT (editorial [pt] OR comment [pt] OR letter [pt])
#12 All original research
  #10 OR #11
#13 Combination of QI terms with SSI terms, limited to original research only
  #9 AND #12
#14 #SSI/QI search limited to English only
  #13 AND Limits: English
#15 CLABSI search (restrict to English only)
  (Catheterization, Central Venous [MeSH] OR central line*[ti] OR central venous catheter*[ti]) AND (Cross infection [mh] OR bacteremia [mh] OR nosocomial [tiab] OR “healthcare associated”[tiab] OR “hospital acquired”[tiab] OR bundle[tiab])
#16 VAP search (restrict to English only)
  (Respiration, Artificial[mh] OR mechanically ventilated*[ti] OR intubated*[ti] OR mechanical ventilation*[ti] or ventilator associated*[ti]) AND (Cross infection [mh] OR bacteremia [mh] OR nosocomial [tiab] OR “healthcare associated”[tiab] OR “hospital acquired”[tiab] OR bundle[tiab])
#17 UCUTI search (restrict to English only)
  (Urinary catheterization[mh] OR urinary catheter*[tiab]) AND (Cross infection [mh] OR bacteremia [mh] OR nosocomial [tiab] OR “hospital-acquired”[tiab] OR healthcareassociated”[tiab] OR bundle[tiab])

Supplemental Searches
#S1 Nosocomial infection systematic reviews (limited to English only)
  Cross infection[mh] AND systematic[sb]
#S2 Handwashing systematic reviews (limited to English only)
  Handwashing[mh] AND systematic[sb]
#S3 Author searches
  Pronovost p[au] OR Gastmeier P[au] OR Gyssens IC[au]