# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Suzanne E. Belinson, Ph.D., M.P.H.; Claudia Bonnell, R.N., M.L.S.; Lisa Garofalo, B.A.; David Samson, M.S.; Lisa Sarsany, M.A.; Stephen Weber, M.D.; Kathleen Ziegler, Pharm.D.; Yoojung Yang, Pharm.D., M.S.; Jennifer Brock, M.P.H.; Sarah Godfrey, M.P.H;. Jenna Khan, M.P.H.; Jessica Hoag, M.P.H.; Umakanth Avula, M.S.