# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
ANOVA: analysis of variance
APACHE II: Acute Physiological and Chronic Health Evaluation II
APIC: Association for Professionals in Infection Control and Epidemiology, Inc.
ARIMA: autoregressive integrated moving average
BSI: bloodstream infection
CAUTI: catheter-associated urinary tract infection
CCU: cardiac care unit
CDC: Centers for Disease Control and Prevention
CI: confidence interval
CLABSI: central line-associated bloodstream infection
CPI: Consumer Price Index
CUSP: Comprehensive Unit based Safety Program
CVC: central venous catheter
CVL: central venous line
DHQP: Division of Healthcare Quality Promotion
DVT: deep vein thrombosis
EPOC: Cochrane's Effective Practice and Organisation of Care Group
FASTHUG: Feeding, Analgesia, Sedation, Thromboembolic prevention, Head of bed elevation, Ulcer prophylaxis, and Glucose control
GRADE: Grading of Recommendations Assessment, Development, and Evaluation
HAI: healthcare-associated infection
HICPAC: Healthcare Infection Control Practices Advisory Committee
HOB: head of bed
HR: hazard ratio
ICU: intensive care unit
IDSA: Infectious Diseases Society of America
IOM: Institute of Medicine
IRR: incidence rate ratio
ISS: Injury Severity Score
KQ: Key Question
MICU: medical intensive care unit
mos: months
NACHRI: National Association of Children's Hospitals and Related Institutions
NHSN: National Healthcare Safety Network
NICU: neonatal intensive care unit
NNIS: National Nosocomial Infections Surveillance
NS: nonsignificant
OR: odds ratio
PDMV: positive displacement mechanical valve
PICU: pediatric intensive care unit
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
PSP: patient safety practice
QI: quality improvement
RAND: Research and Development
RCT: randomized controlled trial
RR: relative risk
RTI: Research Triangle Institute
SAPS II: Simplified Acute Physiological Score II
SD: standard deviation
SHEA: Society for Healthcare Epidemiologists of America
SICU: surgical intensive care unit
SIR: standardized infection ratios
SOE: strength of evidence
SPC: statistical process control
SSI: surgical site infection
TEP: Technical Expert Panel
UC: urinary catheter
VAP: ventilator-associated pneumonia