# Results

## Organization

The results of this review are presented in this section. First the literature search results are summarized in the study flow diagram (Figure 2). This diagram shows how many citations were located and their disposition at each stage of the review.

Figure 2 Study flow diagram

^a^ Four quantitative studies report results about individual clinicians and hospitals and therefore appear in both categories here.

^b^ Three articles included in this count reported the results of one qualitative study; two articles reported results of one other study.

Figure 2. This figure is a flow chart that summarizes the search and selection of articles. There were 11,809 abstracts of ptoentially relevant articles identified by searching MEDLINE, EMBASE, EconLit, PsychINFO, Business Source Premier, CINAHL, PAIS, Cochrane Database of Systematic Reviews, DARE, NHS EED, HEED, Grey Literature Report database and other sources (experts, reference lists, and grey literature). Of these, 10,177 abstracts were excluded. Full-text articles were reviewed for relevance for the remaining 1,632 abstracts. Of these, 1,434 were excluded for the following reasons: not public reporting, no outcome data or study design, methodological studies, public reporting as outcome, not intervention, unable to obtain, wrong provider type, foreign language, and other. Of the remaining, 316 articles were identified as relevant for background, and 198 articles were included in the review. Of the included articles, 97 were quantitative and 101 were qualitative. The included articles were sorted into four categories. The first category was hospitals, with 43 quantitative articles and 43 qualitative articles. The second category was long term care, with 22 quantitative articles and 6 qualitative articles. The third category was health plans, with 24 quantitative articles and 35 qualitative articles. The fourth and last category was individual clinicians, with 12 quantitative articles and 20 qualitative articles.

Following this figure the results of this review are presented in two ways. First they are summarized by Key Question across all the health care settings and then separately by health care setting. The Summary of Results by Key Questions section repeats the results reported in more detail in the section titled Effectiveness of Public Reporting by Health Care Setting. The Results by Health Care Setting section is divided into studies of public reporting about hospitals, individual clinicians, health plans, and long-term care services.

The section on each health care setting contains the following:

- Introduction
- Overview of the Findings. This is a summary of the major finding from the analyses of the quantitative studies;
- Description of the Quantitative Studies. Here the populations, interventions, comparators and outcomes included in the identified studies are described.
- Detailed Analysis of Quantitative Studies. The results of quantitative studies are then discussed in detail. This text is based on the Summary of Evidence provided at the end of the section as well as the full Evidence Table provided in the Appendixes.
- Description and Summary of Qualitative Studies. The included qualitative studies are described briefly and their results are presented in a narrative and bulleted list organized by type of study and presented in chronological order. All abstracted information from qualitative studies is included in the Evidence Tables in the appendixes.

## Search Results

A summary of the search results is presented in Figure 2. Database searches returned 13,318 articles. In addition, 129 articles were selected for review based on expert recommendations and checking reference lists. After identifying duplicates, a total of 11,809 citations remained for abstract and title review. From these reviewers identified 1,632 articles that were possibly relevant. Full-text articles were retrieved, and each was reviewed by two of three reviewers in order to determine inclusion for data abstraction. Any discrepancies were resolved using a third reviewer and consensus. Ultimately, 198 articles were included for abstraction; 97 of which were quantitative articles and 101 were qualitative. Four quantitative articles reported separate outcomes for both individual clinicians and hospitals and therefore appear in counts for both categories. Two studies were reported in multiple articles and are combined in the discussion of the results. Seven of the quantitative studies and twenty-four of the qualitative studies were conducted in countries other than the United States.

## Overview of Effectiveness of Public Reporting as a Quality Improvement Strategy

The following summary of the results is organized by Key Question and seeks to identify cross cutting trends and implications. These are also included in the Discussion section and the summary table at the end of the document. However this does not reflect how the analyses were originally compiled. Research studies of public reporting concern reports and the resulting changes in behavior and outcomes for a specific health care setting. Our analyses followed the literature and presents the results by setting, but the other reason we organized the detailed reporting of the results in later sections by setting was because we believe that the inherent differences in the nature of the decisions (e.g., selecting a cardiac surgeon vs. selecting a nursing home) merit careful consideration when attempting to judge effectiveness.

Overall we found that both the amount of evidence and the results varied by Key Questions and outcome as well as by setting. Here we provide our conclusions as well as the strength of evidence assessment for that conclusion followed by general comments and the relevant key points for each setting. These key points are repeated in the results section for each setting. The key points for hospitals are also divided into those resulting from studies of cardiac care and those from non cardiac care (that is any hospital care that is not cardiac surgery or care for a cardiac condition) as this is the structure we used to organize the large number of articles about hospitals. The strength of evidence assessments are not repeated in the sections by health care setting, they are presented only here and in the summary table in the Discussion section. This is because this assessment was made only across settings.

### Summary of Results by Key Question

#### Key Question 1

Does public reporting result in improvements in the quality of health care (including improvements in health care delivery structures, processes or patient outcomes)?

##### Overall Findings

Mortality. Public Reporting was associated with a small decline in mortality after controlling for trends in reductions in mortality (19 studies, moderate strength of evidence).

Quality and process indicators (e.g. Consumer Assessment of Healthcare Providers and Systems [CAHPS], Healthcare Effectiveness Data and Information Set [HEDIS], and Nursing Home [NH] Compare). Most studies found that public reporting is associated with improvement in quality and process indicators, though this varies across specific measures (19 studies, high strength of evidence).

Mortality was often the focus in studies of hospitals and was also the primary outcome in one study of individual providers. Most of the studies find a decrease in mortality, though these results are not uniformly consistent and many questions about the appropriateness of the comparisons (both groups and risk adjustment methods) are an ongoing subject of debate. In studies of health plans and long term care, the outcomes studied most often were the quality measures for more specific outcomes such as pain, pressure ulcers, and satisfaction with care. In general these studies find that public reporting has a positive impact on the quality measures although some studies find that this varies across plans or subgroups of the patient population (e.g., short- vs. long-stay nursing home residents).

##### Key Points by Health Care Setting

Hospital cardiac

- While eight studies found that mortality tended to improve (decrease) over time with public reporting about cardiac procedures (eight studies),28–35 this finding was not consistent with four other studies finding no difference in mortality associated with public reporting (four studies).36–39
- Seven studies evaluated the effect of regional public reporting efforts on hospital quality.
  ○ One40 earlier study of the Cleveland Health Quality Choice Program showed an effect of public reporting but the other four41–44 did not.
- Two evaluations of QualityCounts10,45 in Wisconsin found significant effect on quality.
- Four46–49 studies evaluated State level public reporting efforts. They all showed slight improvement in quality in hospitals.
- Three50–52 studies were about national level public reports and they all reported slight improvement in quality in hospitals.

Individual clinicians

- Surgeon-specific mortality rates for coronary artery bypass graft (CABG) in New York State declined after rates were publicly reported (one study).28

Health plans

- Quality measures improved for almost all HEDIS and CAHPS domains studied after public reporting (5 studies).53–57
- During the time period in which HEDIS measures were publicly reported by some plans while others submitted data but did not allow it to be released, plans that voluntarily reported quality data had higher-quality scores (two studies)54,55 even after controlling for differences in plans (one study).55

Long-term care

- Some quality measures (QMs), but not all, improved after public reporting (7 studies).
  ○ Measures for short-stay residents of nursing homes showed improvement across studies (2 studies).13,58
  ○ For long-stay residents the measures that improved across multiple studies were physical restraints and pain while the rest of the measures had no improvement or mixed results (5 studies).59–63

#### Key Question 2

What harms result from public reporting?

##### Overall Findings

Mortality. In one study an increase in mortality was attributed to public reporting, limiting clinicians’ willingness to perform a procedure in high-risk patients.64

Inappropriate diagnosis and treatment. In one study the hypothesis that a publicly reported measure would lead to overdiagnosis and prescribing was not supported.

Access restrictions. It was unclear whether public reporting contributes to reduced access for patients (e.g., avoiding high-risk patients, referring high-risk patients out of State). Studies results are inconsistent (13 studies, low strength of evidence).

Unintended provider behavior. There was some evidence from long-term care (LTC) that public reporting motivates changing coding and readmitting patients to the hospital. No evidence supported a link with surgeons or organizations withdrawing from the market or with declines in quality for items not measured (crowding out) (5 studies, moderate strength of evidence).

Harms are an important concern when studying an intervention and they have been the subject of many commentaries about public reporting. In fact, the volume of editorials and discussion is greater than the volume of research. Of the studies that examined harms, more find no evidence of the harm than evidence of harm. Research on harms related to the impact on access (e.g., selection of patients at low risk negative outcomes or expected to do well, which is referred to as cream skimming and cherry picking, or other actions by providers to change ratings by manipulating their patient populations) has mixed findings. However, some studies in LTC have found that public reporting can create incentives that lead to unintended, negative behavior by providers.

##### Key Points by Health Care Setting

Hospital cardiac

- Eight studies investigated the possibility of harms or unintended consequences from public reporting on hospital cardiac care. Results of four36,64–66 include data that suggested a negative impact while four32,34,35,37 did not.
  ○ One study64 found substantially higher hospital mortality rates for patients in New York compared with other States, but the sample size was small and consisted of a specific subgroup of cardiac patients, making it less applicable to public reporting in general.

Hospital noncardiac

- Two52,67 studies examined potential harms including inappropriate diagnosis and prescribing or increased cost (and reduced access for high-risk procedures). Neither study found evidence of these harms.

Individual clinicians

- Evidence about harms varied by the harm studied (three studies) with one finding that public reporting adversely affected access while two report that the expected negative impact on access was not supported by the data.
  ○ Public reporting appeared to increase disparities between whites and blacks or Hispanics in the receipt of CABG for 9 years after public reporting began.68 High-risk patients were more likely to have high-quality surgeons, which is counter to the hypothesis that public reporting might cause adverse selection.69
  ○ Few physicians reported leaving practice due to the impact of the public reports.31

Health plans

- Potential harms were examined in two of the included studies: “crowding out” of quality of care in areas not measured by focusing of the aspects of care that are measured70 and withdrawal of high-quality plans from the market.71 Neither study found evidence of these harms.

Long-term care

- Four studies examined different harms (selection/cream skimming, crowd out, rehospitalization, and down coding) that correspond to actions NHs may take to improve NH Compare ratings rather than actually improve the quality of care.
  ○ One study found some evidence that the number of patients admitted with pain declined among NHs that had low reported quality scores for pain and among for profit and nonprofit NHs compared with government NHs, which the authors conclude indicates some cream skimming.72 Another study that looked at patient sorting among NHs for postacute care73 found no cream skimming. Rather, high-risk patients were more likely to be admitted to high-quality facilities after public reporting.
  ○ No evidence was found that quality in other areas was “crowded out” by NH focus on the publicly reported measures (one study).74
  ○ Indications of “down coding,” that is changing the coding of assessments in order to improve NH Compare scores were found in a study of postacute care, but for only one (pain) out of three quality measures (one study).73
  ○ The most serious harm identified to date is that NHs may readmit postacute care patients to the hospital before they are assessed for NH Compare in order to improve their performance (one study).75

#### Key Question 3

Does public reporting lead to change in health care delivery structures or processes?

##### Overall Findings

Provider actions. The evidence suggests that individual clinicians and organizations respond to public reporting in positive ways including adding services, changing policy and increasing focus on clinical care (10 studies, moderate strength of evidence).

Providers, both individuals and organizations respond to public reports in identified studies by making positive changes in their behavior. Studies found that hospitals were more likely to offer new services, policies were changed, surgeons with worse outcomes left surgical practice, and quality improvement activities increased. However, data are not available for all settings and for others it is based on a small number of studies.

##### Key Points by Health Care Setting

Hospital cardiac

- No studies were identified.

Hospital noncardiac

- Three10,46,76 studies that analyzed the impact of public reports on care processes reported increases in quality initiatives.
  ○ One77 recent study showed little to no effect of public reports on quality initiatives by providers.
  ○ The results of two studies suggested that hospitals change their practice patterns related to cesarean sections when comparative data on the rates are publicly available.76,77

Individual clinicians

- Surgeons who stopped performing CABG surgeries after surgeon-level data were made public were more likely to be poor performers (bottom quartile) (one study).31

Health plans

- No studies were identified.

Long-term care

- NH administrators reported in surveys that they were taking action in response to NH Compare (three studies).63,78,79
  ○ Actions appeared to be motivated more by the administrators’ belief that public reporting influences referral from professionals and the State survey process than by patient and family use of NH Compare in their selection of NHs.
  ○ Nursing homes that reported taking actions experienced improvements in quality measures.63
  ○ An additional study documented that NH administrators invested more resources in clinical care after public reporting.80
  ○ Improvement in one QM (influenza vaccination rates) improved after public reporting, but it increased even more among community dwelling elderly, supporting the idea that factors other than public reporting may be driving change (one study).81

#### Key Question 4

Does public reporting lead to change in the behavior of patients, their representatives, or organizations that purchase care?

##### Overall Findings

Selection (market share/volume). Studies found no or minimal impact of public reporting on selection as measured by market share or volume. Contracting patterns suggest purchasers give only minimal consideration to publicly reported quality when selecting providers (47 studies, moderate strength of evidence).

For this Key Question more than any other, there is more agreement across settings. Public reports seem to have little to no impact on selection of providers by patients and families or their representatives. When an effect was found it is for a subgroup of patients (e.g., younger more educated patients).

##### Key Points by Health Care Setting

Hospital cardiac

- Public reporting had no impact on hospital volume or market share (four studies).28,31,82,83
- In studies where there was some impact on market share, the effect was small or did not persist over time (five studies).30,37,84–86

Hospital noncardiac

- Three87–89 of the six studies on patient behavior reported on patient choice. Two87,89 studies reported little to no effect whereas one88 reported increased discharge rates in public reporting hospitals.
- The other three43,90,91 studies reported on market share and volume as measures that represent patient choice. All three studies reported small decreases in market share for lower rated hospitals or hospitals that did not participate in public reporting.

Individual clinicians

- Results varied across studies.
  ○ Three studies reported no effect of reporting on referral patterns, market share, or surgeon volume.28,31,92
  ○ Three studies reported that market share or probability of selection increased for higher-quality clinicians or clinics after the data were publicly reported.84,93,94
  ○ One study found that public reports led to decreases in volume for poor performing and unrated surgeons, but that there was no corresponding increase for high performing surgeons.83

Health plans

- Publicly reported or widely distributed quality information had little impact on the selection of health plans by individuals based on the results of studies of different populations.
  ○ Quality information had no consistent or significant effect on the health plan choices made by employees of private firms (five studies).71,95–98
  ○ Four studies of public employees had mixed findings.23,99–101
    ■ Two reported limited or no impact on the choice of health plan made by State employees in Minnesota99 and Federal employees in 86 counties.23
    ■ Two additional studies of Federal employees reported that public reports lead to an increase in the use of quality information101 and switching out of plans with low scores.100
  ○ In studies that used random assignment to distribute quality rating materials to some beneficiaries of public insurance programs and not others, the quality information had no impact on plan selection (three studies).102–104
- Employers were more likely to select health plans to offer to employees that had higher HEDIS and CAHPS ratings (one study).105

Long-term care

- Six studies attempted to determine if public reporting influenced the selection of NHs.
  ○ One study looked at patient selection and used a problematic outcome measure (occupancy rate) that may have limited variation or be caused by factors other than patient selection.106
  ○ Two studies used market share to measure NH selection, with one finding no impact from the reporting of five indicators for long-stay residents on market share61 and one finding small increase in market share for postacute care associated with higher NH Compare ratings.107
  ○ Patient matching, meaning higher-risk patients selected higher quality NHs, was found to increase after public reporting (one study).73
  ○ Increase in selection of NHs with better performance on NH Compare by Medicare patients was demonstrated to be the link between higher-quality and better financial performance and this relationship was stronger after NH Compare was made public (two studies).108,109

#### Key Question 5

What characteristics of public reporting increase its impact on quality of care?

##### Overall Findings

Mode and tone of message. One study found that mode (email vs. mail) affects use of public reports, while tone of the message (risks vs. benefits) does not.

Accuracy and usefulness. One study found that the quality information contained in public reports is accurate and useful for patient selection even if there is a substantial delay between data collection and publication.

Almost no quantitative studies examined whether report characteristics affected the impact of public reporting on any outcome. Two studies were identified for public reporting on individual clinicians, but none for other settings, making it impossible to draw conclusions about the strength of evidence.

##### Key Points by Health Care Setting

Hospital cardiac

- No studies were identified.

Hospital noncardiac

- No studies were identified.

Individual clinicians

- Different report characteristics were examined in two studies that identified variation in what makes reports useful and useable for patients.
  ○ The mode (email vs. mail) and the tone of messages used to inform patients about the availability of physician performance data affected whether patients accessed it or not (one study).110
- Publicly reported data was still accurate and therefore likely to be useful to patients even when there was a substantial delay between data collection and when it was made available to the public (one study).31

Health plans

- No studies were identified.

Long-term care

- No studies were identified.

#### Key Question 6

What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care?

Competitive market. Studies have found that public reporting is more likely to result in improvements in quality in if the clinician or provider is in a competitive market (seven studies, high strength of evidence).

Baseline performance. The likelihood of improvement after public reporting is greater for entities with lower quality before or at the first instance of reporting. (five studies, high strength of evidence).

Nursing home characteristics. Characteristics (e.g., ownership) do not reliably predict how NHs react to public reporting. Studies find no consistent difference across characteristics (six studies, low strength of evidence).

Patient characteristics/subgroups. Different patient characteristics such as age, specific health care needs, and insurance coverage may increase the likelihood that publicly reported data affects choice (3 studies, low strength of evidence).

Variation in quality. Public reporting is more likely to influence quality if the level of quality varies across plans in market (one study).

Relatively consistent findings include that public reports have more of an impact in competitive markets and add that improvements are more likely to occur in the subgroup of providers with lower scores in initial public reports. While several contextual factors were identified, they do not seem to represent the complexity of the environment.

##### Key Points by Health Care Setting

Hospital cardiac

- No studies were identified.

Hospital noncardiac

- Subgroup analyses demonstrated that hospitals that are not the only facility in a market or are in a competitive market were more likely to improve quality (two studies).46,111
  ○ One of these studies also examined the financial position of the hospital and found that hospitals that were in worse financial situations were less likely to improve).111

Individual clinicians

- Employment status/tenure, which the researchers suggested served as a proxy for age, affected the likelihood that people would access comparative information about physicians (one study).110
- The impact of public reports was affected by insurance coverage—when care was covered the public reports were more likely to influence selection (one study).93

Health plans

- Contextual factors were not frequently studied in research on health plans, limiting what conclusions can be drawn from the literature.
  ○ The only study of environmental characteristics found quality information was more likely to be used in plan choice in markets that included plans of varying quality.112
  ○ Some variation in the importance of quality information to different subgroups of consumers was identified (two studies).113,114
  ○ Plans that started with lower ratings were more likely to improve their performance after public reporting (two studies).53,57

Long-term care

- Studies that examined the impact of two market characteristics, competition and occupancy rates (characteristics of the environment), found that publicly reported quality measures are more likely to improve in competitive markets and in markets with low occupancy rates (suggesting there are choices and providers must compete to fill beds).60,61,115
  ○ These findings supported the idea that public reporting provides information that influences market-based behavior.
- Ownership characteristics of NHs (e.g., for profit/nonprofit, government, chain affiliation, hospital-based) did not have a consistent effect on the impact of public reporting (two studies).59,62
- One study found that NHs with higher percentages of black residents had smaller changes in quality after public reporting, but that for some indicators they started with better QMs than NHs with fewer black residents.62
- NHs and home health agencies that started with lower publicly reported quality ratings were more likely to improve their ratings than those that started with higher scores.14,78,81
- Only one study included any analyses by patient characteristics other than their baseline risk on the QMs. A study of patient selection for postacute care found that patients with higher levels of education were slightly more responsive to public reporting.107

## Effectiveness of Public Reporting by Health Care Setting

### Hospitals

Modern public reporting started when the Health Care Financing Administration (HCFA), now Centers for Medicare and Medicaid Services (CMS), released mortality statistics for United States hospitals 25 years ago. The HCFA report and other early efforts such as New York State Cardiac Surgery Reporting System (NYS CSRS) as well as the Cleveland Health Quality Choice (CHQC) program encountered resistance, and both the HCFA report and CHQC were short lived. However, these efforts drove improvements in approaches to quality measurement and risk adjustment, establishing the foundation for many current public reports as well as larger transparency initiatives in health and hospital care.

We identified 43 quantitative studies and 43 qualitative studies that met our inclusion criteria and corresponded to our Key Questions. The quantitative studies are described and analyzed first. This is followed by a summary of the qualitative studies. Given the number of studies related to hospitals, this section differs from the others in that it is further subdivided into public reporting about cardiac care and other, noncardiac hospital care. We chose to divide the studies of public reporting on hospitals in this way to make a large number of studies easier to synthesize. This division also mirrors the development of the field. Public reports on cardiac surgery have been the focus of more research than any other type of public reporting to date. While this may be simply the result of the fact that cardiac public reports have been continuously produced for over two decades, it is important to understand and acknowledge the influence that cardiac public reports have had not just on public reporting about hospitals, but on public reporting and quality improvement across all health care settings.

Information abstracted from the articles is included in the Evidence Tables in Appendix H and Appendix I.

#### Overview of Findings

##### Cardiac Public Reports

###### Quality of Care (Key Question 1)

- While eight studies found that mortality tended to improve (decrease) over time with public reporting about cardiac procedures (eight studies),28–35 this finding was not consistent with four other studies finding no difference in mortality associated with public reporting (four studies).36–39

###### Harms (Key Question 2)

- Eight studies investigated the possibility of harms or unintended consequences from public reporting on hospital cardiac care. Results of four36,64–66 include data that suggested a negative impact while four32,34,35,37 did not.
  ○ One study64 found substantially higher hospital mortality rates for patients in New York compared with other States, but the sample size was small and consisted of a specific subgroup of cardiac patients, making it less applicable to public reporting in general.
  ○ Differences in populations and time periods may explain conflicting conclusions about whether access to care is adversely affected by public reporting.

###### Impact on Providers (Key Question 3)

- No studies were identified.

###### Impact on Patients or Purchasers (Key Question 4)

- Public reporting had no impact on hospital volume or market share (four studies).28,31,82,83
- In studies where there was some impact on market share, the effect was small or did not persist over time (five studies).30,37,84–86

###### Public Report Characteristics (Key Question 5)

- No studies were identified.

###### Context (Key Question 6)

- No studies were identified.

##### Noncardiac Public Reports

###### Quality of Care (Key Question 1)

- Seven studies evaluated the effect of regional public reporting efforts on hospital quality.
  ○ One40 earlier study of the Cleveland Health Quality Choice Program showed an effect of public reporting but the other four41–44 did not.
  ○ Two evaluations of QualityCounts10,45 in Wisconsin found significant effect on quality.
- Four46,47,49,111 studies evaluated State level public reporting efforts. They all showed slight improvement in quality in hospitals.
- Three50–52 studies were about national level public reports and they all reported slight improvement in quality in hospitals.

###### Harms (Key Question 2)

- Two52,67 studies examined potential harms including inappropriate diagnosis and prescribing or increased cost (and reduced access for high risk procedures). Neither study’s results found evidence of these harms.

###### Impact on Providers (Key Question 3)

- Three10,46,76 studies that analyzed the impact of public reports on care processes reported increases in quality initiatives.
- The results of two studies suggested that hospitals change their practice patterns related to cesarean sections when comparative data on the rates are publicly available.76,77

###### Impact on Patients or Purchasers (Key Question 4)

- Three87–89 of the six studies on patient behavior reported on patient choice. Two87,89 studies reported little to no effect whereas one88 reported increased discharge rates in public reporting hospitals.
- The other three43,90,91 studies reported on market share and volume as measures that represent patient choice. All three studies reported decreased market share for lower rated hospitals or hospitals that did not participate in public reporting.

###### Public Report Characteristics (Key Question 5)

- No studies were identified.

###### Context (Key Question 6)

- Subgroup analyses demonstrated that hospitals that are not the only facility in a market or are in a competitive market were more likely to improve quality (two studies).46,111
  ○ One of these studies also examined the financial position of the hospital and found that hospitals that were in worse financial situations were less likely to improve.111

#### Description of Quantitative Studies

The 43 studies of public reporting and hospitals were published between 1988 and 2011. Thirty-seven were about hospitals in the United States, two were about Canadian hospitals,38,116 one was about hospitals in Northern England,34 two were in Korea52,77 and one90 studied hospitals in two regions in Germany. Twenty-one of these studies were about public reporting related to outcomes of cardiac care in hospitals, predominately cardiac surgery. The other twenty-two reported on public reporting initiatives concerning other hospital services or general/overall hospital quality. The cardiac and noncardiac public reports are named in the intervention description below and the public reports are described in Appendix E. In describing and summarizing the studies, the cardiac and noncardiac studies are addressed separately in this report for ease of comprehension and synthesis.

The populations in the included studies were most frequently hospitals as providers of health care services that were the subject of the public report. It was their response to public reporting that was expected to result in improved quality of care. An important related topic in the studies of hospital and public reporting is whether public reports create incentives for hospitals to change the type of patients they treat resulting in reduced access to appropriate services for patients. Patients and their representatives were included as the population in some studies, as their selections from available hospitals were measured in terms of changes in volume or market share expected to be gained or lost when information about quality was made available through public reports. The measures and outcomes that correspond to these populations are discussed in more detail in the “outcomes” description.

In the cardiac studies, 10 of the studies evaluated public reports about hospitals in New York State28–32,36,64,65,84,86 and two compared New York State with Pennsylvania66 or California.85 One study evaluated hospital performance in Massachusetts, a State without public reporting at the time, by comparing it to New York State and Northern New England, regions that had public reporting about hospital cardiac care,39 and another study made comparisons across several States and regions,35 comparing New York State, Pennsylvania, New Jersey, and Ohio, all States with cardiac public reports, with the rest of the country. The seven studies that did not involve New York State concerned hospitals in Pennsylvania,82,83 California,33,37 Northern England,34 and two studies about Ontario, Canada.38,116

The 22 studies of hospital quality reporting on noncardiac services included regional, State, and national public reports. Six studies assessed the impact of the CHQC program.40–44,76 Three studies were of hospitals in Wisconsin,10,45,47 one of Missouri hospitals,46 and two in Pennsylvania.49,111 The remaining seven studies were of national public reporting initiatives in the United States,50,51,67,87–89,91, one regional effort in Germany,90 and national reports on hip replacement outcomes52 and cesarean rates77 in Korea.

The public reporting interventions were dominated by public reports generated and distributed by State health departments or other government entities. All of the previously mentioned studies of hospital cardiac care in New York State28–32,36,64,65,84,86 concerned the NYS CSRS produced by the New York State Department of Health. The NYS CSRS began reporting mortality rates for coronary artery bypass graft surgery (CABG) and later expanded to cover other cardiac interventions (see Appendix E).

The studies that concurrently evaluated reports from other States examined Pennsylvania’s State mandated report on cardiac surgery outcomes66 that was later expanded to include outcomes for patients with acute myocardial infarction (AMI), California’s Hospital Outcomes Project (CHOP) was a State sponsored program that reported mortality for AMI and complication rates for cervical and lumbar discectomy and was the subject of one study.85 A public report on coronary artery bypass graft surgery (CABG) outcomes in California was published by the Office of Statewide Health Planning and Development and evaluated in two identified studies.33,37 Pennsylvania also developed a CABG hospital report,82,83 as did the Canadian Province of Ontario,38 which expanded its efforts to include process of care indicators for AMI and congestive heart failure (CHF).116 In England, public reporting by the National Health Service was preceded by reports produced by a commercial company (Dr. Foster), and commercial reports were the subject of one study.34 State involvement in public reports about other types of care that have been studied include a Missouri State report on hospital obstetrics,46 a program of the Pennsylvania Health Care Cost Containment Council that began reporting AMI and CABG outcomes but quickly expanded to include multiple diagnoses and procedures.49,111

The remaining studies involved public reports or public reports created by regional or national entities with one exception (one study is of a ranking published in a popular magazine91). Regional efforts included the CHQC reports which were part of a program of a voluntarily coalition of hospitals, physicians, and employers in Northern Ohio designed to promote selective contracting and quality improvement. These were the most frequently studied noncardiac reports.40–44,76 In Wisconsin the Hospital Association launched a Web site called CheckPoint that included several quality and safety measures47 for hospitals in the State, while a report known as QualityCounts was produced by a large employer purchasing cooperative in Madison, Wisconsin.10,45

National efforts comprised both the earliest and the most recent public reports. The HCFA created the first modern public report when it released hospital mortality data from 1986 through 1992. Dubbed the “death list”, this report was the subject of two of the included studies.87,88 A long-standing program of registry-based reports on results of kidney transplantation dating from 1991 was revamped and starting in 2001 a university-based center with a U.S. government contract released reports every 6 months via the internet.89 One study67 examined the impact of one of several measures of the national Hospital Quality Alliance (HQA), which included 98 percent of U.S. hospitals, and collected and publicly disseminated hospital performance measures. The two most recent studies of public reporting on hospitals assessed the impact of U.S. government sponsored and directed efforts to make information public on patient experience thorough the hospital version of the Consumer Assessment of Healthcare Providers and Systems (HCAHPS) report51 and the ongoing provision of process measure through Hospital Compare on a CMS Web site made possible by the HQA coalition.50 Studies of public reporting in other countries included a voluntary private program in Germany,90 the national release of data on cesarean rates,77 and hip replacement52 in Korea.

The most common comparator in the studies of cardiac public reports is a time period prior to public reporting. Seven studies were interrupted time series^a,28,29,32,34,38,66^ using multiple measures before and/or after the public reports made data available, while one study compared single pre and post test time periods.33 Several studies relied on data available only after public reporting was initiated including four “post only” time series30,31,83,85 and two single group post only studies.82,84 Comparison groups were less common, however one study compared patients from New York State to patients from States in a registry64 and another compared all New York State hospitals to eight hospitals in Michigan.36 Four studies compared multiple groups over time. One compared hospitals that did and did not participate in reporting over a period during which three reports were issued37 while another compared several States with public reports to the rest of the country.35 Two studies employed designs that deviated from usual multiple group time series. One compared groups of patients treated at the Cleveland Clinic defined by place of residence in order to determine if the types of patients from New York State changed after public reporting.65 The other study compared trends in Massachusetts, a State without public reporting about cardiac services at the time, with trends in New York State and Northern New England after public reporting.39 One randomized trial of public reporting for hospitals was conducted in Ontario, Canada and hospitals were assigned to receive publicly released data on their performance on AMI and CHF process measures either early or delayed (21 months later).116

a For definitions of study design types used in this report, see Appendix D.

A time without public reporting was the most common comparator in the noncardiac hospital studies as well. Six studies were interrupted time series40,42,43,67,77,88 and four were time series post public reporting only.50,76,89,91 Five studies analyzed pre and post reporting data for one group,47,51,52,87,117 while two reported post public report information for one group.44,111 Three studies (four out of the 17 articles) involved a comparison group: one comparison group interrupted time series tracked mortality over time and compared one area of Ohio to the rest of State41 and another compared pre- and postreporting outcomes for patients in Pennsylvania to patients in other States. In one study reported in two articles10,45 a group of hospitals that voluntarily participated in public reporting were compared to the remainder of the hospitals in the State which were randomly assigned to receive either confidential feedback or no data.

The quality assessment of these studies was not based solely on study design, but was heavily weighted toward the consideration of the appropriateness of the comparison across groups and time periods and the ability of the study to address confounding. (For a description of the quality assessment criteria see Appendix F, for the ratings of studies see Appendix G). Sixteen studies were rated as good, 22 as fair, and five as poor.

The outcomes in the studies of hospital public reports about cardiac surgery and services have included mortality, volume or market share, and adverse selection or access, and studies often included more than one outcome. Mortality, usually in hospital though occasionally 30-day, was the subject of many of the public reports and studies examining whether hospitals responded to public reporting by changing practices that resulted in lowering mortality (Key Question 1). This outcome was the focus in 13 of the 21 studies of cardiac public reports.28–39,64 The next most frequent outcomes were changes in volume of discharges or market share, both intended to measure the impact of public reports on the selection or choice of hospitals. Volume or market share was the outcome in nine cardiac studies.28,30,31,37,82–86 Eight studies evaluated adverse selection and reductions in access which are frequently cited as possible harms associated with public reporting (Key Question 2). These studies examined whether hospitals changed their treatment patterns in order to improve their rating by not treating patients with higher risks of negative outcomes.32,34–37,64–66

Mortality was the most frequent outcome in the noncardiac hospital studies as well. In 12 of the 16 studies that examined the impact of hospital public reports on quality of care (Key Question 1), six focused on mortality40–43,49,111 and two examined mortality as well as other outcomes.44,45 Other studies reported on changes in the rate of obstetrics procedures,46,76,77 outcomes from specific procedures,52 patient experience,51 or process of care measures.47,50 Two studies addressed potential harms (Key Question 2) and in these case the outcomes were rates of pneumonia diagnosis and antibiotic administration67 and increase in cost of hip surgery following public reports.52 Provider behaviors (Key Question 3) were outcomes in four studies including changes in services offered by hospital, policies, and practices related to cesarean section46,76,77 and quality improvement activity.10 Six studies looked for public report impact on choice of hospital (Key Question 4) through occupancy rates,87 volume of discharges,88,91 or market share.43,89,90 Two noncardiac studies also analyzed whether outcomes varied by market characteristics46,111 (Key Question 6).

#### Effectiveness by Outcome/Key Question: Detailed Analysis of Quantitative Studies

##### Cardiac Public Reports

The findings from 20 of the 21 studies of public reporting about hospital cardiac programs are presented in Table 2. The one study that does not fit in the structure of the table is discussed separately under Key Question 1. The studies are listed in chronological order by year of publication and the results are presented in a reduced form to provide an overview. More details about the primary results can be found in the Hospital Summary Table (Table 3) at the end of this section, and in the Evidence Table in Appendix H.

Table 2 Study findings: hospital cardiac public reports

Author, Year | Report | Study Design | Mortality (KQ 1) | Volume -Market Share (KQ 4) | Access-Adverse Selection (KQ 2)
Hannan, 1994^28^ | NYS CSRS | Interrupted time series | ↑ | ↔ | NS
Hannan, 1994^29^ | NYS CSRS | Interrupted time series | ↑ | NS | NS
Foreman, 1995^82^ | PA HER & CABG | One group post only | NS | ↔ | NS
Omoigui, 1996^65^ | NYS CSRS | Multiple group time series | NS | NS | ↓
Ghali39 | MA with none, NYS CSRS, and Northern NE | Comparison group(s) time series post only | ↔ | NS | NS
Mukamel, 1998^84^ | NYS CSRS | One group post only | NS | ↑ | NS
Peterson, 1998^32^ | NYS CSRS | Interrupted time series | ↑ | NS | ↑
Hannan, 2003^35^ | NYS CSRS; PA HC4; NJ Department of Health and Senior Services Registry; CHQC; Northern New England Cardiovascular Study Group (not public) | Multiple group time series | ↑ | NS | ↔
Dranove, 2003^66^ | NYS CSRS and PA | Interrupted time series | NS | NS | ↓
Cutler, 2004^30^ | NYS CSRS | Time series post only | ↑ | ↑ | NS
Romano, 2004^85^ | NYS CSRS and CA CHOP | Time series post only | NS | ↔ in CA ↑ in NY State limited time | NS
Moscussi, 2005^36^ | NYS CSRS | Comparison group(s) post only | ↔ | NS | ↓
Jha, 2006^31^ | NYS CSRS | Time series post only | ↑ | ↔ | NS
Carey, 2006^33^ | CA CABG Report | One group pretest post test | ↑ | NS | NS
Guru, 2006^38^ | Ontario, CA Cardiac Reports | Interrupted time series | ↔ | NS | NS
Bridgewater, 2007^34^ | UK Reports: Commercial | Interrupted time series | ↑ | NS | ↑
Dranove, 2008^86^ | NYS CSRS | Interrupted time series | NS | ↑ | NS
Apolito, 2008^64^ | NYS CSRS | Comparison group(s) post only | ↔ CABG and PCI | NS | ↓
Romano, 2011^37^ | CCMRP | Multiple group time series | ↔ | ↑ | ↔
Wang 2011^83^ | PA CABG Guide | Time series post only | NS | ↑ | NS

Notes: ↑ = improvement, higher quality, positive impact; ↔ = no difference, no impact; ↓ = worse, lower quality, negative impact. CABG = coronary artery bypass graft surgery; CCMRP = California CABG (Coronary Artery Bypass Graft) Mortality Reporting Program; HER = Hospital Effectiveness Report; NS = not significant; NYS CSRS = New York State Cardiac Surgery Reporting System; PA CABG = Pennsylvania Coronary Artery Bypass Graft [CABG] reports; PCI = percutaneous coronary intervention; UK = United Kingdom

Table 3 Summary of evidence: public reporting on hospitals

Key Question 1: Does public reporting result in improvements in the quality of health care (including improvements in health care delivery structures, processes, or patient outcomes)?

Key Question 2: What harms result from public reporting?

Key Question 3: Does public reporting lead to change in health care delivery structures or processes?

Key Question 4: Does public reporting lead to change in the behavior of patients, their representatives, or organizations that purchase care?

Key Question 5: What characteristics of public reporting increase its impact on quality of care?

Key Question 6: What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality

Author Year (QA) | Public Report | Study Overview | Key Question | Results (↑Improvement; ↓Worse; ↔No Difference)
Apolito 2008^64^ (Good) | NYS CSRS | Compares management of patients with AMI complicated by cardiogenic shock using rates of cardiac catheterization and revascularization and in-hospital mortality in 11 NY State centers, where public reporting is present, to 12 non NY State centers where there is no public reporting to investigate potential negative influences of NYS CSRS. N=545 eligible patients in SHOCK registry (N=220 NY State; N=325 non NY State) | 1 | ↓ NY State patients were more likely to die while in the hospital compared to propensity matched non NY State patients. ↔ but among those undergoing PCI/CABG, there was not a statistically significant relationship.
Apolito 2008^64^ (Good) | NYS CSRS | | 2 | ↓ NY State patients were approximately half as likely as non NY State patients to undergo 3 of 4 cardiac procedures (angiography, PCI, or PCI and CABG). Odds ratios for CABG surgery alone were not statistically significant for NY State compared to non NY State patients. Among patients who were not revascularized (no PCI or CABG), NY State patients were 2.12 times more likely to die in hospital (p=0.01).
Baker 2002^42^ (Fair) | Cleveland Health Quality Choice (CHQC) | Examines temporal RAMR trends using in-hospital, 30-day, and early, post discharge mortality in Medicare patients between 1991 and 1997 in Northeastern Ohio hospitals for six medical conditions (AMI, CHF, gastrointestinal hemorrhage, COPD, pneumonia, and stroke) | 1 | ↔ Overall: in hospital mortality declined, but early post discharge increased, resulting little impact on 30 mortality For six selected conditions In hospital mortality ↑4 of 6 decline in mortality Early Post Discharge ↓5 of 6 increase in mortality 30-day Mortality ↑ 2 of 6 decline in mortality CHF and COPD ↔ 3 of 6 no difference ↓1 of 6 increase in mortality for stroke
Baker 2003^43^ (Fair) | Cleveland Health Quality Choice (CHQC) | Examines whether non Federal hospitals in Cleveland area participating in CHQC that were identified as mortality outliers were more likely to gain or lose market share between July 1991 and December 1997 compared to those with average mortality. Also examines whether hospitals with higher-than-expected mortality rates improved 30-day mortality more than hospitals with average mortality rates. N=30 Hospitals; N=17 Outliers | 1 | ↔ Risk adjusted mortality did not significantly decline after reports for average or below average hospital. Only effect was one hospital had significant improvement after publication.
Baker 2003^43^ (Fair) | Cleveland Health Quality Choice (CHQC) | | 4 | ↔ Market share did not significantly change for hospitals designated as outliers in terms of mortality.
Bridgewater 2007 (Good)34 | Multiple Reports on named Surgeon and Hospital outcomes in UK | Examines changes in in-hospital mortality in Northwest England associated with coronary artery surgery and the number of very high risk patients undergoing coronary artery surgery in years before (April 1997-March 2001) and after publication (April 2001-March 2005) of cardiac surgery mortality data. N=25,730 patients | 1 | ↑ Ratio of observed to expected mortality associated with coronary artery surgery decreased from 0.80 to 0.51 after public reporting.
Bridgewater 2007 (Good)34 | Multiple Reports on named Surgeon and Hospital outcomes in UK | | 2 | ↑ Contrary finding to adverse selection, the number of high risk patients that underwent surgery increased after public reporting (14.1% vs. 16.8%) p<0.001.
Carey 2006^33^ (Fair) | California Coronary Artery Bypass Graft Mortality Reporting Program | Assesses the impact of public reporting on changes in the incidence of PCI and CABG procedures and rates of in-hospital and 30-day mortality and readmission for repeat procedures in CA before and after public reporting. N=115 hospitals in both periods; Overall N~120 (6 stopped and 7 started performing at some point during study period) | 1 | ↑ Observed to Expected mortality ratio declined after public reporting in all 4 procedures under (CABG, PCI, CABG+, Value), but the effect was small (e.g. CABG mortality ORs were 1.17 pre vs. 0.97 post)--no test of significance
Caron 1999^76^ (Poor) | Cleveland Health Quality Choice | Assesses whether hospitals in the Cleveland, Ohio area have responded to public concern about improving their cesarean section and VBAC rates. N=18 hospitals, and survey of quality management directors or personnel deemed appropriate by the director, obstetricians, or labor and delivery nurses. | 3 | ↑15 of 18 hospitals indicated that they currently have an initiative in place to reduce their cesarean section rate. There was no significant correlation between organizational environment and predicted cesarean section rate.
Caron 2004^44^ (Fair) | Cleveland Health Quality Choice (CHQC) | Assesses whether hospitals in the Greater Cleveland area that improved over time in one clinical area also improved in other areas across a 5 year time span. Uses non obstetric (AMI, CHF, and stroke LOS and mortality rates) and obstetric outcomes (total cesarean, primary cesarean, and vaginal birth after cesarean rates). N=27 hospitals for non obstetrics; N=20 hospitals for obstetrics. | 1 | ↑ 9 outcomes all improved over the 5 year period (Mortality and LOS for AMI, CHF, Stroke, and caesarean, VBAC and total caesarean) ↑ Correlation suggest hospitals that improve in one area improve in others.
Clough 2002^41^ (Fair) | CHQC | Compares in-patient mortality rates from 1992–1995 in Cleveland area hospitals to hospitals in the rest of Ohio to determine whether the CHQC had an effect on inpatient mortality in Cleveland. N=30 hospitals in Cleveland | 1 | ↔ after adjustments for differences in case mix, the rate of mortality decline in Cleveland (with reporting) did not differ from the rest of Ohio.
Cutler 2004^30^ (Fair) | NYS CSRS | Examines CABG surgery cases and RAMR in NY State hospitals between 1991 and 1999 to determine whether the NYS CSRS affected where patients went for bypass surgery and whether it led to improvements in medical quality in hospitals identified as high or low mortality outliers. | 1 | ↑ RAMRs at high-mortality hospitals dropped ~1.3% over 36 months. RAMRs at low-mortality hospitals rose slightly over 36 months.
Cutler 2004^30^ (Fair) | NYS CSRS | | 4 | ↑ In first year of being recognized as an outlier, high-mortality hospitals experienced reductions in CABG cases while in low-mortality hospitals CABG cases increased. After 12 months, growth and decline in CABG cases was not significant.
Dranove 2003^66^ (Good) | NYS CSRS and PA CABG Guide | Analyzes patients in PA and NY State undergoing AMI and CABG procedures before and after the public release of information (1991 in NY State; 1993 in PA) to examine effects of public reporting in NY State and PA. Between 1987–94: N=1,770,452 AMI patients; N=967,882 CABG patients | 2 | ↓Public reports led to selection by providers: Patients receiving CABG in States with reports had declining illness severity ↓Public reports increased sorting of patients with more seriously ill patients going to teaching hospitals These two results could explain increase in wait time as selection and sorting take time Increase in costs and adverse health outcomes in States with public reports.
Dranove 2008^86^ (Good) | NYS CSRS | Assesses the effectiveness of the “news” that public reports provides to the market by analyzing hospital demand in 18 hospitals in the NYC metro area before (1989) and after public reporting (1990, 1991). N=23854 CABG patients from 1989–1991 | 4 | ↑ Public reports have an effect on patient choice of hospital when they provide information that differs from prior beliefs, but this is not symmetrical ↑ Hospitals with lower than expected rankings experience a statistically significant decrease in demand ↔ Higher ranking hospitals: public reports have no significant effect on market share
Elliott 2010^51^ (Good) | HCAHPS | Compares changes in patients’ experiences with inpatient care at American hospitals since public reporting of HCAHPS. Analyzes hospital scores based on when they began participating in public reporting (original vs newcomers) and how many beds they have (<100 beds vs. >100 beds). Also looks at change in hospitals that reported in both 2008 and 2009. N changes depending on group and year. Overall N=3863 Hospitals | 1 | ↔ Marginal increase between 2008 and 2009 in percent of positive responses on survey in 8 of 9 categories. None had decreases but all increases were 0.9% or less. Change in doctor communication was not significant. ↑ Newcomers to public reporting outperformed hospitals originally participating in HCAHPS in 7 of 9 categories. 2 categories were not significant. More newcomers were smaller hospitals and smaller hospitals tend to perform better on CAHPS
Evans 1997^111^ (Fair) | PHC4: HER | Examines responses of PA hospitals between 1990 and 1992 to PHC4’s HER by analyzing changes in mortality, morbidity, length of stay, and charges. N=134 hospitals | 1 | ↑ Mortality and Morbidity both had statistically significant declines after reporting in trend analyses that controlled for regression to the mean.
Evans 1997^111^ (Fair) | PHC4: HER | Examines responses of PA hospitals between 1990 and 1992 to PHC4’s HER by analyzing changes in mortality, morbidity, length of stay, and charges. N=134 hospitals | 6 | ↑ Hospitals that performed poorly at base line improved in mortality ↔ Hospitals that performed poorly at base line had no improvement in morbidity ↑ Hospitals in competitive markets had more improvement in mortality ↔ Financial position and competition had no impact on morbidity ↓ Hospitals in lower financial position had lower levels of improvement in mortality
Foreman 1995^82^ (Poor) | Hospital Effective-ness Report (HER) Consumer Guide to Coronary Artery Bypass Graft Surgery (CABG Guide) | Uses two of PHC4’s public reports (HER and CABG Consumer Guide) to examine whether PA hospitals that received high or low quality ratings in the first year of fully released data (1989 or 1990) experienced subsequent changes in patient admissions. N=156 Hospitals | 4 | ↔ Identification of high and low quality hospitals in PA public reports did not lead to any significant change in patient growth in any of the 9 regions studied.
Friedberg 2009^67^ (Good) | One of 10 Hospital-level performance measures reported by the Hospital Quality Alliance | Examines whether public reporting is associated with overdiagnosis of pneumonia, excessive antibiotic use, or inappropriate prioritization of patients with respiratory symptoms visiting EDs in the U.S. before and after public reporting (Jan 2004). | 2 | ↔ No evidence that public reporting increased anti-biotic use or inappropriate ED diagnosis. Waiting times for patients with and without respiratory symptoms increased slightly after public reporting, but expected over prioritization of patients with respiratory symptoms not evident.
Ghali, 1997^39^ (Fair) | NYS CSRS and Northern New England | Compares CABG surgery mortality trends during 1990, 1992 and 1994 in Massachusetts where there is no public reporting to the decreases in mortality in NY State and northern New England where there is public reporting and outcomes feedback programs, respectively. N=12 hospitals Massachusetts Isolated CABG Procedures: 1990 N=5395; 1992 N=5,818; 1994 N=5,915 | 1 | ↔ Adjusted mortality rates for CABG cases in Massachusetts where there is no public reporting fell from 1990–1994 ↔ Massachusetts experienced similar reductions in the percent of in-hospital mortality as northern New England where an outcomes feedback program was in place. ↑ New York, where public reporting was present, had slightly larger reductions in unadjusted in-hospital mortality than Massachusetts.
Guru 2006^38^ (Fair) | Ontario Cardiac Reports | Evaluates differences in 30-day mortality rates for patients undergoing isolated CABG surgery at Ontario hospitals during a transition from no reporting to confidential reporting to public reporting of CABG surgery outcomes (Sept 1991–March 2002). N=9 Institutions (no report: N=12,691; confidential report: N=32,272; public report: N=22,730) | 1 | ↓ 30-Day RAMR in Ontario dropped by 29% after confidential reporting, but there was no significant change after reporting was made public.
Hannan 1994^28^ (Good) | NYS CSRS | Examines impact of CSRS on changes in RAMR over time by dividing participating hospitals and surgeons into three groups (high, middle, and low) based on RAMR prior to public reporting. Also analyzes hospitals and surgeons based on outlier status. N=30 Hospitals; N=95 Surgeons | 1 | ↑ Compared to 1989 baseline outlier status, all outlier groups experienced improved RAMR over the following three years. Reduction in RAMR was most profound in hospitals with higher than expected rates in 1989.
Hannan 1994^28^ (Good) | NYS CSRS | | 4 | ↔ CABG volume percentage by hospital groups based on mortality remained relatively stable between 1989–1992 while total overall volume increased.
Hannan 1994b29 (Good) | NYS CSRS | Assesses changes in the relationship between hospital RAMR and average patient severity of illness and actual, expected and risk-adjusted mortality rates, and volume among 30 NY State hospitals performing CABG surgery on 57,187 patients from 1989, when data were first publicly released, through 1992. | 1 | ↑ Despite increases in expected mortality rates, actual and risk adjusted mortality rates fell overall during the study period. In addition, volume increased yearly.
Hannan 2003^35^ (Good) | NYS CSRS; PA HC4; NJ Department of Health and Senior Services Registry; CHQC; Northern New England Cardiovascular Study Group (not public) | Assessed in-hospital, 30-day, and risk adjusted in-hospital/30-day mortality, changes in out-of-region CABG surgery in regions with quality improvement/public dissemination efforts with the rest of the country. | 1 | ↑ When compared to regions without public reports or similar QI efforts regions and States with public reports experienced lower RAMRs during the period of 1994–1999.
Hannan 2003^35^ (Good) | NYS CSRS; PA HC4; NJ Department of Health and Senior Services Registry; CHQC; Northern New England Cardiovascular Study Group (not public) | | 2 | ↔ No evidence of harm. Northern New England and New Jersey also experienced statistically significant decreases in the percent of patients going out of the region for CABG. Although not significant, OH and NY experienced slight increases while PA did not change. However there was a decrease in out of area surgeries for all regions from the pre to the post public reporting time period.
Hibbard 2003^10^ (Fair) | QualityCounts | Evaluates the impact of public reporting on quality improvement activities in obstetrics and cardiac care in Wisconsin hospitals by comparing QI activities in 24 hospitals with public reporting, and two groups of hospitals randomized to receive either private quality feedback reports (N=41) or no report (N=46). Total N=111 hospitals. Interviews were conducted with hospital CEOs, medical directors and/or quality improvement directors. (62% response rate). | 3 | ↑ Among hospitals identified as worse than expected in obstetrics, QualityCounts led to quality improvement activities in hospitals receiving public reporting more than 2x as much as hospitals with private reporting, which undertook QI activities slightly more than those with no reporting. ↔ Public reporting was not associated with differences in cardiac QI activities among hospitals with worse-than-expected outcomes. ↑ Hospitals participating in public reporting believed that public reporting would affect their image, with those with as expected and better-than-expected outcomes believing public reporting would enhance their hospital’s image. ↔ Similar beliefs among private and non reporting hospitals were not significant.
Hibbard 2005^45^ (Fair) | QualityCounts | Compares Wisconsin hospitals receiving public reporting, private reporting, and no reporting to assess hospitals’ change in overall performance and clinical measures two years following the release of Wisconsin’s QualityCounts report. N=111 hospitals (24 public reporting, 41 private reporting; 46 no reporting). | 1 | ↑ Differences between improvements and declines in obstetric performance after public reporting were greater in the public reporting group than in private reporting and non reporting hospitals with a third of public reporting hospitals making improvements. ↑ Among hospitals with worse-than-expected baseline scores, public reporting hospitals improved more than other two groups.
Hollenbeak 2008^49^ (Good) | PA Hospital Effectiveness/ Performance Report | Compares associations between intensive public reporting and no reporting/limited reporting to in-hospital mortality in PA and other States with and without public reporting. N=168,104 Propensity-matched patient pairs | 1 | ↑ During periods of intensive reporting, in-hospital mortality odds ratios for all 6 conditions studied were lower in PA than in States with limited or no public reporting.
Howard 2006^89^ (Fair) | University Renal Research and Education Association semiannual reports on kidney transplant graph survival | Compares patient transplant registrations and live donor transplants at transplant centers in the United States over time (from Sept 1, 1999 to Oct 30, 2002) to assess the influence of URREA center-specific public reports. N=58,164 patients | 4 | ↔ public reports had no effect on demand (choice) of transplant centers
Jha 2006^31^ (Good) | NYS CSRS | Examines whether NY State hospitals and surgeons identified as having high or low RAMR in one year of the CSRS predicts future performance. Also analyzes effects of hospital and surgeon performance on patient market share in the following year and whether surgeon performance is associated with likelihood of ceasing practice. | 1 | ↑ Moderate correlation between top performing hospitals at baseline on CABG mortality and high performance in subsequent years.
Jha 2006^31^ (Good) | NYS CSRS | | 4 | ↑Increase in demand for centers with better scores by younger patients and patients with college educations.
Jang 2010^52^ (Fair) | Not named, Presented on National Health Insurance Corporation website and in press | Assessed the impact of reporting performance information on the readmission rates, length of stay, change in cost, and patient selection of hip hemiarthroplasty in Korea from January 2006-April 2008 (n=22851 surgeries at 851 medical institutions). | 1 | ↑ Public reporting in Korea on hip surgeries improved (decreased) length of stay by 10%, but when comparing high-volume hospitals after public reporting to pre reporting high-volume or low-volume hospitals, the results were not significant. Overall probability for readmission after public reporting was lower (OR+049) than before public reporting, although readmissions in sub-group analyses of high and low-volume institutions was not significant.
Jang 2010^52^ (Fair) | Not named, Presented on National Health Insurance Corporation website and in press | | 2 | There was not an associated change in cost for procedures.
Jang 2010^52^ (Fair) | Not named, Presented on National Health Insurance Corporation website and in press | | 4 | Patient selection of high-volume hospitals (serving as a proxy for higher quality) after public reporting was marginally insignificant (p=0.059).
Jang 2011^77^ (Fair) | Not named, Presented on National Health Insurance Corporation website and in press | Assessed the effect of Repeated Public Releases for reducing adjusted cesarean section rates and to analyze the characteristics of responsive institutions to repeated public releases in Korean hospitals that provide cesarean sections (N=1194) from August 2004 to June 2007. | 3 | Repeated public reports were only mildly effective in decreasing the rates of cesarean section
Longo 1997^46^ (Fair) | ShowMe Buyers Guide: Obstetrical Services | Examines the impact of an obstetrics consumer report in Missouri (1993 ShowMe Buyers Guide: Obstetrical Services) on hospital behavior during the year following dissemination. N=82 Hospitals (Response rate to telephone survey = 93%; 82 out of 88 hospitals) | 1 | ↑ Improvement in ultrasound and cesarean ↔ No significant improvement in VBAC
Longo 1997^46^ (Fair) | ShowMe Buyers Guide: Obstetrical Services | | 3 | 30–50% of facilities that did not offer services such as car seats and follow up began after the public report. Some, but now all facilities reported changing or planning to change polices.
Longo 1997^46^ (Fair) | ShowMe Buyers Guide: Obstetrical Services | | 6 | Facilities in communities with multiple facilities were more likely to say they were going to change policy.
Mennemeyer 1997^88^ (Fair) | HCFA mortality report | Uses pre HCFA mortality report data (1983) as baseline to examine whether HCFA public reports led to changes in community hospital discharges in outlying hospitals (1 or more σ from mean) between 1984 and 1992. N=23,564 over 9 year period. | 4 | ↑Hospital discharges (used as measure of selection) declined in hospitals with higher mortality after reporting; however the effect was small: a hospital with double the expected mortality is predicted to have 46 few discharges a year. ↓Another analysis found that media reporting of an untoward event had a much larger impact on discharges--a 9% reduction. This is based on a small number of incidents.
Moscucci 2005^36^ (Fair) | NYS CSRS | Compares in-hospital mortality among 11,374 patients in a multicenter PCI database in Michigan which has no public reporting to 69,048 patients in a Statewide New York PCI database where public reporting is present to determine the potential effect of public reporting on PCI case selection. N=34 NY State hospitals; 8 MI hospitals | 1 | ↔No difference in NY State vs. MI mortality when adjusted for comorbidities and volume ↑Lower mortality in NY State with public reporting compared to MI for unadjusted and adjusted for age and gender.
Moscucci 2005^36^ (Fair) | NYS CSRS | | 2 | ↓Difference in case mix in NY State vs. MI absent different levels of disease suggests New York is not treating higher risk patients.
Mukamel, 1998^84^ (Fair) | NYS CSRS | Examines whether NY State hospitals offering CABG surgery and surgeons with better RAMR in NYS CSRS experience increases in market shares and prices over time. N=30 Hospitals; N=114 Surgeons | 4 | ↑ Increases in RAMR on report led to a decrease in subsequent market share. In NYC change in market growth was not significantly associated with published RAMR, but published RAMR decreased growth in Upstate NY State by 8.8 percentage points.
Omoigui 1996^65^ (Poor) | NYS CSRS | Examines whether NY State’s decrease in RAMR for CABG surgery was due to high-risk CABG surgery patients in NY State being referred out of State to the Cleveland Clinic in Cleveland, Ohio. N=9442 isolated CABG operations at the Cleveland Clinic between 1989 and 1993. | 2 | ↓increased mortality among NY State patients at Cleveland Clinic compared to patients from other locations and NY State patients in prior period suggests public reporting is increasing referral of high-risk patients out of NY State.
Peterson 1998^32^ (Good) | NYS CSRS | Analyzes the effects of NYS CSRS provider profiling on bypass surgery access and outcomes in elderly patients (Medicare) in NY State by examining data before and after public release in NY State to determine whether provider profiling increased the percentage of patients going out-of-State for bypass surgery, whether surgery following myocardial infarction (MI) changed, and whether bypass surgery outcomes improved more rapidly in NY State than in the rest of the nation between 1987 and 1992. N=39,396 NY State patients; N=662,675 non NY State patients | 1 | ↑ Mortality rates fell significantly in NY State and faster than in the rest of the country post reporting.
Peterson 1998^32^ (Good) | NYS CSRS | | 2 | ↔ No evidence of harm: percentage of NY State residents having surgery out of State declined, and elderly people in NY State were more, not less likely to receive bypass surgery.
Pope 2009^91^ (Fair) | America’s Best Hospitals (Ranking in U.S. News and World Report | To estimate the impact of the ranking on hospital patient volume and revenues. | 4 | ↑ Based on modeling, moving up one spot in this ranking is associated with a 0.7% increase in non emergency Medicare patient volume (p<0.05). Analysis using lagged variables confirms that the effect is not realized until sometime after release, suggesting the report provides new information to patients.
Romano 2004^85^ (Good) | CHOP (CA) and CSRS (NY State) | Analyzes CHOP and NYS CSRS data from NY State and CA to determine whether hospitals identified as mortality outliers experienced volume changes after publication of CHOP and NYS CSRS. | 4 | In CA ↔Low mortality and high mortality outliers experienced no significant changes in volume for AMI ↑ Slight increase in volume for low mortality outliers for lumbar diskectomy Strongest effects among white patients and patients with HMO coverage In NY State ↑ Outliers experienced changes in CABG volume but for limited periods low mortality hospitals had increase in volume 1 month post publication high mortality hospitals had decrease in volume 2 months post publication Strongest among Medicare and white patients.
Romano, 2011^37^ (Fair) | California CABG Mortality Reporting Program | Assessed impact of public reporting on hospital market share, hospital mortality, and patient selection for coronary artery bypass graft surgery in hospitals in California that perform CABG surgeries for three different CCMRP releases (2001: N=79 hospitals, 2003: N=70, 2005: N=77) | 1 | ↔ There was no association between the release of the CCMRP reports and risk-adjusted hospital mortality for any of the groups.
Romano, 2011^37^ (Fair) | California CABG Mortality Reporting Program | | 2 | ↔ After release of the CCMRP reports, high-mortality outlier hospitals tended to operate on less sick patients, as reflected by an adjusted reduction in expected mortality of 0.785% in absolute terms or 25% in relative terms (p=0.02). However this was attributable to reduction in risk factors and there was no difference in hospitals overall.
Romano, 2011^37^ (Fair) | California CABG Mortality Reporting Program | | 4 | ↑ Hospitals labeled as low-mortality outliers experienced a statistically significant 8.9% relative increase in mean market share during the 6 months after publication of a report. Nonparticipating hospitals did not suffer a loss of market share.
Rosenthal 1997^40^ (Good) | CHQC | Analyzes changes in hospital mortality rates associated with eight diagnoses (AMI, CHF, obstructive airway disease, gastrointestinal hemorrhage, pneumonia, stroke, CABG, and lower bowel resection) before and after publication of the CHQC in Northeast Ohio hospitals. N=30 Hospitals (N=101,060 consecutive eligible discharges) | 1 | ↔ In 8 medical conditions combined together, there was no significant change in RAMR after public reporting. ↔ No significant change in RAMR after public reporting for 6 of 8 medical conditions. ↑ Public reporting associated with RAMR reductions over time in CHF and pneumonia. ↑ Risk of in-hospital death decreased after public reporting in 5 of 8 medical conditions.
Shabino 2006^47^ (Poor) | Wisconsin CheckPoint | Reports changes in Wisconsin State hospital averages on various quality measures over a two year period since the introduction of public reporting in the State. N=115 December 2004; N=117 September 2006 | 1 | ↑ All measures improved from Dec. 2004 (pre) to Sept. 2006 (post reporting). However some improvements were small (under 5 percentage points--no statistical test done, not listed below) Over 5 percentage point improvement ↑ AMI 1 of 6 ACEI/ARB Left Ventricular Smoking Counseling: 86% vs. 95% ↑ CHF 2 of 4 Smoking Counseling: 64% vs. 86% Discharge instructions: 53% vs. 64% ↑ Pneumonia 2 of 3 Pneumonia vaccine: 47% vs. 73% Smoking counseling: 61% vs. 83%
Tu 2009^116^ (Fair) | AMI and CHF Process Measures for acute care hospital | Evaluates whether public release of cardiac quality data stimulated Ontario hospitals to improve performance on process of care indicators and mortality related to AMI and CHF by randomizing hospitals to receive either delayed feedback or early feedback of quality reports. N=81 hospitals (42 early feedback; 39 delayed) | 1 | ↔ Differences in AMI and CHF composite indicators between early and delayed feedback hospitals were not significant. ↔ Of 8 exploratory sub-group categories, analysis found only 2 (STEMI 30-day mortality and CHF and LV dysfunction 1-year mortality) differences were significant and lower in early feedback hospitals than delayed feedback hospitals.
Vladeck 1988^87^ (Poor) | HCFA mortality report | Analyzes occupancy rates at NY State general acute care hospitals before and after release of HCFA mortality data. Splits hospitals into three groups based on mortality rate outlier status: Higher-than-expected (N=14), As-expected (N=47), and Lower-than-expected (N=9). Total N=70 Hospitals | 4 | ↔ Release of HCFA mortality data did not affect occupancy rates in NY State hospitals in any of the groups.
Wang 2011^83^ (Good) | PA CABG Guide | Examines the impact of CABG public reports on volume trends from 1998–2006 in PA n=114,039 patients n=59 hospitals (varies by year) | 4 | ↔No statistically significant impact of the public report on hospital CABG volume over the study period. One year after being rated a high mortality hospital there was a significant drop in the volume of CABG cases of 15% on average due to a decrease in low severity cases, but the effect does not persist.
Werner 2010^50^ (Good) | CMS Hospital Compare | Examines changes in hospital process performance on composite and individual measures in the first three years of Hospital Compare (2004 vs. 2006) and tests whether changes in process measures correlated to changes in hospital mortality rates, length of stay, and readmission rates. N=3476 acute care, non Federal U.S. hospitals | 1 | ↑ Mean performance score on composite measures for AMI, heart failure and pneumonia all improved from 2004 to 2006. All individual measures also improved. ↑ 10 point improvement on performance scores were significantly related to reductions in mortality, length of stay and readmission rates for AMI, to reductions in readmission rates for heart failure and for length of stay in pneumonia. ↑ Low ranking and low-middle ranking groups at baseline improved the most in all categories between 2004 and 2006. ↑ Based on group rankings at baseline, a ten point change in performance predicted a decrease in AMI and pneumonia mortality in all but the highest performing hospitals. AMI length of stay was also reduced for all but the highest performers. ↓ Based on same group rankings, a ten point increase in hospital performance was associated with longer length of stay for pneumonia.
Wübker 2008^90^ (Fair) | Klinikfuhrer Rhein-Ruhr (Clinic Guide), 74 hospitals in the Rhine-Ruhr | Assessed number of patients and market share before (2003–2005) and after public reporting (2005–2006) in157 German hospitals in two regions, Rhine-Ruhr (study group) and Cologne-Bonn (control group) | 4 | Hospitals voluntarily publishing their quality data measured on the basis of case numbers and market shares are in stronger demand than those not publishing their quality data while competing with the publishing hospitals. The non publishing hospitals in the Rhine-Ruhr region lose relative case numbers and market shares to their publishing competitors. The publication of quality information results in hospitals with below average quality to be selected less often than hospitals with above-average quality

Notes: AHRQ = Agency for Healthcare Research and Quality; AMI = acute myocardial infarction; CA = California; CABG = coronary artery bypass graft surgery; CHF = congestive heart failure; CHQC = Cleveland Health Quality Choice; CMS = Centers for Medicare and Medicaid Services; COPD = chronic obstructive pulmonary disorder; CSRS = Cardiac Surgery Reporting System; ED = emergency department; HCAHPS = Consumer Assessment of Healthcare Providers and Systems Hospital version; HCFA = Health Care Finance Agency; HER = Hospital Effectiveness Report; MD = Maryland; MI = Michigan; NR = not reported; NS = not significant; NY = New York State; PA = Pennsylvania; PCI = percutaneous coronary intervention; RAMR = risk adjusted mortality rates; QI = quality improvement; U.S. = United States; VBAC = vaginal birth after cesarean

###### Key Question 1 Quality of Health Care

The one randomized study was not included in Table 2 as it examined outcomes not included in any other study; Tu et al.116 evaluated the impact of public reporting on composite indicators of quality of care for AMI and CHF that were derived from selected process of care indicators. The study found that improvement was not significantly different in the group randomly assigned to early release of data and the group assigned to public reporting after the collection of followup data. However, in exploratory analyses they found slight declines in 30-day mortality for subgroups of patients in the early reporting group that did not occur in the later reporting group. The conclusion of this randomized study that public reporting has a limited, if any, impact on health outcomes is echoed by the other quantitative studies of cardiac public reports. However, differences in comparisons, time periods, and populations make generalizations difficult.

Thirteen identified studies analyzed the impact of public reporting on mortality.

- Eight of these reported declines in mortality (improvement) although the declines were small or limited to a subgroup of patients in some studies:
  ○ Hannan et al. in two of the earliest studies28,29 found that hospitals with higher mortality rates prior to reporting improved over the 3 years after reporting and Cutler30 also identified a trend toward improvement; Jha31 found that hospitals that performed well at baseline when reports were issued tended to have high performance in future years;
  ○ Peterson et al.32 found that mortality rates for Medicare patients in New York State were declining faster than the rest of the country; and Carey et al.33 found a small decline for four cardiac procedures after reporting in California. Bridgewater34 reported a substantial mortality decline for CABG in Northern England after public reporting and Hannan reported statistically significant larger declines in mortality from 1994 to 1999 in several States with cardiac report cards compared with the rest of the United States.35
- Four studies found no change in mortality.
  ○ These included an assessment that a similar mortality decline occurred in Massachusetts without public reporting as was reported in New York State and Northern New England where CABG mortality rates for hospital were reported.39 Similar declines were seen in Michigan hospitals (no reporting) compared with New York State.36, A study of CABG reporting in California that compared participating and non participating hospitals as well as changes after three releases of the report card also showed similar results.37 A study in Ontario, Canada found a significant drop in mortality after hospitals were given comparative information, but no further drop when the data was made public.38
- Apolito et al.64 compared patients from New York State with patients from the rest of the country that have AMI complicated by cardiogenic shock included in a registry. The mortality rates for patients who received either CABG or percutaneous coronary intervention (PCI) were not significantly different.

###### Key Question 2 Harms

Eight of the identified articles reported on studies that examined harms and four found evidence suggesting that harms were occurring. The harms studied were all variations on the idea that public reporting will lead providers (hospitals and surgeons) to avoid high risk patients (adverse selection) and thereby reduce access to needed services. However, as in the studies of improvement in mortality, these studies were of different population subgroups and often involved comparisons that are not the most rigorous, limiting confidence in the results and making it difficult to draw conclusions across studies.

- Five studies were about the risk of being referred out of State if the patient was high risk.
  ○ One study found that patients treated at the Cleveland Clinic, who were referred from New York State, were at higher risk and had a higher mortality rate than patients from New York State before public reporting as well as patients from other locations.65.
  ○ A study of Medicare beneficiaries in New York State32 and another study of cardiac patients in several States with public reporting35 found that the number of CABG patients having surgery out of State declined, suggesting high risk patients were not being sent out of State. This second study of Medicare beneficiaries32 also looked at access to services and concluded that elderly New Yorkers were more rather than less likely to have surgery.
  ○ A study in England also found that high-risk patients were more likely to have surgery after public reporting.34
  ○ A study in California found that patients treated at high mortality hospitals were less sick after public reporting, but concluded that this was due to a decline in key risk factors and not an unintended consequence of public reporting.37
- Three studies were about reduction of illness severity in States with public reporting compared with the ones without.
  ○ Moscucci36 found that New York State patients were at lower risk of negative outcomes than Michigan patients despite similar rates of heart disease in the two States, and Dranove et al.,66 who compared New York State and Pennsylvania patients before and after public reporting, identified declining illness severity after public reporting.
  ○ Apolito et al.64 reported that New York State patients with myocardial infarction and cardiogenic shock were half as likely to have procedures and waited longer for surgery, but more importantly were 2.5 times more likely to die in the hospital than similar patients in other States. Overall mortality rates were higher in New York State and the author suggested this means patients may not be receiving these interventions in New York State, which is one of the harms that could result from public reporting. While this was a study of a specific subgroup of patients and the number of patients studied was smaller (220 from New York State, 325 from other States) than the other studies, it suggests the potential for harm if public reporting creates incentives to avoid high-risk patients.

###### Key Question 3 Impact on Providers

We did not identify any studies that examined the impact of public reports on hospital cardiac services on provider behaviors.

###### Key Question 4 Impact on Patients or Purchasers

In nine studies of hospitals, market share or volume of discharges was used to indicate the selection of hospitals by patients or their representatives (e.g., referring physicians, health plans, employers, etc.). Market share can be defined differently in different studies, but is usually the number of admission or discharges for one hospital divided by all the admissions or discharges in defined geographic region. One of the primary theories underlying public reporting is the idea that given information about quality that was previously unavailable, consumers (patients) will choose higher quality providers. Therefore the expectation is that with public reporting hospitals with higher ratings will experience increases in market share, while those with lower rating should lose customers and see their market share decline.

The results of five studies support this hypothesis, while three found no difference, and one produced mixed results.

- The five studies that find no effect included an inquiry that found CABG volume across hospitals was stable during the early years of public reporting (1989–1992).28 Other studies also of CABG volume found no change in Pennsylvania following public reports37,82,83 or in New York State.31
- One study with mixed results found no change in California for AMI while finding increases in CABG volume for low mortality hospitals 1 month after release of public reports and decreases in volume for high mortality hospitals after reports in New York State.85
- The three studies that found public reports affected market share often cautioned that the impact was limited.
  ○ Mukamel et al.84 found that reports of increased mortality led to a decrease in market share for hospitals in New York State, but that all of this was accounted for by a decline in Upstate New York, while there was no effect in New York City. Another study identified effects immediately after reporting but that did not persist over time in New York State.30
  ○ The exception is one study of CA CABG reporting documented a statistically significant increase of 8.9 percent in market share in low-mortality hospitals in the 6 months after the publication of the data.37 Analyses by Dranove and Sfekas found that public reports affected market share when they provided new information, but this was not symmetrical in that hospitals with lower than expected rankings experienced a significant decrease in demand but the market share of higher ranking hospitals did not change.86

##### Hospital Public Reporting (Noncardiac)

Twenty-two studies were identified that evaluated public reporting about hospitals for either a wide range of services or for a specific noncardiac service. Like the cardiac public reports, most of these examined how public reporting influences quality of care (Key Question 1) with mortality, the most common measure that was publicly reported, and changes in mortality used to assess the impact of public reporting. Only one study in the group addressed harms and a small subset assessed the effect on providers or patients or the influence of context. These studies are listed and described below.

###### Key Question 1 Quality of Health Care

Fourteen overall studies addressed Key Question 1. There were seven studies that evaluated the effect of regional public reporting efforts on hospital. The most common of these were part of the CHQC program from 1993 to 1998. Five40–44 articles reported the results of research on the impact of CHQC on quality of care, out of which one also looked at the impact on market share (discussed in Key Question 4).

- One of the six studies showed an effect of CHQC on mortality rates.
  ○ In the study published in 1997, Rosenthal et al.40 tracked mortality for eight diagnoses in 30 hospitals during the year prior to data collection for one period in which the data was provided confidentially to the hospitals, and for 2 years after it was public. Risk adjusted in hospital mortality for all eight conditions combined declined from 7.5 percent to 6.5 percent but was not significant (p=0.06), while the separate analyses by condition found declines for CHF (7.1 percent to 5.6 percent) and pneumonia (11.1 percent to 9.9 percent) were significant.
- Four later studies showed little or no significant effect. This was a result of a better understanding of mortality trends in this region and/or more sophisticated analysis measures.
  ○ Clough et al.41 compared the trends in the CHQC hospitals to those in the rest of Ohio and found the same trend of decline in mortality across the State, suggesting it was not result of this program.
  ○ Baker et al.42 used Medicare data to examine mortality in the CHQC hospitals from 1991 and 1997 and determined that while in-hospital mortality declined, mortality in the days following admission increased. The net result was that mortality, in or outside the hospital but within 30 days of admission, did not significantly decline for three of six conditions, declined for CHF and chronic obstructive pulmonary disorder (COPD), and increased for stroke.
  ○ In another study the same researchers used some of the same data but focused on individual market share and also reexamined trends in mortality.43 In this analysis they found that only one hospital, identified as an outlier (with higher than expected mortality), improved and had lower mortality consistently for the rest of the study period.
  ○ One additional study of CHQC took a different approach and looked at whether outcomes for disparate but all publicly reported outcomes (mortality, length of stay, caesarean, and vaginal birth after cesarean [VBAC] delivery rates) improved as a group indicating a systems approach rather than a selective approach to quality improvement.44 Their analyses suggested that hospitals that improve in one area tend to improve in others as well.
- Out of the seven regional quality initiatives with a public reporting component, two studies by Hibbard et al. were about the Alliance, an employer purchasing cooperative in Madison, Wisconsin that produced a report, QualityCounts, that compared 24 hospitals in the region.
  ○ This report was evaluated by comparing the hospitals in the report to the remaining hospitals in the State. The remaining hospitals were further randomly assigned to either confidentially receive the same indicators as the report or not.45 The results indicated that the quality of worse than expected hospitals improved in all groups but were statistically significantly higher in the hospitals that were a part of QualityCounts.
  ○ A later study compared performance across the three groups 2 years after QualityCounts was distributed.10 These analyses focused on two areas where there was variation in performance at baseline, obstetric and cardiac care, although the report covered several other domains. Comparisons of the number of hospitals that improved, as well as analyses that introduced more statistical controls, found a gradient across the groups with the public report group having the highest percentage of hospitals that improved, private reports in the middle, and the no report group having the fewest of hospitals that improved. This was significant for obstetrics and had the same trend in cardiac care though it was not significant.

Four identified studies of public reporting were evaluations of State-level public reporting efforts. State reports have been studied in Missouri, Wisconsin, and Pennsylvania.

- In 1993 the Missouri Department of Health issued a consumer guide to obstetrics services at hospitals in the State. Longo et al.46 evaluated the impact of this guide on clinical outcomes by estimating trends based on years prior to the report and comparing the actual post guide results to estimated value and found significant changes in ultrasound and cesarean rates but no significant change in VBAC rates.
- The Wisconsin Hospital Association’s public report, CheckPoint, was launched in March 2004 and a basic study of its influence cited high levels of compliance with recommended treatment measures at two points after it was made public.47 Small amounts of improvement in care indicators for AMI, CHF, pneumonia, and error prevention occurred in the 2 years after reporting, but these differences were not subjected to any statistical tests or analyses.
- Two studies published a decade apart considered the relationship of the Annual Hospital Effectiveness Report publicly disseminated in Pennsylvania with health care outcomes.
  ○ In 1997 Evans et al. published a study that found that Pennsylvania hospitals improved (decreased mortality and morbidity) but that this was achieved by not reducing length of stay at the rate common during this period, an action that could have financial implications.111
  ○ More than a decade later in 2008, Hollenbeck et al. evaluated the same reporting system by matching patients in Pennsylvania with patients in other parts of the country characterized by intense or limited public reporting using propensity matching.49 Their analyses showed that patients in States or time periods with intense public reporting had significantly reduced odds of inpatient mortality compared with States or time periods with less public reporting. For example, for patients in Pennsylvania subject to intense public reporting in 2002 to 2003 compared with non Pennsylvania patients in States with limited reporting, the odds ratio for hospital mortality across six conditions ranged from 0.59 to 0.79 (all p<0.0001).

Three recent studies reported the results of ongoing national initiatives in public reporting relative to hospitals.

- Two of these three studies were based on public reports in the United States while one was from Korea.
  ○ Hospital Compare was one component of a CMS initiative to disseminate information about the quality of health care services and promote quality improvement. Since 2005 CMS has made hospital performance rating and rankings available on a Web site. Werner and Bradlow50 examined hospital performance in the 3 years following the initiation of Hospital Compare and found significant improvements (p<0.0001) in individual and composite measures for AMI, heart failure, and pneumonia. They also demonstrated that improvement in these measures of process of care were associated with improvements in outcomes for AMI such as declines in mortality rates, length of stay, and readmission. Changes in outcomes for pneumonia and heart failure were smaller or not significant.
  ○ As a complement to clinical indicators and outcomes, CAHPS is an AHRQ project that has developed surveys and measures of patient experience that could be publicly reported. The first survey was developed for health plans, but a hospital version was developed (HCAHPS) and public reporting of results began in March 2008. Elliot et al.51 examined the HCAHPS data from March 2008 and March 2009 and found small, consistent, though not statistically significant improvements in eight of nine domains. The only domain with no improvement was doctor communication, while the largest improvement was in responsiveness of hospital staff (59.9 percent to 60.8 percent giving the most positive responses).
  ○ While most of the general public reporting about hospitals included quality measures on several procedures, a study in Korea focused on hip replacement and documented that the length of stay and readmission rates declined significantly after these outcomes were routinely publicly reported.52

###### Key Question 2 Harms

One of the two studies that addressed potential harms was designed to test concerns that publicly reporting a specific process measure, percentage of patients with pneumonia receiving antibiotics within 4 hours of arrival, would encourage premature diagnoses of pneumonia, overuse of antibiotics, and inappropriate prioritization of patients with respiratory symptoms in emergency departments (EDs). Analyses of data from a nationally representative sample of ED visits for 2001 through 2005 found no evidence of increase in any of these adverse outcomes after public reporting of the measure began in January 2004.^67^

The study of hip surgery in Korea,52 mentioned earlier, included several outcomes including change in cost for high risk procedures and patient selection. The study concluded that none of these potential adverse effects occurred.

###### Key Question 3 Impact on Providers

Three of the four studies, which evaluated Key Question 3, reported improvements in the quality initiatives by providers in hospitals.

- In an evaluation of the 1993 Missouri Department of Health consumer guide for obstetrics services in addition to an examination of trends in outcomes, Longo et al.46 surveyed hospitals about their services and policies and any changes they made in response to the guide. They found that 39 percent of hospitals that did not have obstetrician-related services had added them or were planning to add them and that hospitals varied in whether they reported changing policies in response to the report (from a high of 34 percent reporting changes related to cesarean delivery to 8 percent considering changes in policy related to ultrasound use).
- A study of the CHQC program determined that most participating hospitals both improved their rates on cesarean sections (16 hospitals) and VBAC (15 hospitals). Fifteen hospitals had initiatives designed to address the issues raised by public reporting and score high on an assessment that included organizational leadership and monitoring care.76
- The evaluation of the QualityCounts public report on hospital performance included a survey of hospital executives in the three study groups (public report, confidential report, and no report).10 Respondents were asked about quality improvement activities and responses about priorities and strategies did not differ across the groups. However, the public report hospitals reported more quality improvement activities related to the measure in the QualityCounts report than the confidential or no report hospitals.
- One recent study by Jang et al. tracked the impact of the yearly release of data on the cesarean rates for all hospitals in Korea for 4 years. A significant decrease in cesareans occurred after the first report but then the rate remained at a level still higher than what is considered high quality care despite continued reporting.77

###### Key Question 4 Impact on Patients or Purchasers

Three out of the six studies, which were about Key Question 4, reported results on impact of public reporting on patient choice of hospitals.

- Two of these studies were of the first modern public report, the HCFA hospital mortality report. They both analyzed the impact of this data on choice of hospital and found no evidence of the intended effect.
  ○ In 1988 Vladeck et al.87 reported the earliest results identified in this systematic review. Their research examined trends in occupancy rates for five quarters before and three quarters after the HCFA report release and compared hospitals in New York City identified as having higher than expected death rates to those with lower than expected death rates, and found no significant differences.
  ○ Almost a decade later in 1997, a study analyzed number of hospital discharges for a 9-year period that included years prior to the HCFA report release and all the years in which the report was made public.88 These researchers did find that hospitals experienced a very small decline in discharges after being cited as a higher mortality hospital. Their estimate of the size of the effect was that a hospital with double the expected mortality would have 46 fewer discharges a year as a result of the public release of the mortality information.
- One study of public reporting and patient choice sought to determine if five reports issued over a 2-year period influenced patient choices of hospitals for their kidney transplants.89 The study included patients receiving living and deceased donor kidneys. The authors reported that most major cities now have at least two transplant centers and patients chose after diagnosis in consultation with their nephrologist, although the choice may be constrained by insurers. Analyses of hospital choice as a function of outcome reports found no effect overall but some effect among younger patients (age 18 to 40) and patients with college degrees.

Three studies examined the impact of different public reports on patient volume and market share.

- A study in Germany evaluated the difference in market share between voluntarily reporting hospitals and the ones that did not. The hospitals that did not report their outcomes were losing market share to the ones that voluntarily reported them. It was noticed that hospitals with lower ratings lost market share to the higher rated hospitals.90
- Pope 2009^91^ modeled the impact of the U.S. News “America’s Best Hospitals” report and found that improvements in ranking lead to significant increases in the numbers of non emergency patients.
- One of the six studies about CHQC (the other four are described in Key Question 1 as they focus on mortality) examined discharges for six medical conditions as an indication of market share. The five worst hospitals (highest mortality) tended to lose market share but this was not significant and there was no relationship between when a hospital was identified as an outlier and subsequent market share.43

###### Key Question 6 Context

Two studies considered characteristics of the hospital’s market in addition to other outcomes. Longo et al.46 in their study of the impact of an obstetrics public report in Missouri, found that hospitals in communities with multiple facilities were more likely to change their policies related to measures included in the report than hospitals that were the single facility in a community.

In a study of Pennsylvania hospital response to the Annual Hospital Effectiveness Report, Evans et al.111 found that improvements in mortality were more likely in hospitals in competitive markets and less likely in hospitals reporting they were in worse financial condition.

#### Qualitative Studies

##### Description of Qualitative Studies

We identified 43 qualitative studies and lab-type experiments that focused on public reporting about hospitals and corresponded to at least one of this review’s Key Questions. The studies were published between 1989 and 2010. Eighteen were conducted in countries other than the United States including five in Canada,118–122 four in England,123–126 three in The Netherlands,127–129 two in South Korea,130,131 and one each in Scotland,132 Germany,133 France,134 and Iran.135

Most of these studies were surveys or interviews. Twenty-four were surveys, including 12 surveys of medical care providers and administrators (hereafter “professionals”),121,122,136–145 11 surveys of patients/consumers,128–131,134,146–151 and one study that combined surveys of professionals and patients.135 Ten studies were based on interviews. One used patient interviews,152 one interviewed patients and professionals,133 and eight interviewed professionals120,124,126,153–157 including one that presented a series of case studies based on interviews and observations.155

Four studies reported the content of focus group discussions, including three with patients123,125,158 and one with professionals.118 Three studies combined focus group methods and interviews, two of which were with patients119,127 and one included both patients and professionals.132 Two studies were lab-type experiments in which participants were asked to evaluate materials, take tests, or complete decision exercises.159,160

##### Summary of Qualitative Studies

Qualitative studies of public reporting about hospitals tend to focus on certain topics across different time periods and populations. These are: (a) awareness, attitudes, and self-reported intention to use reports in the future; (b) importance or relevance of specific topics or measures to people using the public report; (c) reactions to format including comprehension; and (d) decision processes used to evaluate and ultimately select hospitals. It might be expected that these would change over time as public reporting became more common and evolved. Given the relatively large number of interview and survey studies identified by our search, we arranged the description of the studies by year of publication (included in parentheses below) both to impose an organizational framework and to allow an assessment of whether by looking across studies it is possible to determine how attitudes and use are changing since public reporting is no longer a new phenomenon.

###### Interviews and Descriptive Surveys

Professionals. Ten survey and interview studies of professionals assessed their awareness of or attitudes toward actual or planned public reports. These studies did not directly examine action by providers (Key Question 3), but as awareness and acceptance of reports is a precursor to action, we briefly summarize these studies here.

- A survey of executives selected to represent hospitals with different levels of mortality in the HCFA mortality report found the report was viewed very negatively regardless of the hospital’s rating and that there was significant resistance to public reporting (1990).142
- Cardiac surgeons and cardiologists were aware of the Pennsylvania cardiac report. Sixty-three percent of surgeons said they were less willing to operate and 59 percent of cardiologists said it was somewhat more difficult to find a surgeon for their patients due to the report (1996).141
- A survey of New York State cardiologists during the initial years of the NYS CSRS found that 93 percent had reservations about the accuracy of the data and 62 percent said it had not affected their choices at all when referring patients for surgery (1997).139
- Thirty-nine hospital administrators were surveyed and three quarters reported finding some aspect of the CHOP public report useful and most stated that they disseminated it in their hospital [exact percentages not reported] (1998).156
- New York State and California hospital administrators reported distributing State public reports and preferring those to the HCFA reports. Administrators at hospitals rated as “high mortality” in any public report remained critical of the public reports (1999).138
- In response to a survey, Canadian cardiac surgeons endorsed the idea of publicly reporting mortality but also said they did not believe it influenced patients and reported no instances of patients asking about the rankings (2003).121
- Thirty-five percent of stroke and cardiac care managers surveyed in Ontario, Canada were not aware of the existing public report (2003).122
- Interviews with professional stakeholders in Canada about cardiac public reports found that public reporting was supported in principle but there was concern about the accuracy and the public’s ability understand the data (2004).120
- Administrators (n=61) at six sites in England answered they did not feel the “star ratings” were relevant and although they provided a basis for benchmarking local performance they were more concerned about dysfunctional responses such exclusive focus on what is measured and pressure to make targets (2005).126
- Guru et al. surveyed cardiac surgeons in Ontario, Canada and compared their results to previously published surveys of cardiologists and cardiac surgeons in Pennsylvania. The Ontario results were generally favorable: 51 percent supported hospital reporting, 26 percent supported surgeon-specific reporting, 84 percent believed it affected referrals, and 80 percent believed it affected patient choice. In contrast, the Pennsylvania results were negative (e.g. only 13 percent believed the public report affected referrals) (2009).145

Ten studies focused on whether the information in public reports was used to inform practice and quality improvement. These studies correspond to Key Question 3 in that they assess changes in practice in response to public reporting.

- Seventeen public hospitals in California reported minimal use of the HCFA and CHOP report in a study published in 1996.^140^
- Survey responses of hospitals in Pennsylvania and New Jersey (a State without public reporting) were compared and hospitals in Pennsylvania reported using performance information more frequently but the differences were not consistent across questions and public reporting was not well defined (1998).143
- Interviews and observations were used for case studies that characterized the responses of four hospitals to CHQC. All created interdisciplinary work groups to review practice and develop practice change in response to the public report (1998).155
- Chassin et al. found in interviews with key administrators and physicians at four hospitals identified as outliers (high mortality) that these hospitals took targeted actions and created quality improvement (QI) programs to address the underlying issues (2002).137
- Two similar studies conducted in the same program but at different times reported somewhat different results.
  ○ Interviews reported by Mehrotra et al. with hospital executives and public report producers in 11 U.S. communities concluded most public reports were not successful in that they did not prompt or increase QI (2003).154
  ○ Three years later, Pham et al. published the results of 111 interviews of hospital and association executives as well as public report producers in 12 U.S. cities in the same program and found: (1) hospitals participated in multiple reporting programs, and (2) although they did not believe these influenced patient choice, they believed they had led to improved quality by making physicians more open to performance measurement (2006).157
- A national stratified random sample of QI directors (n=664) and senior executives (n=650) at short-term acute care general and critical access hospitals that submitted data for Hospital Compare during 2005 were surveyed to identify the barriers hospitals face in making quality improvements. The major barriers identified among hospitals with more than one measure that scored below the 50 percent benchmark were: (1) inaccurate documentation and missing data, (2) failure to involve physicians, (3) financial challenges, and (4) lack of QI staff. Ninety-five percent of the QI directors reported that their hospitals implemented new or enhanced QI programs in response to public reporting (2006).144
- Interviews with hospital administrators in Rhode Island revealed that QI initiatives were started in response to a Statewide public report (no interviews with hospitals not subject to public reporting) in areas that both directly corresponded to reported measure as well as in other areas of clinical care and customer service (2006).153
- The majority of 800 hospital executives surveyed in the United States answered that public reports lead to incorporation of QI in strategic planning (93.6 percent) and attention to quality by more staff (96.5 percent) (2007).136
- Interviews with 24 National Health Service employees in England responsible for patient surveys at hospitals found that the survey results were generally well-received but were not informative for QI because they reported on the whole hospital and not on smaller units where changes could be implemented (2008).124

Patients. One interview study and 11 surveys collected similar information on awareness of public reports and their impact on the decisions among patients or their representatives.

- A survey of 186 military health plan members and 200 non military respondents in New York State reported they would use government mortality data to judge hospital quality (yes: 67 percent military; 59 percent non military), but a smaller percent responded that they were very likely to use this information in selecting a hospital for surgery (34 percent and 30 percent) when asked this in a separate question (1989).149
- A survey of patients who had CABG surgery in the previous year (n=474) revealed that only 20 percent were aware of the Pennsylvania Consumers Guide at the time of their surgery and only 4 percent had seen the report. Twenty-eight percent were not interested in the report and the major reason was that distance was an important factor in choice (1998).148
- Outpatients at University of Missouri Medical Center (n=935) were provided a hospital public report and completed a questionnaire indicating that most people found it an effective way to compare providers (59.9 percent), but very few were likely to change providers based on the information (2003).146
- Randomly selected Medicare beneficiaries who had selected surgical procedures (n=510; 68 percent response rate) reported that decisions about where to have the surgery were largely influenced by doctors and family and only a few (11 percent) attempted to find comparative hospital information before their surgery. Forty-seven percent said they would use a list of best hospitals if this type of information was available in the future (2005).151
- Patients and physicians in Germany were asked to rank indicators currently included in a nationally mandated public report on hospitals as well and measures common in other hospital reports. The two groups agreed on the top 10, though the exact order differed. Both groups rated several indicators that reported on hospital structural characteristics such as ownership as unimportant to their decisions, which suggests they could be dropped in order to shorten the report (2007).133
- Patients who had one of six selected procedures at three hospitals in The Netherlands were asked how they chose the hospital and what information they would use to choose if they needed similar care in the future. Hospital reputation was the primary reason for the past choice and previous experience was the most cited source of information for future choices (25.3 percent), while quality information was rarely cited as important (2008).129
- Women in South Korea age 20 to 49 were surveyed by phone (n=505; 57.3 percent completed of 882 eligible after random sampling) to determine if they were aware of the public reporting of cesarean section rates for Korean hospitals. Two-hundred twenty eight reported being aware of the report, and younger women and those with higher levels of education were more likely to know about the report (2008).131
- Masor et al. showed 59 people a public report on health care acquired infection rates for hospitals and in interviews discovered that most people were not aware the hospital acquired infections (HAIs) existed. While the respondents were distressed to learn about them, they were unlikely to choose a hospital based on this alone (2009).152
- Based on responses to a mail survey (n=201; 25 percent return rate), Masor et al. evaluated formats for a public report on HAIs and found reports were generally easy to understand with the exception of the section that explained risk adjustment and confidence intervals; however HAI rate was not cited as likely to influence choice of hospital (2009).150
- Researchers surveyed a total 381 people including inpatients, recently discharged patients, and visitors to a hospital in France about the their knowledge about infection control and whether a report like the French mandatory report on infection control activity would influence hospital choice. Seventy-seven percent stated they were interested in the report and it was ranked as the 6^th^ most important reason to choose a hospital, but most people would seek advice about admission from their physician rather than refuse admission based on this report (2009).134
- Over 50 percent of outpatients surveyed at four general hospitals in South Korea (n=385) said they would use the hospital performance information from the National Health Evaluation Program but the average respondent rating of understanding the indicators was 3.15 (3=fair) (2009).130
- A survey of 104 patients or family members and 104 physicians in Iran verified that few people (7.7 percent of patients and 11.7 percent of physicians) were aware of the grading system and public report that exists for Iranian hospitals, that patients relied on suggestions from relatives, and that physicians considered their patient’s economic situation first when referring patients (2010).135
- Three hundred thirty-seven patients undergoing surgery for the first time at three Dutch hospitals were surveyed regarding their use of public information to select their hospital. Patients were divided between those who had compared hospitals prior to their surgery (21 percent) and those who did not (79 percent). Most respondents indicated they chose their hospital deliberately, but the major factors in their decisions were previous experiences with the hospital and their acquaintances’ previous experience; comparative information was the lowest ranked of four choices in this regard. Patients were also asked to choose factors important in future selections; public information of physician experience was most important, but other aspects, such as wait time and physician communication, had higher relative importance than other aspects included in public reports such as quality of nursing care (2011).128

One study examined the use of hospital public reports by health plans for contracting decisions. It is included here as health plans are acting as representatives of patients in selecting the plans they offer.

- Health plan executives were surveyed and asked to rate the importance of factors that impact their contracting with hospitals. The top three factors were accreditation, location, and price while the average rating of the quality of care indicators ranged from 3.03 to 3.67 (where 5 is very important). Thirty-three percent reported conducting their own studies of comparative hospital quality (2003).147

###### Focus Groups

Seven studies reported feedback obtained through either focus groups or a combination of focus groups and interviews. Two of these involved physicians and administrators while five focused on former or prospective patients.

- Professionals
  ○ Focus groups and interviews with hospital administrators, physicians, and health councils in Scotland found that public reporting of clinical indicators had raised awareness of issues but that reports were not disseminated within hospitals; that while over three-quarters of physicians knew about the reports, they could not recall seeing the most recent report and relied on other sources to assess hospitals; and that health councils had received no inquires about the hospital reports.132
  ○ Another focus group study exclusively involved physicians and had them rate a long list or indicators for AMI (47 indicators) and CHF (34 indicators).118 More than half of the indicators were considered acceptable for public dissemination, and of the rest all but three were rated as reasonable but requiring caution in interpretation. The three were considered unacceptable because they differed too much based on the needs of patients.
- Patients
  ○ Focus groups of the general public were usually with people who had been in the hospital.
  ○ Cardiac patients (n=91) in seven Canadian cities participated in focus group discussions about hospital public reports on cardiac procedures.119 Participants agreed with the idea of public reporting but wanted reports that emphasized patient experience by including feedback from other cardiac patients, patient involvement in care, and communication as well as waiting times.
  ○ Moser et al. used two focus groups and interviews to ask 18 people in The Netherlands who had had total knee or hip replacement within five years what information they would use to choose a hospital if they needed a similar procedure in the future. A hospital public report was viewed as supplementary information that increased awareness of quality but that had to be interpreted in the context of personal, prior experience. The public report was viewed as too general and did not contain enough information that the participants considered important for it to play a larger role in the choice of a hospital.127
  ○ Six focus groups of people with recent inpatient experience in England were conducted by Magee et al. just before the public release of National Health Services quality information.125 One group was composed of family caregivers and another of ethnic minorities; however all the groups expressed suspicion of government ratings, did not like the idea of shopping around for health care, and preferred the format of a commercially produced report that had been publicly available.
  ○ Sofaer et al. used 16 focus groups that included people with similar health care coverage and hospital experience in the same group. In these groups first a general discussion of personal experience and then a review of a CAHPS report were used to identify important domains. Communication, responsiveness (e.g. responding to call buttons), and cleanliness were important to all participants regardless of background and the authors reported that participants viewed hospitals as responsible for the quality of services, in contrast with the author’s prior experience with health plans, which were not held accountable.158
  ○ One focus group study took advantage of this method to explore the decisionmaking process. Fasolo et al. conducted seven focus groups with 44 people in England. An open discussion of how a hospital would be selected for future care was followed by an exercise that involved sorting 16 indicators in order of importance and selecting the top three, and then selecting a hospital from among three on a mock public report. Each of these steps involved individual rankings followed by group discussion. They found that preferences for different indicators were influenced by new information and discussion, suggesting that values are not set.123

###### Lab-Type Experiments

The two articles about lab-type experiments both examined the interrelationships among end-user skills, motivation, comprehension, and choice based on tests and questionnaires completed by the same 303 working age (18–64) adults.159,160 The participants were randomly assigned to receive different versions of actual and reformatted public reports and were asked complete comprehension questions and decision exercises, as well as measures of health literacy, numeracy, and patient activation, which was defined as taking an active role in managing one’s own health and health care.

- The analysis presented in Peters et al.160 concluded that formatting that reduces cognitive burden (ordered information, higher always better, and separation of types of information) increased the likelihood of choosing the higher-quality hospital and improved comprehension for people with lower levels of numeracy.
- Hibbard et al.159 controlled for the variation in formatting, evaluated the impact of skills and activation on choices, and found that higher levels of activation had improved comprehension even with lower skill (numeracy and health literacy) levels, and higher activation increased willingness to trade other hospital characteristics for higher quality.

### Individual Clinicians and Outpatient Clinics

This section reports on the identified studies of public reporting on individual clinicians and outpatient clinics. Outpatient clinics are practices included here primarily because only one study of fertility clinics was identified,93 which was not enough information for a separate section. Fewer studies are available of public reporting about the quality of individual clinicians than about hospitals, health plans and long-term care. In part this is because public reporting of performance data at the individual level is controversial. The issues stem from both measurement concerns and different conceptualizations of health care, quality, and accountability. Accuracy of measurement and adequate risk adjustment are more difficult to obtain with the smaller number of cases available for individual clinicians as opposed to health plans, hospitals, or nursing homes that treat from hundreds to hundreds of thousands of patients per year. Approaches to health care that are anchored in teams and systems responses to assure safety are contrary to the idea that any one individual is solely responsible for outcomes, and individual providers resist public reporting about processes and outcomes they view as outside the scope of their control.

Studies of reporting on individual clinicians are dominated by those of the impact of the public reporting of mortality rates for cardiac surgeons in New York State. These data were collected to produce hospital public reports, but individual results were added to the NYS CSRS after a newspaper, Newsday, won a freedom of information lawsuit and obtained the individual data. Health plans, employers, and private entities have created public reports about individual physicians as well as medical groups, but these are less consistently available across the country and less studied. This may change in the near future as CMS adds individual physician performance data to its nationwide public reporting initiative and “Physician Compare” joins Medicare health plans, hospitals, nursing homes, home health care agencies, and dialysis facility versions of “Medicare Compare” now available via the CMS Web site.

We identified 12 quantitative and 20 qualitative studies that evaluated public reporting and addressed at least one of this review’s Key Questions.

#### Overview of Findings

##### Quality of Care (Key Question 1)

- Surgeon-specific mortality rates for CABG in New York State declined after rates were publicly reported (one study).28

##### Harms (Key Question 2)

- Evidence about harms varied by the harm studied (three studies) with one finding that public reporting adversely affected access while two reporting that the expected negative impact on access was not supported by the data.
- Evidence of harm
  ○ Public reporting appeared to increase disparities between whites and blacks or Hispanics in the receipt of CABG for 9 years after public reporting began.68
- No evidence of harm
  ○ High-risk patients were more likely to have high-quality surgeons, which is counter to the hypothesis that public reporting might cause adverse selection.69
  ○ Few physicians reported leaving practice due to the impact of the public reports.31

##### Impact on Providers (Key Question 3)

- Surgeons who stopped performing CABG surgeries after surgeon-level data were made public were more likely to be poor performers (bottom quartile) (one study).31

##### Impact on Patients or Purchasers (Key Question 4)

- Results varied across studies (seven studies).
  ○ Three studies reported no effect of reporting on referral patterns, market share, or surgeon volume.28,31,92
  ○ Three studies reported that market share or probability of selection increased for higher-quality clinicians or clinics after the data were publicly reported.84,93,94
  ○ One study found that public reports led to decreases in volume for poor performing and unrated surgeons, but that there was no corresponding increase for high performing surgeons.83

##### Public Report Characteristics (Key Question 5)

- Difference report characteristics were examined in two studies that identified variation in what makes reports useful and useable for patients.
  ○ The mode (email vs. mail) and the tone of messages used to inform patients about the availability of physician performance data affected whether patients accessed it or not (one study).110
  ○ Publicly reported data was still accurate and therefore likely to be useful to patients even when there was a substantial delay between data collection and when it was made available to the public (one study).31

##### Context (Key Question 6)

- Employment status/tenure, which the researchers suggested served as a proxy for age, affected the likelihood that people would access comparative information about physicians (one study).110
- The impact of public reports was affected by insurance coverage—when care was covered the public reports were more likely to influence selection of health care provider (in this a case fertility clinics) (one study).93

#### Description of Quantitative Studies

We identified 12 quantitative studies about public reporting on individual providers. The studies were published between 1994 and 2011 and all were conducted in the United States. Ten of the 12 evaluated the impact of public reports about cardiac surgeons.28,31,68,69,83,84,92,94,161,162 The two studies about other services included ratings of fertility clinics93 and individual physicians.110 Four of the studies about the impact of cardiac surgeon public reports also included outcomes at the hospital level.28,31,83,84 In these cases, the results have been separated and the hospital results are reported in the previous section while the results pertaining to individual clinicians are reported here.

The populations in most of the studies were patients, families, or payers who needed to select a health care provider. These included employees with health coverage, selecting physicians,110 and prospective patients selecting a fertility clinic93 in the two noncardiac studies.

In the studies of the cardiac surgeons, the populations were the patients and/or referring physicians that selected surgeons for CABG.83,84,92,94 In two studies, the focus was on whether public reports influenced the contracting decisions of Managed Care Organizations (MCOs),161,162 which function as patient representatives when they make contracting decisions which determine what surgeons are available to members. In one study with multiple analyses,31 patients and surgeons were the populations of interest for different hypotheses. In the case of studies that evaluated improvement in quality of care28 or potential harms,68,69 the population was the cardiac surgeons who may change their practice in response to public reports.

The interventions were public reports of mortality data for cardiac surgeons in 10 of the 12 studies. Eight of the studies were about the NYS CSRS28,31,68,69,84,94,161,162 and two were about the Pennsylvania cardiac report, the Pennsylvania’s Guide to Coronary Artery Bypass Graft Surgery.83,92

The two studies not about cardiac surgeons included one study in which employees were referred to a Web site (Bridges to Excellence) maintained by a nonprofit organization that provided performance data about individual physicians.110 The other noncardiac public report was a Federally mandated report on success rates for assisted reproductive therapy (ART) provided by fertility clinics that is published by the Centers for Disease Control and Prevention.93

As public reporting is about individual providers and is not pervasive, the comparator for studies of State reports on cardiac surgeons could be other States that did not produce these public reports. In one of two multi-group pretest post test studies, referral patterns to cardiac surgeons in Pennsylvania where there was public reporting were compared to those in Florida (no public reporting) for a time periods before and after reporting started in Pennsylvania.92 The other study of this type estimated the differences in use of several cardiac procedures by race for patients in New York State before and after public reporting and compared this to patients in other States without public reporting for the same periods of time.68

However, most studies did not incorporate a comparison group that did not experience public reporting, rather they examined one group with public reporting and the difference in study designs were variations in the time periods included. Two studies used multiple years of data from the NYS CSRS and Medicare and were “time series post only” designs,31,84 in that they looked at trends in data after public reporting. Another included data that predates the public report and multiple periods after, making it a one group interrupted time series.28 Four studies were “one group post only,” including one study of patient volume and the Pennsylvania public report,83 an assessment of a potential harm associated with New York State reporting,69 and two studies of managed care organization contracting practices,161,162 all including only one data point after public reporting. Two studies were one group pretest-posttest designs with one data point before and after public reporting. The research about fertility clinics examined market share before and after public reporting, a one-group pretest-posttest study design.93 The other study with this design was a study of the choice of cardiac surgeons.94

The study of employee use of a Web site with physician performance data employed a randomized design. Employees were randomly assigned to receive information about physician ratings that differed in terms of form (email vs. mail) and tone (benefit vs. risk).110

See Appendix D for definitions of the study design terminology used in this report. The study design influenced the rating of the body of evidence but did not determine the quality assessment of individual studies. Confounding and similarity across compared groups or compared time periods were given more weight than other criteria (see Appendix G for the quality assessment for these studies and Appendix F for a description of the quality assessment criteria) when assessing the quality of the individual studies. Of these 12 studies, six were assessed as good and six as fair.

The outcomes in the studies varied. The one study that assessed improvement in health care outcomes (Key Question 1) tracked risk adjusted mortality rates for surgeons as the outcome.28 One study of potential harms (Key Question 2) estimated the likelihood that higher-risk patients have higher-quality surgeons for CABG.69 The other study of harms compared percentages of patients undergoing the procedures by race across the time periods and States after adjusting for patient characteristics.68 Another study31 examined patterns of surgeons discontinuing practice and their reasons for doing so as outcomes.

The most common outcome in these studies was selection of providers. In five studies the outcome was the selection of providers by patients (Key Question 4) which is defined as the probability of selection94 or measured through market share31,84,93 or patient volume.28,83 One study took a slightly different approach and modeled the patient and referring physician possible surgeon choices defined by the regional market or surgeon affiliation with the hospital of admission.92 In two studies the outcome was selection of surgeons by MCOs for contracting161,162 and one of these162 also included interview responses by MCO executives to questions about the factors that influence their choices of surgeons when establishing contracts.

Two studies have outcomes that were not used in any other studies. In one study the outcome was an action that precedes the selection of the provider, in this case the use of a Web site with the physician ratings.110 Another study analyzed the relationship of surgeon quality at the time the data was collected to surgeon quality at the time it was made public (1 to 2 year delay). The ability of the earlier performance to predict future performance was used to determine if the data were likely to be valid in the time period they were most likely to be used by patients.31 This result is relevant to Key Question 5, as how old or current the report data are is a characteristic of the report (Key Question 5).31

#### Effectiveness by Outcome/Key Question: Detailed Analysis of Quantitative Studies

Table 4 at the end of this section provides an overview of each included quantitative study and a summary of the findings organized by the Key Question they address. The complete abstracted data for each study is in the Evidence Table in Appendix J.

Table 4 Summary of evidence: quality of individual clinicians and outpatient clinics

Key Question 1: Does public reporting result in improvements in the quality of health care (including improvements in health care delivery structures, processes, or patient outcomes)?

Key Question 2: What harms result from public reporting?

Key Question 3: Does public reporting lead to change in health care delivery structures or processes?

Key Question 4: Does public reporting lead to change in the behavior of patients, their representatives, or organizations that purchase care?

Key Question 5: What characteristics of public reporting increase its impact on quality of care?

Key Question 6: What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care?

Author Year (QA) | Public Report | Study Overview | Key Question | Results (↑Improvement; ↓Worse; ↔No Difference)
Outpatient Clinic
Bundorf 2009^93^ (Good) | Federally Mandated Report on success rates for fertility clinics maintain by the CDC. | Examines the effect of public reports on choice of fertility clinics before (1996–98) and after (1998–2003) public release. N=411 fertility clinics. | 4 | ↑The differential effect of birth rates post vs. pre public reports is positive and statistically significant, indicating that measured performance had larger, positive effect on choice when the information was publicly disseminated to consumers.
Bundorf 2009^93^ (Good) | Federally Mandated Report on success rates for fertility clinics maintain by the CDC. | Examines the effect of public reports on choice of fertility clinics before (1996–98) and after (1998–2003) public release. N=411 fertility clinics. | 6 | ↑The impact of public reporting was greater in States that mandate insurance coverage for ART than in States that do not.
Individual Clinicians
Epstein 2010^92^ (Fair) | PA Cardiac | Examines the effect of public report on referral patterns to Cardiac surgeons in PA vs. FL before (2001–2002) and after (2002–2003) publication of the CABG public report in PA. n=23655 for PA and 38164 for FL | 4 | ↔There was a marginal difference in the probability of selection of lower mortality surgeons in PA vs. FL in pre vs. post public reporting in the direction expected, but it was not significant.
Glance 2008^69^ (Fair) | NYS CABG Surgery Reporting System | Investigates the potential negative effect of public reports on access for high-risk patients vs. low-risk patients between 1997 and 1999 in NYS. n=51750 CABG surgery discharges | 2 | ↑For every 10% increase in patient risk of mortality, the surgeon’s Observed to Expected mortality ratio (predictor of quality) is significantly reduced by 0.034 points. ↑After adjusting for race and other hospital characteristics, this relationship is weakened by still significant. No evidence that high quality surgeons are avoiding high-risk patients.
Hannan 1994^28^ (Good) | NYS CSRS | Examines the outcomes and volume of CABG patients before (1989–1990) and after (1991–1992) public report among providers in NYS. N=32 providers in lower tercile, 32 in middle tercile, and 31 in lower tercile | 1 | ↑All tercile groups experienced reductions in their RAMR, with the highest RAMR in 1989 being reduced from 5.90 to 3.26 in 1992. ↓Among outliers, only those who were the lowest outliers in 1989 (with an RAMR of 0.74) experienced a RAMR rise in 1992 (1.09). ↑The largest reduction in RAMR was among the high mortality outlying surgeons with 7.06% decrease between 1989–1990 and 1992.
Hannan 1994^28^ (Good) | NYS CSRS | | 4 | ↔ No effect on surgeon volume
Jha 2006^31^ (Good) | NYS CSRS | Examines the effect of public reports on whether surgeons continue to practice and market share post release of the public report Includes all cardiac surgeons practicing in NYS from 1989 to 2000 (years data was collected; 1989 data was reported in 1991). | 2 | ↔ 2 of 18 surgeons surveyed (of 31 surgeons who discontinued practice during the study period) reported they left due to pressure to reject high-risk patients; however 10 of the 18 who responded to a survey said the CABG report had no influence on their decision to leave practice; 2 said minimal impact; and 6 moderate or more.
Jha 2006^31^ (Good) | NYS CSRS | | 3 | ↑ 20% of bottom-quartile surgeons stopped performing CABG during the study period compared to 5% in the top three quartiles.
Jha 2006^31^ (Good) | NYS CSRS | | 4 | ↔ Performance had no significant impact on market share for surgeons.
Jha 2006^31^ (Good) | NYS CSRS | | 5 | ↑Surgeons that have low RAMR when data are collected continue to perform well when data are released 2–3 years later. This suggests data are still useful despite the delay from data collection to public reporting.
Mukamel 1998^84^ (Fair) | New York State CSRS | Hypothesizes that high-quality surgeons experience increase in market share and price in NYS for 1990, 1991, and 1992 due to public reporting. n=74 surgeons with quality reporting and Medicare claims in study years | 4 | ↓The decline in market share growth rates for individual physicians due to an increase of 1 percentage point in mortality rate was 7 percentage points. For the median surgeon with 60 surgeries this would be a loss of 4.2 patients. ↔There was no significant effect of published RAMR on price changes although this was expected (higher quality physicians raise prices).
Mukamel 2000^162^ (Fair) | NYS CSRS | Determines the effect of surgeons’ quality report on HMO, PPO, or IPA contracting in NYS by examining what they say and what they do in terms of using quality data in contracting with surgeons. N=31 of 53 (59% response rate) of MCOs in NYS completed interviews Data from 42 of 53 (78%) on contracting with surgeons | 4 | What MCOs say about contracting with surgeons: ↑60% say quality is the most important consideration ↑64% have examined the NYS CSRS What MCOs do in contracting: ↑Prefer high volume and high-quality outlier surgeons ↓Do not choose based on low-quality outliers or RAMR ↔No systematic bias for either higher or lower quality surgeons
Mukamel 2002^161^ (Fair) | NYS CSRS | Evaluates the association between contracted by MCOs and the quality of surgeons n=42 of 53 MCOs in NYS (78%) 1,709 potential combinations of MCOs and surgeons (1,588 after dropping MCOs that contract with all surgeons) | 4 | ↑Low volume status significantly decreases the probability of contracts (−35.3% upstate and −13.6% downstate; p=0.00) ↑High-quality outlier status results in a significantly higher probability of a contract but only in downstate NY (27.1%; p=0.00) ↑ One standard deviation increase in excess RAMR results in a significant decrease in probability of a contract in Downstate, but not Upstate NY (−6.1% to −9.1% for different types of MCOs)
Mukamel 2004^94^ (Good) | NYS CSRS | Evaluates the effect of public reports on cardiac surgeons by comparing selection before (1991) and after (1992) public release in NYS. N=13,078 Medicare Fee for Service enrollees over 65 in NYS | 4 | ↑Higher RAMR (i.e. lower quality) significantly lowers the surgeon’s odds of being selected by about 7 to 8 percent. ↑Public report information increases the probability Black patients will select a high quality surgeon and reduced the magnitude of the difference between Whites and Blacks. ↑The impact of price and surgeon’s years of experience decline once the public reports are available. ↔Public report information does not appear to change referring physicians’ propensity to refer to surgeons at the same hospital where they admit.
Ranganathan 2009^110^ (Fair) | Bridges to Excellence (created by a nonprofit; provides physician-level performance data) | Evaluates the effect of the mode (internet vs. mail) and the tone of the invitation to view a public report on physician performance on its usage and understanding in active and retired employees of GE, MA. N=3000 for mail, 2111 for email and 1500 retired (mail) | 5 | Website received 789 hits (11.9% hit rate) ↑Odds of registration was 6.42 times higher in email vs mail for active employees p<0.001 ↔There was a slight increase of odds of response to positive tone vs negative tone messages but it was not significant.
Ranganathan 2009^110^ (Fair) | Bridges to Excellence (created by a nonprofit; provides physician-level performance data) | | 6 | ↑Retired employees had 63% higher odds of registration than active employees p<0.001.
Wang 2011^83^ (Good) | PA Cardiac | Examines the impact of CABG public reports on volume trends from 1998–2006 in PA n=114,039 | 4 | ↑Public reporting led to significant decrease in volume poor (4.762 percentage points) performing surgeons. ↑The volume of the high performing surgeons increases significantly for low-severity cases ↔The volume of the high performing surgeons does not increase significantly for high-severity cases. ↔The volume of unrated cases shows an increase of 21.9 percentage points but it is not statistically significant.
Werner 2005^68^ (Good) | New York CABG | Examines the effect of public reports on racial disparities in receipt of CABG surgery before (1988–1991) and after (1992–1995) public reporting. n=310,412 NYS patients and 618,139 patients in other States | 2 | ↓The disparity in CABG surgery between white and black patients in NYS is 2.0 percentage points higher than other States (p=0.006) ↓The disparity in CABG surgery between White and Hispanic patients in NYS is 3.4 percentage points higher than other States (p=0.01) ↔The difference between White and Black and/or Hispanics in percentage of patients with AMI undergoing cardiac catheterization and PTCA in NYS is 0.4 percentage points lower than other States, but the results are not statistically significant. ↓These results suggest public reporting contributes to worsening of racial disparities in care.

Notes: AMI = acute myocardial infarction; ART = assisted reproductive therapy; CABG = coronary artery bypass graft; CDC = Centers for Disease Control; CSRS = Cardiac Surgery Reporting System; FL = Florida; HMO = Health Maintenance Organization; MCO = managed care organization; PA = Pennsylvania; PPO = preferred provider organization; PTCA = percutaneous transluminal coronary angioplasty; RAMR = risk-adjusted mortality rates; NYS = New York State

##### Key Question 1 Quality of Health Care

Only one study of those identified addressed the impact of public reporting about individual providers on quality of care. Hannan et al. tracked risk adjusted mortality rates (RAMR) for surgeons and found that mortality declined after the NYS CSRS was made public. The RAMR declined 7.06 percent for high-mortality outliers but reductions were seen across all terciles defined by baseline mortality rates.28

##### Key Question 2 Harms

Public reporting about individual providers was, and remains, controversial in part due to concerns that it may have unintended adverse effects, particularly that it may reduce access to care. Three studies addressed the potential for a negative impact on access differently.

Werner et al.68 compared the percentages of white, black, and Hispanic patients that received CABG, percutaneous transluminal coronary angioplasty, and cardiac catheterization before and after the New York State CABG public report was available. They also compared the trends in New York State to trends in other States for which discharge data were available that included race. Their findings identified increasing disparities with public reporting, counter to the assumption that public reporting may reduce disparities if availability of information helps to level of the playing field for diverse patient groups. They found that the disparity in the percentage of patients who received CABG by race increased in the periods after public reporting and that this disparity is greater in New York State than in 12 comparison States that had not released CABG public reports.

Use of other cardiac procedures did not increase to offset this difference. Nineteen percent fewer black and Hispanic patients than white patients had CABG after the public report and the disparity did not return to its pre public report level until 9 years after the first public report.

Glance et al. analyzed all CABG discharges for New York State in 1997 through 1999 (after public reporting of surgeon mortality rates) and found that high-risk patients were more likely to have had high-quality surgeons (the observed to expected mortality ratio declined by 0.034 points for a 10 percent increase in patient risk of death).69 This counters the speculation that surgeons would avoid high-risk patients and by doing so improve their rating.

In one of several analyses of the NYS CSRS, the 31 physicians who discontinued performing CABG during the study period were identified and they were surveyed as to their reasons for leaving surgical practice. Two respondents out of 18 who completed survey said their decision was a reaction to pressure to reject high-risk patients; however 10 respondents said the CABG report had no influence on their decision.31

##### Key Question 3 Impact on Providers

A potential effect of public reporting is that poor performing providers may be encouraged to leave practice. A study that identified surgeons who stopped performing CABG after the NYS CSRS began reporting surgeon-specific mortality rates found that 10 percent of the bottom-quartile surgeons discontinued performing CABG compared with 5 percent in the top three quartiles.31

##### Key Question 4 Impact on Patients or Purchasers

The most frequently studied issue was whether public reports affected the selection of providers by patients or purchasers or others acting on behalf of patients. The results of analyses of selection in the research on public reporting about individual clinicians were not consistent across studies.

Three studies concluded that public reports have had no effect. Epstein92 studied the patterns of referrals to cardiac surgeons, an instance in which the referring physician is acting for the patient and potentially basing referrals to surgeons who are the subject of public reporting on the surgeon’s report card scores. The study found that the public report publication did not influence CABG referral patterns based on analyses of models and patterns of referrals before and after public reporting in Pennsylvania, and compared these patterns to Florida, which did not have a public report. While there was a shift away from high-mortality surgeons and toward low-mortality surgeons in Pennsylvania after the report was released, a similar trend in Florida “cancels out” this change in a difference-in-difference analysis, suggesting it was a secular trend independent of public reporting. One explanation the author offered for this finding was that referring physicians already knew the relative performance of surgeons without the public report. In other studies, Jha and Esptein31 reported that the NYS CSRS had no significant impact on market share for surgeons and Hannan et al.28 found no differences in surgeon volume in the first 4 years the NYS CSRS was available. In these studies market share and surgeon volume were used as measures of the numbers of patients selecting surgeons.

Two cardiac studies and one study of reproductive medicine clinics reported an effect that corresponded to the underlying theoretical model of public reporting: they found that information about quality led to an increase in selection of higher-quality providers. An evaluation of the early impact of NYS CSRS found that physicians with better outcomes had higher rates of growth in market share after public reporting.84 In a later analyses of some of the same data, Mukamel et al. reported that lower quality (higher RAMR) lowered a surgeon’s odds of being selected by 7 to 8 percent.94 Additionally, once public report data were available, the importance of price and surgeon’s years of experience on the decision declined. These researchers repeated their analysis with race as a variable and found that the disparity between white and black patients’ selection of high-quality surgeons narrowed after the quality data was made public, which they interpreted as the public report helping to rectify a situation where white patients had more access to other sources of quality information. The public report did not affect the behavior of referring physicians who tended to select surgeons who practiced at the hospitals where they admitted patients across all time periods.

Higher birth rates were associated with larger market share after performance of clinics offering assisted reproductive therapies were made public, while birth rate was not significantly associated with market share in a period before public reporting, even after analyses that controlled for other sources of information.93

Wang et al. authored the one study that reported mixed results for selection. They found that the Pennsylvania cardiac public report had a mixed effect on surgeons’ volume. Reports led to a decrease in volume for unrated and poor performing surgeons, but the volume of high-performing surgeons did not increase and the researchers interpreted the results of modeling of matching between patients and surgeons as suggesting that poor performing and unrated surgeons were avoided due to public reporting.83

Managed care organizations determine what surgeons are available to their enrollees. Two studies explored whether the NYS CSRS data on surgeon quality influenced contracting decisions. In the first study, interviews were combined with an analysis of provider lists to compare what MCOs say they do to their actual contracting patterns. While 60 percent of the plan representatives interviewed responded that quality was the most important consideration in selecting surgeons, analysis of actual contracting patterns showed weak and mixed effects. There was a statistically significant preference for high-volume and high-quality outlier surgeons, but there was no systematic selection based on RAMR or low-quality outlier status.162 Another analysis of the same contracting data161 modeled the likelihood of MCO-surgeon contract combinations and found that low volume status significantly reduced the likelihood of contracts (−35.3 percent in upstate New York and −13.6 percent downstate) while high-quality outlier status and excess RAMR only affected the probability of contracts in downstate New York. The authors concluded that regional and market differences are important in assessing the impact of public reporting.

##### Key Question 5 Public Report Characteristics

Quantitative analyses of the impact of specific characteristics of public reports were rarely identified for any of the health care setting included in this review. However, for this topic there were two studies that were unique in the issues they addressed.

One study evaluated use of a Web site with physician performance information provided by an employer to employees and retirees. Overall, 11.9 percent of the people given the information visited the site. Current employees who were randomly assigned to receive information about the site via email were 6.42 times more likely to register and use the site than those who received paper information by mail (p<0.001). The difference in use by employees and retirees who received risk-focused compared with gain-focused was not statistically significant.110

In a study with multiple analyses related to the NYS CSRS, Jha and Epstein31 examined the impact of delay in release of data on relevance of report cards to potential users. They demonstrated that surgeons’ performance in the year the data were collected was predictive of performance in the year it was released (2–3 year delay) and most likely to be used. Based on this they concluded that the information is therefore more likely to be used and still be useful to patients selecting surgeons despite the delay.

##### Key Question 6 Context

Two studies included some contextual feature, one focusing on a characteristic of the decisionmaker (employed vs. retired) and one focusing on a characteristic of the environment (whether insurance coverage was mandated). Retirees were more likely than employees to use a Web site with physician performance information, perhaps because this information was more important to older adults.110 Public reports had a greater impact on market share in States that mandated insurance coverage for ART, perhaps because the insurer directed beneficiaries to higher-quality providers or because with coverage people were less likely to trade quality for price.93

#### Summary of Qualitative Studies

We identified 20 qualitative studies that focused on public reporting for individual physicians and one group practice. These studies were published between 1996 and 2011, and 15 were conducted in the United States, 2 in Taiwan,163,164 and 3 in England.165–167 Most of these studies were descriptive surveys including eight surveys of physicians139,141,164,167–171 and five surveys of patients.146,163,170,172,173 Other studies reported the themes from interviews,174,175 focus groups,165,176 and a 3-year program of focus groups, interviews, and observations.166 Two studies used lab-type experiments in which people were asked to make a series of hypothetical choices between physicians based on public report ratings177 and different formats of reports.178

The results are briefly summarized below in chronological order by year of publication in order to allow the identification of changes in attitudes or trends over time.

Professionals. The surveys of providers clustered near the start of the Pennsylvania and NYS CSRS reporting on surgeons and documented physician concerns and generally negative perceptions of this public reporting.

- Schneider and Epstein surveyed a 50 percent random sample of all cardiologists and cardiac surgeons living in Pennsylvania in 1994 and asked their views on the Pennsylvania CAGB guide. Six-hundred ninety seven (64 percent) surgeons responded. Eighty-two percent of cardiologists and 100 percent of surgeons were aware of the guide; 63 percent of surgeons said they were less willing to operate on high-risk patients, and 59 percent of cardiologists reported it was harder to find a physician for their high-risk patients (1996).141
- A survey sent to all cardiologists (36 percent response rate) asked whether they discussed the NYS CSRS data on CABG with patients when referring them to surgeon (78 percent replied “no”). Responses to items about accuracy and format were generally critical (e.g., 33 percent replied that the report was not at all accurate, 37 percent said the report was very misleading, while 46 percent said “somewhat” misleading) (1997).139
- In response to a survey fielded in 1996, 88 percent of 1,444 interventional cardiologists (28 percent response rate) said they would be somewhat or much less likely to treat high-risk patients if physician-level outcomes were publically reported (1999).168
- All active cardiac surgeons were surveyed in New York State and 67 percent reported refusing treatment to at least one high-risk patient in the previous year. They also reported that their practice (30 percent) and the practice of their peers (37 percent) changed due to public reporting (1999).169
- Narins et al. sent a mail survey to all interventional cardiologists included in a New York State public report about PCIs. Physician responses indicated that public reporting is perceived as influencing practice so that access to care is restricted: 83 percent agreed that patients who might benefit were not getting the procedure and 79 percent agreed or strongly agreed that knowing their data will be public had influenced their decisions about specific patients (2005).170
- A survey explored the views of rank-and-file physicians about public reporting and financial incentives linked to quality measures.171 Five hundred fifty-six of 1,168 randomly selected general internists from the AMA master file practicing in one of 12 selected metro areas completed questionnaires (48 percent response rate). Thirty-two percent were in favor of releasing individual physician data and forty-two percent were in favor of releasing medical group data. Their reservations seemed to link to views that quality measures are not adequately adjusted for a) patients’ medical conditions (36 percent strongly agree, 52 percent somewhat agree) nor for b) patients’ socioeconomic status (38 percent strongly agree, 47 percent somewhat agree). Respondents also thought that measuring quality (to be used for public reports or financial incentives) will divert attention from important care that is not measured (22 percent strongly agree, 39 percent somewhat agree) and may lead physicians to avoid high-risk patients (40 percent strongly agree, 42 percent somewhat agree) (2007).
- The one provider survey with a different focus was a mail survey of 236 (29 percent response rate) Taiwanese health care providers that collected data on doctors’ preferences for public report content, format, and frequency. Respondents preferred reporting that was updated yearly, was risk adjusted, provided detailed scores, and labeled charts so ranges of value could be identified as good or bad (2010).164
- A survey of cardiac surgeons in the United Kingdom was conducted in 2005 and repeated in 2009 in order to measure changes in attitudes toward public reporting of performance tables.167 One hundred and nine out of 206 surgeons sent surveys responded (52.9 percent). The results documented that while many respondents still do not welcome public reporting of individual surgeon results (68.8 percent in 2005 and 43.3 percent in 2009), an increasing number believe the reporting improved standards (42.2 percent in 2005 and 64.9 percent in 2009, p<0.0001) and increase patient confidence in their care (21 percent in 2005 and 39.6 percent in 2009, p=0.001) (2011).

Patients. Patient reactions to public reporting was the subject of five studies that produced a range of results, potentially due to the fact that they surveyed very different populations.

- Schultz et al. conducted a phone survey of employees who had the opportunity to review a public report and select a “care system” group of practices. Forty-two percent of respondents with single coverage and 52 percent of respondents with family coverage recalled seeing the public report. Respondents found overall ratings most helpful and detailed ratings least helpful. Consumers who changed care systems were most likely to use the public report and found it useful while people happy with their current provider tended not to use the report (2001).179
- A survey of outpatients at the University of Missouri Health Center asked for patient reactions to a report the medical center produced and distributed about its providers, and 59.9 percent said it was useful information but 30.2 percent thought it was hospital advertising. While few people were very or somewhat likely to change doctors or hospitals based on this data, more than half (21.9 very and 31.9 somewhat) were likely to use the information to decide where to have a procedure (2004).146
- In response to a phone survey based on random digit dialing almost half (49.6 percent) of the adult respondents (20 years old or more) surveyed in Taiwan reported they had compared doctors based on quality of care and 76.7 percent said they would change physicians based on quality information if their physician’s score was low (2004).163
- Patients likely to be looking for a primary care provider were provided access to web-based information about physicians and then asked about their physician choice and usefulness of the information. Seventeen percent visited the site (n=382) and of the 301 who completed the questionnaire, 51 percent said patient experience scores were the most important information and these respondents were more likely to pick a physician with high scores from the patient experience survey (2007).172
- A survey of 467 people (66.8 percent response rate) conducted at outpatient clinics at a university medical center found that only 13 percent of respondents were aware of any Web sites on health care quality and only 2 percent reported the Web site was important in their choice of a provider. The most important factors in their choices were reputation and a trusted referral from another physician or family and friends (2011).173

Interviews, focus groups, and studies that used multiple methods collected additional information on the perceptions and choices of physicians and patients.

- Marshall et al.165 conducted 12 focus groups, four with patients, four with general practitioners, and four with clinical administrators in order to get their reaction to public reporting about general practice. Themes were similar across the groups with participants having an initial strong negative reaction to public reporting that became more positive over the course of the discussion. Patients felt “shopping around” was inappropriate for health care and were most concerned about location while providers and administrators worried that reports were politically motivated and that “good” practices would be swamped by new patients (2002).
- In a different study, Marshall et al.166 used an action research-based approach and over 3 years conducted interviews, focus groups, observations, and presentations at four primary care organizations in order to develop an information source about primary care services. Participants included 104 members of the public, staff at 19 practices, and 4 managers. Their major findings were that the public wanted different information than the staff; they viewed performance information as a supplement to information from other sources; they wanted narrative descriptions as well as numbers; they disliked league tables; and they were not confident about the source of quality information (2006).
- Barr and colleagues interviewed 56 physicians and during the interviews they presented scenarios that varied in terms of patient age and diagnosis in which patients asked questions about a referral based on information from a public report. They categorized physician responses into four major themes: (a) rely on existing physician-patient relationships; (b) acknowledge and consider patient perspectives; (c) take actions to follow up on patient concerns; and (d) provide their perspectives on quality reports, and also reported that physicians were concerned about the methodological rigor of reports (2008).174
- In Massachusetts, researchers interviewed 72 leaders of physician group practices that provided primary care about their awareness and use of a new physician group report on patient experience. Seventeen percent were not aware of the report and 22 percent used the report to focus on low performers, while 61 percent reported instigating group-wide improvement activities based on the results. The most common QI activities concerned access (57 percent), communication with patients (48 percent), and customer service (45 percent) (2010).175

Two lab-type experiments and one focus group study were used to determine patient preferences for different types of information and different formats.

- In an experiment that offered participants (n=301 adult volunteers) choices between two physicians and provided rating of technical and interpersonal quality, 66 percent of people selected the physician with higher technical quality three or more out of five possible times, leading the authors to conclude that technical quality is more important to potential patients (2005).177
- Stein et al. conducted four focus groups in Pennsylvania with mental health care consumers who were Medicaid beneficiaries. Participants said they wanted information about providers, but specific items they valued such as flexibility in scheduling, ability to talk to the doctor, and shared decisionmaking were not the items available from public reports (2009).176
- Donelan and colleagues178 recruited 337 adults to review four different versions of records on CABG outcomes for fictional, individual surgeons. The versions varied in both format (text, charts, and graphical indicators) and the data presented. Participants were asked to select the surgeon with the lowest mortality rate and to rate different versions in terms of their usefulness. Participants viewed the type of data as important with 40 percent saying it was “absolutely essential” and 42 percent “very important.” The ability to correctly select the surgeon varied from 66 percent based on a version that included graphical indicators to 16 percent when using a text-table. However, the text-table that resulted in the lowest percentage of correct identifications of the lowest mortality surgeon was the one most frequently cited as the most useful (selected by 37 percent of participants) (2011).

Additional information extracted from these qualitative studies is included in the Evidence Tables in Appendix K.

### Health Plans

Rating and reporting of health plans is linked to the growth of managed care in both the private health insurance market and public health insurance programs. Also important have been the active roles employers and employer purchaser coalitions began to play as agents for their employees in the late 1980s and early 1990s. Businesses went from simple provision of health insurance to active involvement in creating and offering more options and models of health insurance; advancing a quality improvement agenda in health care; and selecting, or in some cases creating, the health plans available to employees. These changes were motivated both by the desire to control the rising costs of health care coverage and to assure a healthy and more productive workforce. At the same time public programs such as Medicaid and Medicare began offering and sometimes requiring enrollment in managed care plans.

Health plans are selected when people start a job or become eligible for a public insurance program. First health plans must be included among the options offered by employers and public programs. Then health plans must appeal to employees and beneficiaries who select from among the offered options. People select health plans for ongoing and future health care needs, and can change plans once yearly during open enrollment periods or if their status changes (e.g., spouse loses coverage from another employer, newborn is added). Health plans may try to increase their market share by offering different combinations of quality of information, benefits, premium structures, and more or less restricted access to providers (physicians, specialists, hospitals, prescription drugs, etc.).

We identified 24 quantitative studies and 32 (reported in 35 articles) qualitative studies lab-type experiments about public reporting of quality information related to health plans that met our inclusion criteria and fit our analytic model. Information abstracted from the articles is included in the Evidence Tables in Appendix L and Appendix M.

#### Overview of Findings

##### Quality of Care (Key Question 1)

- Quality measures improved for almost all HEDIS and CAHPS domains studied after public reporting (five studies).53–57
- During the time period in which some plans allowed their HEDIS measures to be publicly reported while others submitted data but did not allow it to be released, plans that voluntarily released quality data had higher-quality scores54,55 (two studies) even after controlling for differences in plans (one study).55

##### Harms (Key Question 2)

- Potential harms were examined in two of the included studies. The potential harms were crowding out which refers to declining quality of care in areas not measured due to a focus on the aspects of care that are measured70 and withdrawal of high-quality plans from the market.71 Neither study found evidence of these harms.

##### Impact on Providers (Key Question 3)

- No studies were identified.

##### Impact on Patients or Purchasers (Key Question 4)

- Publicly reported or widely distributed quality information had little impact on the selection of health plans by individuals based on the results of studies of different populations.
  ○ Quality information had no consistent or significant effect on the health plan choices made by employees of private firms (five studies).95–98,113
  ○ Four studies of public employees had mixed findings.23,99–101
    ■ Two reported limited or no impact on the choice of health plan made by State employees in Minnesota99 and Federal employees in 86 counties23
    ■ Two studies of Federal employees reported that public reports lead to an increase in the use of quality information101 and switching out of plans with low scores.100
  ○ In studies that used random assignment to distribute quality rating materials to some beneficiaries of public insurance programs and not others, the quality information had no impact on plan selection (three studies).102–104
- Employers were more likely to select health plans to offer to employees that had higher HEDIS and CAHPS ratings (one study).105

##### Public Report Characteristics (Key Question 5)

- No studies were identified.

##### Context (Key Question 6)

- Contextual factors were not frequently studied in research on health plans, limiting what conclusions can be drawn from the literature.
  ○ The only study of environmental characteristics found quality information was more likely to be used in plan choice in markets that included plans of varying quality.112
  ○ Some variation in the importance of quality information to different subgroups of consumers was identified (two studies).113,114
  ○ Plans that started with lower ratings were more likely to improve their performance after public reporting (two studies).53,57

#### Description of Quantitative Studies

The 24 quantitative studies of public reporting and health plans are described and synthesized below. These studies were published between 1998 and 2010 and except for one about health plans in the Netherlands,57 all were conducted in the United States. The public reports that are the subject of study are all versions of HEDIS or CAHPS, or similar items or domains that predate widespread use of HEDIS and CAHPS. (More detail on HEDIS and CAHPS is provided in the intervention description below and in Appendix E).

The populations in the included studies were most frequently employees or people eligible for public insurance programs. Ten studies examined health plan choices of employees of corporations, the U.S. Federal Government, one State government, and one university.23,95–98,101,113,180–182 Three studies were of people eligible for Medicaid,102,103,183 one was about parents selecting a State plan for children,114 and two were about Medicare enrollees.104,112 One study examined how employers selected plans to offer their employees.105 In the remaining studies the populations were the health plans and the focus was on their responses to public reporting.53–57,70,71

The public reporting intervention in eight studies about choice of health plans was public reports or plan rating sheets produced by employers for use by their employees.96–101,113,181 In the other studies about choice of plans the public report was HEDIS,95 CAHPS,102–104,183 or both.23,105,112,114 The studies of health plan behavior also examined the effect of HEDIS,53–55,70,71 CAHPS,57 or both.184 HEDIS is a set of clinically oriented measures developed by the National Council on Quality Assurance (NCQA) that included measures related to screening, prevention, care coordination, and treatment of specific conditions. HEDIS has been in use for over 20 years and is currently used by over 90 percent of managed care plans and an increasing number of preferred provider organizations (PPOs). It is required in 34 States for reporting on private and public health plans. CAHPS is a measure of member experience initially developed by the Federal government for health plans in the United States. Several versions have been created and used in different health care settings and other countries.57

The comparator in the majority of health plan studies was either (a) time period during which the report was not available or (b) groups that did not have the publicly reported information. However some studies did not have a true comparator as they measured only change over time after public reporting began.

HEDIS, CAHPS, and custom reports on the quality of health plans have been distributed and published in phases over time. This has allowed for use of a variety of study designs (see Appendix D for definitions of the study design terminology used in this report). The comparator and study design influence but do not alone determine the quality assessments of articles included in this review. Potential confounding as well as the strength of the comparison (similarity across compared groups or compared time periods) was given more weight than other criteria. (See Appendix G for the quality assessment for these studies and Appendix F for a description of the quality assessment criteria). Seven studies were rated as good,23,55,71,96,98,102,103 13 as fair,53,54,70,95,96,99–101,104,105,112–114 and 4 were poor according to these criteria.56,57,97,183

Three studies of health plans used random assignment102–104 which is rare in studies of public reporting. These studies all examined the impact of CAHPS on plan selection by randomly assigning Medicaid beneficiaries to receive or not receive CAHPS information in their enrollment materials and then compared plan selection across the groups. In one case the random assignments were not recorded by the company responsible for the mailing and the investigators had to ask survey respondents to self-report whether they had received the CAHPS report in their materials.104 Studies that included data only post public reporting were most common, with two “post only” time series,53,56 five studies that reported data for one group post public reporting,23,71,95,96,105 and six studies that included a comparison group.54,57,97,98,114,183 Studies that included data collected prior to public reporting included one study that interviewed Medicare beneficiaries before various versions of plan information were mailed and compared their plan selections to beneficiaries who received the different mailings;112 three studies that compared different groups before and after public reporting;55,70,99 and four studies that analyzed data from one group of subjects pre and post reporting.100,101,113,181

The most common outcomes in these studies (17 out of 24) were the selection of health plans by employees, people eligible for public insurance programs, or employers (Key Question 4).23,95–105,112–114,181,183 This selection outcome was operationalized in several ways including the likelihood of selecting a plan conditional on its quality rating, the probability of switching plans, or the retention of members by plans. The outcomes of studies that analyzed the changes in health plan performance in response to public reporting were changes in the quality of care provided by health plans (Key Question 1).53,54,56,57 Two studies tested potential harms (Key Question 2): in one the harm was that plans would focus on what was measured in HEDIS and quality would decline on unmeasured care;70 and in the other it was proposed that plans with high scores would withdraw from the Medicare market because providing high-quality care is too costly.71 None of these studies of health plans and public reporting examined other changes in health plan behavior (Key Question 3) or the impact of characteristics of the public report (Key Question 5). Six out of the 24 studies specifically addressed contextual factors (Key Question 6) in addition to other outcomes, including one study that examined the relationship between change in quality and the varying levels of quality of health plans available in the market112 and five studies that reported differences by the characteristics of the decisionmaker.53,56,57,113,114

#### Effectiveness by Outcome/Key Question: Detailed Analysis of Quantitative Studies

Table 5 at the end of this section provides an overview of each included empirical study and a summary of the key findings. The complete abstracted data for each study is in the Evidence Tables in Appendix L.

Table 5 Summary of evidence: public reporting on quality of health plans

Key Question 1: Does public reporting result in improvements in the quality of health care (including improvements in health care delivery structures, processes, or patient outcomes)?

Key Question 2: What harms result from public reporting?

Key Question 3: Does public reporting lead to change in health care delivery structures or processes?

Key Question 4: Does public reporting lead to change in the behavior of patients, their representatives, or organizations that purchase care?

Key Question 5: What characteristics of public reporting increase its impact on quality of care?

Key Question 6: What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care?

Author Year (QA) | Public Report | Study Overview | Key Question | Results (↑Improvement; ↓Worse; ↔No Difference)
Abraham 2006^97^ (Poor) | Performance results booklet containing member satisfaction survey results awards for quality. | Examined health plan choices of employees of 16 firms that distributed or did not distribute quality information and whether performance information leads to switching plans. N= 651 single employees | 4 | ↔Quality information does not have an impact on switching plans ↑Employees are more likely to be aware of quality information when booklet is distributed to all employees or available on request than when booklet was not distributed by employers
Bardenheier 2007^54^ (Fair) | HEDIS | Examined the effect of HEDIS reporting on childhood immunization rates in health plans that publicly reported their data compared with the non publicly reporting health plans. N=423 plans in 1999, 383 plans in 2000, 371 plans in 2001 and 332 plans in 2002. | 1 | ↑Public reporting results in a statistically significant increase in immunization (p<0.009) controlling for accreditation, enrollment size, years in business, region, minority status of enrollees and purporting of enrollees who had a primary care visit.
Beaulieu 2002^113^ (Fair) | Plan profiles provided by employer (Harvard) | Examined whether quality information affects health plan choice in Harvard University employees from 1994 to 1997. N=11,500 employees | 4 | ↑Employees were slightly but significantly more likely to switch from a low-quality plan than a high quality plan (p<0.01). ↑One unit increase in quality resulted in a 10% increase in odds of switching plans (p<0.01).
Beaulieu 2002^113^ (Fair) | Plan profiles provided by employer (Harvard) | Examined whether quality information affects health plan choice in Harvard University employees from 1994 to 1997. N=11,500 employees | 6 | ↑ Families and older individuals have stronger preferences for quality; younger and single are more sensitive to price
Bost 2001^56^ (Poor) | HEDIS and CAHPS | Evaluated the impact of public reporting of HEDIS for 1996, 1997 and 1998, and 1999 on HEDIS and CAHPS scores. N=421 health plans | 1 | For plans that publicly reported, all 8 HEDIS measures improved over time. ↑ 3 out of these 8 measures improved significantly over the 3 years (p<0.01) ↑ 7 out of 10 CAHPS measures were better for reporting plans compared to non reporting and new reports. (p<0.01)
Chernew 1998^95^ (Fair) | HEDIS | Analyzed the impact of plan performance rates on employee health plan choices of single coverage at one company. N=5795 employees | 4 | Relationship between ratings and choice is inconsistent ↔no effect 6 out of 8 measures ↑Superior rating on medical treatment related to increased selection but only significant in 1 of 4 models. ↓Superior rating on satisfaction is related to lower likelihood of choosing a plan.
Chernew 2004^105^ (Fair) | CAHPS and HEDIS | A cross sectional comparison of plans offered by employers in the United States by those not offered in terms of quality measures. N= 855 employer/MSA combinations | 4 | ↑ Employers are more likely to offer plans with better HEDIS and CAHPS scores. Also more likely to offer low-cost plans and plans that are nonprofit, established and part of national chains.
Dafny 2008^112^ (Fair) | One HEDIS measure (mammogram rate) and one CAHPS measure (first communicate, then best care) included in the Medicare and You brochure. | Examined the association between public reports and switching behavior by comparing Medicare beneficiary responses before and after receiving mailed information including one HEDIS and one CAHPS indicator. The focus was on separating responses due to learning about quality from other sources from these. N=8212 plan-county-year combination | 4 | ↔ Medicare enrollees were switching to high quality plans independent of the public reports during the period. ↑ A response to the public report is still found controlling for switching already happening. This effect is due to the CAHPS measure about best care, not the HEDIS measure. ↑ Switching is within HMOs, not from traditional plans to HMOs and is small (1.24% of beneficiaries in 2002 estimated through simulations).
Dafny 2008^112^ (Fair) | One HEDIS measure (mammogram rate) and one CAHPS measure (first communicate, then best care) included in the Medicare and You brochure. | | 6 | ↑Impact of public reports greater in markets that have providers of varying quality levels.
Farley 2002a102 (Good) | CAHPS | Assessed the impact of CAHPS health plan performance information on plan choices by New Jersey Medicaid beneficiaries randomly assigned to receive or not receive the CAHPS information. N= 1763 intervention and 787 control | 4 | About 1/2 of people mailed CAHPS report say they received and read it ↔No difference in HMO selection across groups ↑Group that said they read it was more likely to pick a high quality HMO than control, but only if they did not pick the dominate HMO in market
Farley 2002b103 (Good) | CAHPS | Examined the impact of CAHPS on the health plan choice of Iowan Medicaid beneficiaries randomly assigned to receive or not receive CAHPS information. N=13,077 new beneficiaries | 4 | ↔The odds of switching vs staying in an assigned HMO in CAHPS vs No CAHPS group was not statistically significant. ↑Participants were significantly more likely to switch from a low-rated HMO to a high-rated HMO than from a high- to a low-rated HMO, independent of the CAHPS information, suggesting this is based on other information.
Fowles 2000^98^ (Good) | HEDIS and CHIP | Compared consumer responses to report cards (HEDIS and CHIP) in two health care purchasing cooperatives in Denver, CO (N=670) and St. Louis, MO (N=784). The study assessed the exposure and helpfulness of report cards. | 4 | ↑The number of employees who remember seeing the report card were 35% higher in St Louis than Denver. The results were significant ↔There was no significant difference in the number of employees who had read most or all of the report. ↔There was no significant difference in the number of employees in Denver and St. Louis who found the report helpful. ↑Gender and Education were statistically significantly related to helpfulness in learning about plan quality.
Fox 2001^183^ (Poor) | CAHPS | Evaluated the impact of CAHPS report vs. no CAHPS in selecting a managed care plan by Medicaid enrollees in Kansas in May 1998. N= 698 new enrollees | 4 | ↑Ease of judging quality of care was rated easier by in CAHPS report group vs no CAHPS p=0.01 ↓Making Informed Choices: Odds of choosing most influenced by doctor or nurse was 30% lower in CAHPS groups vs No CAHPS group. People self-reporting receiving report: 39.4% said it influenced their choice of plan a lot; 31.7% a little.
Habermann 2007^70^ (Fair) | HEDIS | Examined the effect of HEDIS measures on reported and unreported quality care, which is assessed by comparing stage of breast cancer for women 65–69 years old (reported) and 70–75 years old (not reported). N=30,857 Women ages 65–74 diagnosed with breast cancer from 1994 – 2002 | 2 | ↔ lack of difference in stage across age groups reported and not reported in HMOs and the persistent of the difference between Fee for Service and HMO across the two age groups suggests there is not crowding out and may be spill over to the older group not included in the HEDIS measure.
Hendricks 2009^57^ (Poor) | CAHPS version | Analyzed whether health plan quality improved in The Netherlands after the introduction of public reporting. N= 30 plans in 2005 and 32 in 2006, 2006, and 2008 | 1 | ↑Improvement on 4 of 7 quality aspects (general rating, health plan information, access to call center, transparency of copay requirements). Improvements were small. Identification of areas as important by the government did not influence which areas experienced improvement.
Hendricks 2009^57^ (Poor) | CAHPS version | Analyzed whether health plan quality improved in The Netherlands after the introduction of public reporting. N= 30 plans in 2005 and 32 in 2006, 2006, and 2008 | 6 | ↑6 of 7 quality aspects the performance of below-average scoring health plans increased more than the performance of average and/or above-average scoring health plan.
Jin 2006^23^ (Good) | HEDIS and CAHPS | Estimated the impact of public reports of quality on choice of plan for retirees covered by the Federal Employee Health Benefit Plan separate from the impact of quality information they can obtain without the report. N= employees in 86 counties with the greatest number of plans | 4 | ↔99.3% of enrollment choices would have been the same with or without the information. ↑The impact of public information on choice of plan is 2.63 percentage points increase in likelihood of choice with one standard deviation increase in reported score.
Jung 2010^55^ (Good) | HEDIS | Examined the impact of voluntary information disclosure on quality of care in HMO markets in the United States by comparing HEDIS scores for disclosing and non disclosing HMOs. N= 797 discloser and 265 non disclosing HMOs | 1 | ↑Public reporting leads to an increase in the composite quality score after controlling for differences in plans. ↑in 3 of 4 domains (chronic illness, maternity, childhood immunizations) ↔ on 1 of 4 domains: screening tests
Knutson 1998^99^ (Fair) | SEGIP (employee group insurance) produced report | Tested effect of public report vs. no public report on the knowledge, attitudes, and choice of health plan by Minnesota State employees. n=385–431 for different types of employees Total N=3573 | 4 | Limited impact of public reports ↔5 out of 8 outcome measures showed no significant difference in either single or family coverage groups. 3 significant findings ↑Knowledge in single coverage intervention group improved significantly but not in family coverage group. ↑Relative importance of cost and quality of health plan significantly improved in family coverage intervention group but not in single coverage. ↑Single coverage intervention group switched more frequently than control.
Lied 2001^53^ (Fair) | HEDIS | Estimated improvements in four HEDIS measures from 1996 to 1998. N= varies by measure from 55 to 167 | 1 | All improved over study years; within year comparisons varied ↑All 4 outcome measures improved between 1996 to 1998 statistically significantly (p<0.05). ↑2 out of 4 outcomes increased statistically significantly between 1996 to 1997. ↔2 of the 4 outcomes changed but not significantly between 1996 to 1997. ↑All 4 measures increased between 1997 to 1998 where 3 were significant and 1 was not.
Lied 2001^53^ (Fair) | HEDIS | Estimated improvements in four HEDIS measures from 1996 to 1998. N= varies by measure from 55 to 167 | 6 | ↑ the plans with poor performance in 1996 accounted for most of the improvement.
Liu 2009^114^ (Fair) | CAHPS and HEDIS | Examined whether parents of children enrolled in the New York State Children’s Health Insurance Program chose managed care plans with better quality and whether this differs across subgroups such as special needs and income. N=2644 parents of new enrollees | 4 | One unit increase in CAHPS score increase probability of plan selection by 2.5 percentage points ↔HEDIS scores had no significant association with plan choice.
Liu 2009^114^ (Fair) | CAHPS and HEDIS | | 6 | ↑CAHPS had a larger impact on choice by parents of children with special needs ↔Impact was not significantly different by education or income
McCormack 2001^104^ (Fair) | CAHPS | Examined the impact of CAHPS vs. no public report on the choice and attitudes of Medicare beneficiaries in 1998–1999. N= 1156 experienced beneficiaries (62% response) N=951 new beneficiaries (58% response) | 4 | ↔Use of information for health plan switching did not vary ↑Experience beneficiaries who received CAHPS info were more confident in plan choice p<0.01 ↓New beneficiaries less likely to use mailed materials to chose plan in the group that received the CAHPS p<.01
Pham 2002^71^ (Good) | HEDIS | Assessed whether high performance on quality indicators by health plans was associated with withdrawal from Medicare. N=2310 Contract-County Units | 2 | ↔The hazard of withdrawal is higher in low-quality health plans vs. high-quality health plans. All results were statistically significant. This is contrary to the suggested harm that high quality plans would withdraw.
Scanlon 1999^96^ (Fair) | HEDIS-based ratings created by employer | Analyzed of the impact of HEDIS-based ratings on one company’s employee selection of plans for family coverage. N= 96 plans available to sampled employees | 4 | No evidence of strong response to ratings ↔no effect on 4 out of 5 domains. ↓Superior rating on surgical care is related to lower likelihood of choosing a plan, which may be due to correlation among items.
Scanlon 2002^181^ (Good) | GM Public Report + HEDIS | Examined the impact of HEDIS on health plan choice in GM employees. N=29,000 | 4 | ↔ Modeling of impact of specific domains on choice was not successful ↑Plans with below average ratings were less likely to be selected. Impact of below average rating is large compared to impact of price. ↔Superior ratings did not increase likelihood of choice.
Tai-Seale 2004^101^ (Fair) | OPM | Explored the link between distribution of satisfaction information and retention of members in health plans among Federal employees. N=250 plans | 4 | ↑Distribution of satisfaction information appears to have an impact in that it is associated with lower retention, suggesting the information induced people to withdraw from plans.
Wedig 2002^100^ (Fair) | Public report created by Office of Personnel Management for Federal employees. | Tested the hypothesis that publicly reported quality indicators impact the choice of health plans in Federal employees between 1995 where public report distribution was limited and 1996, where public report was widely disseminated. N=4299 in 1995 N=4863 in 1996 | 4 | ↑In 1996, the odds of using quality information for choosing a plan was 57% higher for new hires and 21% higher in existing employees, compared to 1995 hires.

Notes: CAHPS = Consumer Assessment of Healthcare Providers and Systems; HEDIS = Healthcare Effectiveness Data and Information Set; HMO = health maintenance organization

##### Key Question 1 Quality of Health Care

Of the five studies that examined health care outcomes for health plans, three reported the impact of public reporting on HEDIS measures. Lied and Sheingold53 found that all four reported HEDIS measures (adult access to prevention, beta blockers following a heart attack, breast cancer screening, and eye exams for people with diabetes) improved significantly from 1996 to 1998. Bardenheier et al.54 reported that childhood immunization rates improved (from 65.7 percent in 1999 to 67.9 percent in 2002) and plans that publicly reported their rates had significantly better rates than those who did not after controlling for several factors including enrollment size and minority status of enrollees. Jung55 used health maintenance organizations (HMOs) that did not publicly release their HEDIS data as a comparison group for those who did. After controlling for differences among the plans she concluded that public reporting led to improvements in the composite quality score from 1997 to 2000 and that this improvement occurred in three of four domains (chronic illness, maternity, and childhood immunizations, but not in screening tests). Bost56 authored the one study identified that examined changes in both HEDIS and CAHPS data. He found that plans that released their data for 3 years in a row (1997–1999) had significant improvements in three of eight HEDIS measures (adolescent immunization, breast cancer screening, and beta-blocker treatment) and seven out of ten CAHPS domains. Reporting plans performed better than those plans that did not report or started releasing their HEDIS data in 1998. The only non United States study followed scores derived from CAHPS for 3 years after they were released publicly for health plans in The Netherlands.57 The study found improvement in four of seven quality aspects. The Dutch government also identified areas in need of improvement among the aspects of quality and publicized this information. However this added attention by the government and the public did not influence where health plan improvement actually occurred.

##### Key Question 2 Harms

Two studies investigated potential harms due to public reporting about health plans. Pham et al.71 tested the claim that plans that perform well on HEDIS would be forced to withdraw from Medicare because high quality care cannot be sustained under Medicare payment policy. Results that included adjustment for several confounders found that withdrawal was five times higher among plans with low scores (20.5 percent vs. 4.5 percent) as opposed to those with high scores on six HEDIS indicators, counter to the expectation related to this proposed harm.71 In a larger study of the impact of policy on breast cancer screening, Habermann et al.70 explored another potential harm by comparing the stage of cancer at diagnosis among women age 65–69 for whom the rates of screening were reported in HEDIS with that for women age 70–75 who were not included in the HEDIS measure. The premise the researchers tested was that health plans will focus their efforts on the activities that are measured and allow quality to deteriorate in areas that are not measured and publicly reported, or crowded out. The finding that the stage at diagnosis did not differ across the age groups suggests quality of care on the unreported activity (screening for women age 70–75) is not crowded out by focus on the reported measure.

##### Key Question 3 Impact on Providers

We did not identify any empirical studies that examined the impact of public reports on the intermediate outcome of health plan behaviors.

##### Key Question 4 Impact on Patients or Purchasers

The bulk of the evidence about public reporting and health plans focused on how public reporting affects the selection of plans by employees, people eligible for public insurance programs, and employers planning to offer plans to their employees.

Five studies analyzed the health plan choices of employees in private companies and universities. One study of university employees found that the quality of information had little or inconsistent effects on plan selection.113 Chernew and Scanlon,95 in a study of the choices for single coverage at one large firm, concluded that the information on six out of eight HEDIS measures distributed to employees had no effect on choices during the 1995 enrollment period. A superior rating on the Medical Treatment domain increased selection but only in one of four models and a superior rating on satisfaction was actually related to decreased selection. A similar study of choices for family coverage made by employees of one company96 found no strong response to HEDIS-based ratings. A third study of a single company was not able to model the impact of specific measures but identified that plans with below average ratings were less likely to be selected, while superior ratings did not increase the likelihood a plan would be selected.181 Abraham et al.97 analyzed information from 16 firms and did not find a link between quality information and employees switching plans. Beaulieu examined the choices of Harvard University and found a small, significant effect with a 1-unit increase in quality resulting in a 10 percent increase in the odds of switching plans.113

One study evaluated the health plan choices in two different health care purchasing markets. This study98 found that despite markedly different markets (Denver, CO and St. Louis, MO) the responses to the report cards were almost the same. Exposure and helpfulness of report cards were limited and related more to employee preferences for the type of information than to their health care needs.

Four studies of State and Federal employees and retirees conducted during the same time periods had mixed results. In a study of Minnesota State employees in 1995, the choices of employees at locations who received a public report on available health plans were compared to those at locations that did not and the reports were found to have limited impact on health plan choice.99 Three studies involved Federal employees or retirees. Wedig100 reported the odds that new hires use quality information in their choice increased 57 percent in 1996 when the public report was distributed compared with the year before. In another study of the distribution of satisfaction information to Federal employees during open enrollment, retention of health plan members declined compared with prior periods in which satisfaction materials were not distributed, suggesting the information inspired employees to drop plans.101 Jin and Sorenson23 analyzed the choices of Federal retirees in 86 counties with multiple plan choices and estimated that 99.3 percent of all choices would have been the same, but in the case where employees did change plans the information was important.

The six studies of plan choices in Medicaid and Medicare programs similarly found no or limited impact of public reports on choice of plans. Three of these studies used random assignment to distribute the quality reporting materials and create control and intervention groups. Farley et al. conducted studies in New Jersey102 and Iowa103 in which the intervention groups received Medicaid enrollment materials that contained CAHPS information while the controls received standard enrollment materials. Enrollment data was combined with phone interviews to assess the impact of the CAHPS report. In New Jersey half of the people who were mailed the CAHPS data reported receiving it and there was no difference in HMO selection across the groups. In Iowa the difference in the odds of switching or staying with the assigned plan were the same in the CAHPS and the control group. Furthermore, switching from a low-rated HMO to a higher rated HMO was the same in the two groups, suggesting this choice is based on information from another source. McCormack used a similar design to test the impact of quality information on Medicare beneficiaries.104 Medicare beneficiaries in 1999 were randomly assigned to receive different versions of program information, one of which contacted a CAHPS report. The different information did not have an impact on switching health plans although it did increase the confidence of experienced beneficiaries in their choice.

Women newly eligible for Medicaid in Kansas were also sent materials with and without CAHPS reports in a study by Fox et al.183 The distribution of the materials was not tracked so they had to depend on survey self-reports of respondents as to whether they received the CAHPS materials or not. Those who reported receiving the report said it made it easier to judge plans and they were less likely to be most influenced by a doctor or nurse in their choice. Lui et al. studied the impact of HEDIS and CAHPS on the choices made by parents enrolling their children in a State insurance program in New York State.114 They found that a 1-unit increase in the CAHPS score resulted in a 2.5 percentage point increase in the probability of plan selection while the HEDIS scores had not impact on choices. Dafny and Dronove112 sought to determine the relative importance of quality scores and other sources of information for people selecting Medicare HMOs. They found that Medicare enrollees were switching to high-quality plans independent of public reports. The public report had an effect above this existing switching which was in response to the single item from CAHPS, while the single HEDIS item had no effect.

Finally, one study analyzed the health plan choices employers made to offer to their employees. Looking at large employers in 2000, Chernew et al.105 found that employers were more likely to offer plans with better HEDIS and CAHPS ratings.

##### Key Question 5 Public Report Characteristics

We did not identify any empirical studies that examined the impact of public report characteristics on the effectiveness of public reporting.

##### Key Question 6 Context

Five studies examined outcomes by contextual factors including characteristics of the environment and the decisionmaker.^b^ One study examined the HMO market for Medicare beneficiaries and found that the quality information was more likely to contribute to plan selection when the market included plans with varying quality.112

b Studies often include contextual factors as part of their major analyses in which they serve as control variables, allowing a sensitivity analysis or tests of robustness for the primary comparison. Studies were included here if the contextual factors were the subject of a subgroup analysis or produced different results.

Two studies specifically examined characteristics of the people selecting health plans. In a study of university employees Beaulieu113 confirmed that older people and people selecting family coverage had stronger preferences for quality while younger people and people selecting single coverage were more sensitive to price. Lui et al.114 determined that parents of children with special needs were more influenced by quality ratings than other parents when choosing from plans offered by a State-sponsored agency.

In two studies, improvement in the quality ratings was attributed more to plans that started with lower ratings. Lied and Sheingold53 documented that most of the improvement in health plan performance on HEDIS measures from 1996 to 1998 could be attributed to improvement by plans with poor performance in 1996. In the one non United States study, for six out of the seven quality aspects measured for Dutch health plans, the improvement in performance of below-average plans outpaced improvement by plans that had average or above-averages scores at baseline.57

#### Summary of Qualitative Studies

We identified 32 qualitative studies and lab-type experiments reported in 35 articles that focused on public reporting about health plans and corresponded to at least one of our Key Questions. These are included in the evidence table in Appendix M. All were conducted in the United States and published between 1996 and 2009. The year each study was published is included after the summary of the results in order to allow identification of any trends over time.

Six studies were descriptive surveys185–190 and 12 articles reported on results from focus groups alone191–197 or in combination with interviews and questionnaires.198–202 Four summarized interviews203–206 and 12 were lab-type experiments in which participants were asked to evaluate materials in terms of format or applicability to future decisions.207–218

##### Consumers

Two descriptive surveys asked consumers (people selecting health plans in the future) about their experience with CAHPS and the evaluations were generally positive.

- Sixty percent of health plan members in Washington State reported that CAHPS was easy to understand and 30 percent selected it as the more useful source of information when selecting a plan (1998/2000).185,219
- Similarly, in evaluation surveys in five States, 10 percent to 40 percent of respondents (varied by State) reported that CAHPS had a lot of influence on their choice although fewer than half of intended recipients remember receiving the information (2002).187
- Interviews with health plan enrollees in The Netherlands focused the demand for and use of information about health plans.
  ○ The key findings from interviews with 20 health plan members were: (1) there is discordance between the large amount of information consumers say they want but then rarely use in making decisions; (2) over the course of the interview, what patients said was most important in choosing a health plan changed, suggesting their values are not fixed; and (3) contradictory information in reports was difficult for consumers to interpret (2009).205

The focus group studies were all with consumers of different types. Two studies were conducted in multiple cities and identified numerous barriers to the use of quality information by people with Medicaid, Medicare, and private insurance.

- Twenty-two focus groups held in eight locations found that the information in public reports was perceived as marketing and that most people did not understand the indicators or expect health plans to be able to influence the results (1996).191
- Results of focus groups in six cities that focused on the impact of formatting reported that most issues were common sense. For example, consumers wanted short, clear information and guidance on how information should be used, but that most existing health plan quality materials do not meet these criteria (2001).201

Two studies were specifically constructed to develop and test Medicare materials that included CAHPS quality information.

- Harris-Kojetin reported the results of seven focus groups in which participants reported finding CAHPS generally easy to understand but interpreting the report as “pushing HMOs” as only HMOs were included (2001).192
- Goldstein used focus groups, cognitive interviews, and mall-intercept surveys to ask Medicare beneficiaries about the meaningfulness of CAHPS domains and the format. Participants chose “getting needed care” and “getting care quickly” as more important than customer service and office staff; results were mixed on format preferences with some confused by star ratings and others by bar charts (2001).194

Four focus group studies included people with different types of health care coverage and focused on the format and comprehension of public reports.

- Three articles reported different aspects of the results of 15 focus groups, supplemented by followup questionnaires that focused on comprehension and interpretation, and included people with private insurance and Medicaid as well as uninsured. Participants were unable to generalize from specific indicators to overall assessments of quality and did not understand ratings of undesirable events (1996).220 Participants stated that patient rating and desirable events were most important to them. But when they chose plans they chose those with better scores, that is, fewer undesirable events because these were viewed as aspects of care they cannot control that could have dire consequences (1996).199 Another analysis of these group responses found that participants rated the indicators that they better comprehended as most important while those they did not understand were given less weight (1997).200
- One focus group study conducted five focus groups to evaluate the usefulness, trustworthiness, and content of public reports. Most participants claimed that they would use the information if they were dissatisfied with their health plan, had changing health care needs, or were new to the community. Participants requested additional information about patient-physician relationship, ease of getting referral, clinic facilities and costs. Lastly, the older patients were more skeptical about the quality information than other community members (2002).197

Two focus group studies asked people with disabilities (2007)196 and mobility issues (2002)195 about their information needs.

- In focus groups that discussed CAHPS, participants rated the CAHPS domains as important but also asked for this additional information as well as more on access to specialists, rehabilitation, and equipment (2002).195
- In focus groups in five States, people with disabilities were shown actual public reports from California, Maryland, Michigan, and Texas. Comments on format included: most wanted shorter public reports with numbers and visuals and some did not understand star ratings or composite scores. In addition to disability-specific information they were interested in ratings on care coordination and the physical accessibility of facilities (2007).196

An evaluation of the California Quality of Care Report Card used focus groups, interviews, and Web site tracking to evaluate the report from the perspectives of consumers, health plans, and other stakeholders.

- Most visitors to the Web site visited the summary page with the star charts, but did not click through to the more detailed pages. All of the HMO executives and all but one of the medical group directors interviewed were familiar with the report. Forty-seven percent of medical groups and 13 percent of health plans reported undertaking QI efforts in response to the report (2005).202

Eight lab-type experiments explored the impact of both format and choice options on comprehension and understandability of health plan reporting.

- Included studies concluded that changes in format can increase ease of use and knowledge (2006);213 that using graphics such as bar charts or stars can increase comprehension but the results varied by subgroups of participants (2001);209 that framing quality in terms of risk increased comprehension more than framing as benefits; (2000)208 and that people need evaluative labels such as good, fair, and poor when evaluating performance (2009).215
- Lab-type studies have also been used to assess the potential impact of quality information on a decision. One study found that CAHPS increased perceptions of the availability of information on plan performance (2002)212 and another study of family members or agents for Medicare beneficiaries found that people say they want more information but time constraints and the increased cognitive burden decrease the likelihood it will be used (2007).214
- One lab-type experiment suggested that some presentation approaches like visual cues might improve comprehensibility but others like ordering health plans by cost or member satisfaction or presenting trend data may result in consumers’ decisions that undermine their self-interest (2002).218
- The difference in public report comprehension between nonelderly and the Medicare population was evaluated by another lab-type experiment. The results indicate that after controlling for education, the elderly had more difficulty understanding and using comparative information to make health plan choices (2001).217

One lab-type experiment explored a topic not considered in other identified studies. It focused on the impact of context information along with report cards on health plan choices.

- The context information made a difference in the understandability of the measures but was insufficient to influence decisions and made no real difference on health plan choice because the individual indicators were often misinterpreted. Thirty-eight percent of the group who were provided the report card without context information said they did not know how the plans educated and informed members compared with 11 percent in the context group (1996).216

Other lab-type experiments explored the tradeoffs people are willing to make when selecting plans.

- In one study HMOs and PPOs were given different hypothetical CAPHS ratings and costs and people were more likely to pick the scenario where the plan with the higher CAPHS rating cost less but covered less (2000).207
- In scenarios including quality information and the choice between HMOs and traditional Medicare, the quality information did not increase HMO selection over traditional Medicare, but did impact choices among HMOs (2002).210
- In a study that examined the impact of specific indicators on people’s willingness to accept plan restrictions, the researcher found this varied by indicator, with people more likely to accept restrictions if the rating was high for members being extremely satisfied with care (2002).211

##### Employers/Purchasers

Four surveys/interviews asked employers about how they selected plans to offer as options to their employees.

- An interview with 33 large health care purchasers suggested that the use of clinical quality information among purchasers was relatively low. Seventy-eight percent reported that HEDIS data were available to them but only 50 percent used the data in New York and California, 57 percent in Pennsylvania, and 60 percent in Cleveland, Ohio. The hospital outcomes data usage was low with 0 percent in New York and Pennsylvania, 20 percent in California, and 80 percent in Cleveland, Ohio (1997).206
- A study in 1998 suggested that only 5 percent of employers consider, or are even aware of, HEDIS data when selecting health plans for employees and only 1 percent of them provided the HEDIS performance data to their employees (1998).190
- One study reported that 58 percent of employers used some source of quality information when making their decision about health plans to offer employees.186 (2001)
- Other researchers found that just over half of the employers studied considered HEDIS and CAHPS ratings when selecting plans to offer and that this did not vary by company size (2007).188

##### Health Plan Leadership/Sponsors

- One study combined the findings from interviews and focus groups conducted over 3 years with representatives of managed care plans who were subject to public reporting of CAHPS results. Credibility of the report increased, concerns decreased over time, and managed care representatives reported increasing their QI efforts in response to low scores. One expected finding was that the organizations were reluctant to share best practices with others due to competition for better ratings (2001).193
- Similarly, interviews with leaders at 24 plans in six States found that despite having issues with the cost of collecting HEDIS information and the specificity of the information, 77 percent of interviewees reported QI activities were identified as a response to performance measurement, with 37 percent attributed directly to the public reporting of HEDIS and 6 percent to CAHPS reports (2001).203
- Interviews with public agencies and business coalitions that sponsored CAHPS found that sponsors were invested in producing and disseminating reports annually (80 percent, or 20 out of 25 interviewed) and were using various media (Web, 100 percent; written materials, 96 percent) to disseminate the reports (2007).204
- Another survey asked medical directors of health plans if they changed policies and practices in response to the reporting of HEDIS measures and 54 percent reported they revised guidelines and 62 percent reported that they began measuring screening rates (2008).189

### Long-Term Care Services

Prior systematic reviews of public reporting do not contain studies of reporting on the quality of long-term care services either because the searches predated major national initiatives in public reporting of the quality measure for this setting, or the search strategy, inclusion criteria, and types of designs allowed precluded inclusion of studies of public reporting about long-term care (e.g., Fung,15 Marshall,221 and Ketelaar222) The Centers for Medicare and Medicaid Services (CMS) began posting quality data on the Medicare Nursing Home Compare Web site in 2002 and on Home Health Compare in fall 2003.

Selecting a long-term care (LTC) service may be substantially different than selecting other health care services. Decisions about LTC may be likely to involve family members. They may be made during a hospitalization to expedite discharge with the involvement of discharge planners or social workers. Alternatively people may be admitted from the community when disease progression and functional impairments require more than outpatient management. Nursing homes (NHs) (alternatively referred to as nursing facilities or skilled nursing facilities) and home health agencies admit people from hospitals and the community. Nursing homes provide postacute care to people who are expected to improve (referred to as short-stay residents) as well as care for long-stay residents with degenerative or debilitating conditions who are likely to need care for an extended period. Similarly, home health agencies provide postacute care and also admit people from the community with long-term chronic care needs.

Long-term care organizations and individuals that provide care (collectively referred to as “providers”) and quality improvement efforts might also differ from acute care and health plans. As the market areas are different for LTC, the choices may be greater when there is some substitution among types of services (NH, home health, assisted living, etc.). Conversely, the choices may also be more limited when only one provider is available in a geographic area or a location near family is more important than any other consideration. Many LTC service providers are for-profit yet public payers (Medicare and Medicaid) are major sources of revenue. For this reason and due to a history of financial crime, unsafe conditions, and abuse, long-term care services have traditionally been heavily regulated. Combined with the need to serve two very different populations, short-stay and long-stay residents, these factors create a challenging environment. While the underlying theory of how public reporting may lead to quality improvement is the same across settings, the different environment and history may affect its potential impact on long-term care differently than how public reporting affects hospitals, individual clinicians, and health plans.

We identified 23 quantitative observational studies and six qualitative studies that met our inclusion criteria and corresponded to our Key Questions. The observational studies are described and analyzed first. This is followed by a summary of the qualitative studies.

#### Overview of Findings

##### Quality of Care (Key Question 1)

- Some QMs, but not all, improved after public reporting (seven studies).
  ○ Measures for short-stay residents of nursing homes showed improvement across studies (two studies).13,58
  ○ For long-stay residents improvement was less consistent. The measures that improved across multiple studies were physical restraints and pain while the rest of the measures had no improvement or mixed results (five studies).59–63
- Public reporting for LTC is a national program. This makes it challenging to design studies where the improvement can be attributed to the public report.
  ○ The one study that controlled for regression to the mean concluded that there was improvement above what could be explained by regression to the mean.60
  ○ Most studies used prior periods to examine trends62,63,74,80,81,106,108,109,223 while more recent studies constructed a comparison group consisting of small NHs not included in NH Compare or compared outcomes for pilot and non pilot status.13,61,73,75,107 However, many studies were “post only” designs that made it difficult to determine if the public report contributed to the change.14,59,60,115,224

##### Harms (Key Question 2)

- Five studies examined different harms (selection/cream skimming, crowd out, rehospitalization, and down coding) that correspond to actions NHs may take to improve NH Compare ratings rather than actually improve the quality of care.
  ○ One study found some evidence that the number of patients admitted with pain declined among NHs after they had low-quality scores reported for pain. Level of pain on admission also declined and among for profit and nonprofit NHs compared with government NHs. The study authors concluded this indicates some cream skimming.72
  ○ Another study that looked at patient sorting among NHs for postacute care73 found no cream skimming, rather that high-risk patients were more likely to be admitted to high quality facilities after public reporting
  ○ No evidence was found that quality in other areas was crowded out by NHs focus on the publicly reported measures (one study).74
  ○ Indications of “down coding,” that is changing the coding of assessments in order to improve NH Compare scores were found in a study of postacute care, but for only one (pain) out of three quality measures (one study).73
  ○ The most serious harm identified to date is that NHs may re-admit postacute care patients to the hospital before they are assessed for NH Compare in order to improve their performance (one study).75

##### Impact on Providers (Key Question 3)

- NH administrators reported in surveys that they were taking action in response to NH Compare (three studies).63,78,79
  ○ Actions appeared to be motivated more by the administrators’ belief that public reporting influences referral from professionals and the State survey process than by patient and family use of NH Compare in their selection of NHs.
  ○ Nursing homes that reported taking actions experienced improvements in quality measures.63
  ○ An additional study documented that NH administrators invested more resources in clinical care after public reporting.80
  ○ Improvement in one QM (influenza vaccination rates) improved after public reporting, but it increased even more among community dwelling elderly, supporting the idea that factors other than public reporting may be driving change (one study).81

##### Impact on Patients or Purchasers (Key Question 4)

- Six studies attempted to determine if public reporting influenced the selection of NHs
  ○ One study looked at patient selection and used a problematic outcome measure (occupancy rate) that may have limited variation or be caused by factors other than patient selection.106
  ○ Two studies used market share to measure NH selection, with one finding no impact from the reporting of five indicators for long-stay residents on market share61 and one finding small increase in market share for postacute care associated with higher NH Compare ratings.107
  ○ Patient matching, meaning higher-risk patients selected higher-quality NHs, was found to increase after public reporting (one study).73
  ○ Increase in selection of NHs with better performance on NH Compare by Medicare patients was demonstrated to be the link between higher-quality and better financial performance and this relationship was stronger after NH Compare was made public (two studies).108,109

##### Public Report Characteristics (Key Question 5)

- No studies were identified.

##### Context (Key Question 6)

- Studies that examined the impact of two market characteristics, competition and occupancy rates (characteristics of the environment), found that publicly reported quality measures are more likely to improve in competitive markets and in markets with low occupancy rates (suggesting there are choices and providers must compete to fill beds).60,61,115
  ○ These findings supported the idea that public reporting provides information that influences market-based behavior.
- Ownership characteristics of NHs (e.g. for profit/nonprofit, government, chain affiliation, hospital-based) did not have a consistent effect on the impact of public reporting (two studies).59,62
- One study found that NHs with higher percentages of black residents had smaller changes in quality after public reporting, but that for some indicators they started with better QMs than NHs with fewer black residents.62
- Nursing homes and home health agencies that started with lower publicly reported quality ratings were more likely to improve their ratings than those that started with higher scores (three studies).14,78,81
- Only one study included any analyses by patient characteristics other than their baseline risk on the QMs. A study of patient selection for postacute care found that patients with higher levels of education were slightly more responsive to public reporting.107

#### Description of Quantitative Studies

We identified 23 observational studies about public reporting on long-term care services (see Evidence Tables in Appendix N) and reported on the results of 22. One study was not included after inconsistencies were identified in the reported results.225 All these studies were published between 2005 and 2012. One study was about home health care services14 and the rest concerned NHs. All studies were conducted in the United States and used national data or a sample based on national data.

The populations in the studies were both organizations that provide long-term care (nursing homes and home health agencies) and patients/families/payers that select and use these services. Nursing homes or home health agencies are assumed to respond to public reporting by improving care practices that lead to improvements in the reported quality measures as well as other health care outcomes. Patients or payers are assumed to respond by selecting higher quality NHs or home health agencies. However, selection was not measured directly in any of these studies. In the studies where patient choice was the outcome of interest, occupancy rate106 and market share61,107 were used to represent selection.106

The public reporting intervention in almost all of the identified studies was NH Compare. Fifteen of the studies concerned public reporting of quality measures for both long-stay and short-stay nursing home residents. Of these, thirteen studied some aspect of the impact of NH Compare,59–63,72,78,79,81,106,109,115,226 while one focused on a designation given by CMS to facilities with chronically poor quality (Special Focus Facilities [SFFs])224 and one analyzed State survey deficiency and staffing level information that was made public prior to existence of quality indicators on NH Compare.106 Six studies were about NH Compare but limited their scope to the quality measures for short-stay, or postacute, residents.13,58,73–75,107 We identified one study about Home Health Compare.14

Nursing Home Compare and Home Health Compare are nationwide public reporting programs that include almost all nursing home and home health agencies certified by Medicaid and Medicare. Only those agencies that accept solely private payments and those with small numbers of patients/residents are excluded. Nursing Home Compare was initially launched in six States (Colorado, Florida, Maryland, Ohio, Rhode Island, and Washington) as a pilot in April 2002, then 7 months later in November 2002 it became available nationwide. This has affected what comparators and study designs have been possible (see Appendix D for definitions of the study design terminology used in this report). This also influenced the quality assessment of the studies and is the reason confounding and similarity across compared groups or compared time periods were given more weight than other criteria (see Appendix G for the quality assessment for these studies and Appendix F for a description of the quality assessment criteria). Twelve studies were assessed as good quality, nine as fair quality, and one as poor quality in terms of their ability to rigorously address our Key Questions.

The most common type of study we identified was “interrupted time series” (nine studies), in which data on quality measures from periods prior to NH Compare were compared with periods after NH Compare was made public in 2002.^62,63,74,80,81,106,108,109,223^ Three additional studies were “multiple group interrupted time series” that compared multiple time periods before and after NH Compare for two groups. These three studies compared pilot and nonpilot NH Compare States61,73,75 for the 7 months before NH Compare was nationwide within the context of trends for both groups. Two studies, one time series13 and one pre-post,107 used a group of small NHs not required to report in NH Compare as a comparison group. Five other studies included data from periods only after the quality data were made public: two were “time series post only” studies that examined change and trends after NH or Home Health Compare;14,59 two were “one group post only” that quantified a change from one time period to another after NH compare;60,115 and one “comparison group post only” study compared NHs in counties with and without a NH designated as chronically poor quality by CMS – a SFF – after these facilities were publicly identified.224 Two studies were cross sectional and based on survey data.78,79 One other study with pre and post NH Compare data included a “one group pre post” study in which MDS data was used to calculate the values of the quality measures before they were publically reported and then compared these with scores for the 12 months after they were publically reported by NH Compare.58

The most frequent outcomes in these studies were changes in the publicly reported quality measures reported in eight articles (seven studies), either overall (Key Question 1) or compared across provider or market characteristics (Key Question 6). Four studies examined potential harms (Key Question 2) and used different outcomes including characteristics of admission cohorts before and after public reporting to determine if NHs were choosing not to admit people who could negatively impact their quality rating; performance on measures not publicly reported to determine if NHs focused on improving the publically reported measures to the detriment of other aspects of care; trends in assessments to determine if NHs changed how assessments were coded; and rehospitalizations of patients to avoid their inclusion in the NH Compare measures. Three of the five studies that reported on changes in health care delivery (Key Question 3) used survey responses by NH administrators about actions they have taken in response to public reports. The other two examined whether NHs increase clinical expenditures and one other looked at changes in vaccination rates in response to public reporting. The only study that looked at changes in patients’ or purchasers’ behavior (Key Question 4) used occupancy rates as the outcome measure. None of these studies of long-term care services examined the impact of characteristics of the public report (Key Question 5). Twelve studies specifically addressed the impact of context, such as market characteristics or characteristics of the NHs or their administrator, on the effectiveness of public reporting. Market characteristics studied included competition, occupancy rates, and the presence of chronically poor-quality nursing homes in the same market. Provider characteristics examined in identified studies included ownership (for profit/not for profit/government ownership), chain affiliation, percentage of Medicare residents, percentage of black residents, and high or low rating on QM in prior periods or at baseline.

Table 7 at the end of this section provides an overview of each included study and a summary of the finding.

Table 7 Summary of evidence: long-term care services

Key Question 1: Does public reporting result in improvements in the quality of health care (improvements in health care delivery structures, processes, or patient outcomes?

Key Question 2: What harms result from public reporting?

Key Question 3: Does public reporting lead to change in health care delivery structures or processes?

Key Question 4: Does public reporting lead to change in the behavior of patients, their representatives, or organizations that purchase care?

Key Question 5: What characteristics of public reporting increase its impact on quality of care?

Key Question 6: What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care?

Author Year (QA) | Public Report | Study Overview | Key Question | Results ↑ Improvement; ↓ Worse; ↔ No difference
Cai 2010^81^ (Fair) | NH Compare | Compared State vaccination rates for three flu seasons (2005–2006, 2006–2007, 2007–2008) after the publication of vaccination rates in NH Compare. Rates for NH residents compared with rates for community dwelling elderly. N=51 (all States and DC). | 3 | State vaccination rates change with NH Compare ↑ Vaccination rate: Short-stay and long-stay residents ↔ Larger increase in community-dwelling elderly than in NH residents
Cai 2010^81^ (Fair) | NH Compare | | 6 | ↑ More improvement among NHs with lower baseline rate ↓Slight decline among NHs with higher baseline rate
Castle 2007^115^ (Fair) | NH Compare | Compared publicly reported QMs for U.S. NHs in markets with high competition and low occupancy rates to NHs in markets with low competition and high occupancy rates in 2003 and 2004. N=14,554 | 6 | [underlined: Higher Competition] ↑ 5 out of 14 QMs improved and overall improvement Long Stay: ADLs, low risk pressure sores; short stay: delirium, pain, pressure sores ↔no significant effect: 9 out of 14 QMs [underlined: Lower Occupancy] ↑ 8 out 14 QMs improved and overall improvement Long stay: ADLs, low risk pressure sores, catheter, ability to move around Short stay: delirium, pain, pressure sores ↔no significant effect: 7 out of 14 QMs
Castle 2008^60^ (Fair) | NH Compare | Examined trend in improvement post public reporting adjusted for regression to the mean for U.S. NHs from 2004 to 2006. Subgroup comparisons by market characteristics. N=14,224 | 1 | ↑ 9 of 15 QMs Long stay: pain, high risk PU, low risk PU, restraints, depressed, catheters Short stay: delirium, pain, pressure sores ↓ 5 of 15 QMs Long stay: ADLs, incontinence, move about, UTI, lose too much weight ↔ 1 of 15 QMs Long stay: mostly in chair or bed
Castle 2008^60^ (Fair) | NH Compare | Examined trend in improvement post public reporting adjusted for regression to the mean for U.S. NHs from 2004 to 2006. Subgroup comparisons by market characteristics. N=14,224 | 6 | [underlined: Higher Competition] ↑ 8 out of 15 QMs and overall Long stay: ADLs, high risk pressure sores, depressed, most time in bed or chair, UTI, lost too much weight Short stay: delirium, pain ↔no significant effect: 7 out of 15 [underlined: Lower Occupancy] ↑ 10 out 15 QMs and overall Long stay: ADLs, low risk pressure sores, restraints, depressed, incontinence, UTI, ability to move around, lost too much weight Short stay: delirium, pressure sores ↔no significant effect: 7 out of 14 QMs
Castle 2010^224^ (Fair) | Special Focus Facility designation by CMS (on Nursing Home Compare) | Compared all U.S. NHs divided by whether they are in counties that had one or more special focus facility in 2007 (n=135) compared with NHs in counties where none had this designation. (N=14,1553) | 6 | Impact on quality measure of SFF in same county ↑4 out of 22 QMs High-risk PU, low-risk PU, UTI, short-stay PU ↓2 out of 22 QMs Any deficiency, quality citations ↔ 16 out of 22 QMs ↑8 out of 22 QMs when only facilities below the median level of quality are analyzed
Gaudet 2011^62^ (Good) | NH Compare | Examined how NH performance changed in response to public reporting and how this varies across market and facility characteristics, particularly the proportion of black residents in NHs. N=over 14,500 NHs (exact n varies for each quarter) | 1 | Change in NH Compare QMs ↑Restraints, pressure ulcers, pain ↓ADLs
Gaudet 2011^62^ (Good) | NH Compare | | 6 | ↔ Percent no significant effect of Medicare residents, nonprofit ownership, market competition on QMs ↔ Percent Black residents had no significant effect overall; NH with higher percent Black residents started a higher quality pre public reporting on some QMs. NH Compare had less of an impact (slope of change was less) on facilities with higher percent Black residents compared to facilities with lower levels of Black residents
Grabowski 2011^61^ (Good) | NH Compare | Evaluated the effect of NH Compare on facility performance and consumer demand for services in pilot and on pilot States. N=15,553 NHs | 1 | QMs post NH Compare; comparison of pilot and non pilot States ↔ No impact on 5 of 5 QMs
Grabowski 2011^61^ (Good) | NH Compare | Evaluated the effect of NH Compare on facility performance and consumer demand for services in pilot and on pilot States. N=15,553 NHs | 4 | ↔ No impact of 5 publicly reported QMs on market share
Grabowski 2011^61^ (Good) | NH Compare | Evaluated the effect of NH Compare on facility performance and consumer demand for services in pilot and on pilot States. N=15,553 NHs | 6 | [underlined: Higher competition] ↑2 of 5 QMs High-risk PU, low-risk PU ↔ 3 of 5 QMs
Jung 2010^14^ (Fair) | Home Health Compare | Described change in quality measures from 2003 to 2007 (yearly measures) and change by Home Health Agency Characteristics. N=8,679 agency with at least 2 years of data. | 1 | Change in QMs post HH Compare ↑7 of 7 functional measures Number of QM for which agencies changed quality indicator scores ↑ 6 of 7 more agencies improved ↓ 1 of 7 more agencies worsened
Jung 2010^14^ (Fair) | Home Health Compare | Described change in quality measures from 2003 to 2007 (yearly measures) and change by Home Health Agency Characteristics. N=8,679 agency with at least 2 years of data. | 6 | ↑ Nonprofit started lower than for profits on some QM, but had greater improvement and ended with higher scores on all QMs ↑ hospital-based had greater improvement ↑ longer Medicare tenure had greater improvement ↑ lower baseline QMs increased more
Konetzka 2012^75^ (Good) | NH Compare | Analyzed if NHs responded to public reporting by rehospitalizing postacute care patients who might have a negative impact on their NH Compare scores before they are assessed (Day 14) for NH Compare scores. N=8,139 NHs | 2 | ↓ 1.2% increase in discretionary rehospitalizations. 0.5% after controlling for secular trends by comparing pilot and non pilot States. Increase greater in patients at higher risk of poor scores on NH Compare QMs
Mukamel 2008^63^ (Good) | NH Compare | Compared quality scores for all U.S. NHs. Pre Public Reporting(4th Q 2001 to 4th Q 2002) and Post Public Reporting: (1st Q 2003 to 4th Q 2003). Merged with survey responds for 10% sample of administrators. 724 completed survey (48.2%) | 1 | ↔0 of 5 for time trend ↑2 of 5 for change in level after public report: physical restraints, short-stay pain ↓ 1 out of 5: pressure ulcers (in non demonstration States) ↔2 out of five: ADLs, infection and PU in demo States.
Mukamel 2008^63^ (Good) | NH Compare | | 3 | Change in QMs with number of actions taken ↑ With increase in actions: Physical restraints, short-stay pain ↓ With increase in actions: Pressure Ulcers ↔ With increase in actions: ADL and Infections
Mukamel 2009^72^ (Fair) | NH Compare | Compared NH admission cohorts for all U.S. nursing homes for periods pre and post reporting as well as after changes in 1st Q 2004. Pre Reporting: 1st Q 2001 to 4th Q 2002. Post Reporting: 1st Q 2003 to 4th Q 2005. N=16,745 | 2 | ↔ No significant change in admission cohorts indicating no cream skimming ADL, diabetes, incontinence, PU stage 2 or higher ↓ Decrease indicating cream skimming Pain and memory loss
Mukamel 2009^72^ (Fair) | NH Compare | | 6 | Change in admission cohorts by NH characteristics ↔ADL, diabetes, incontinence, PU stage 2 or higher Reduced admissions ↓ Pain: for profit and nonprofit reduced admissions, government NH did not Memory loss: for profit and chain reduced admissions
Mukamel 2010^80^ (Fair) | NH Compare | Compared ratio of clinical to hotel expenses by NHs for 2 pre report-card years and 4 post public report years including 10,022 NHs over 6 years from 2001 to 2006 (54,235 observations). | 3 | ↑ by 5% in the ratio of clinical to hotel expenditures post public report Magnitude of effect reduced significantly by controlling for differential growth in costs.
Mukamel 2010^80^ (Fair) | NH Compare | Compared ratio of clinical to hotel expenses by NHs for 2 pre report-card years and 4 post public report years including 10,022 NHs over 6 years from 2001 to 2006 (54,235 observations). | 6 | ↑ Ratio for NH with: Lower-quality scores Lower occupancy For profit Chain owned More competitive markets
Park (13080) 2011a108 (Good) | NH Compare | Examined if high quality NHs or NHs that improve on publicly reported quality scores receive a return in terms of financial performance by increasing admissions by comparing 1999–2002 to 2003–2006. N=6,286 NHs | 4 | Improvement in NH Compare QMs leads to ↑ Market share, specifically increased Medicare admissions leading to better financial performance (higher revenues) If NHs is High Quality based on NH Compare QMs than ↔ Market share and financial performance relationship do
Park (12601) 2011b109 (Good) | NH Compare | Explored if public reporting changes the relationship between financial performance and quality of care in NHs prior to NH Compare (1997–2002) vs after NH Compare (2003–2006). N=9,444 NHs | 4 | Interaction between profit margin and QMs ↑ 3 of 4 QMs the association between profit margin and QMs was stronger after public reporting (total staff hours per resident day, incidence of pressure ulcers, number of deficiency citations) ↔ 1 o4 QMS the association between profit margin and restraint use was not significantly different after public reporting
Park (12601) 2011b109 (Good) | NH Compare | Explored if public reporting changes the relationship between financial performance and quality of care in NHs prior to NH Compare (1997–2002) vs after NH Compare (2003–2006). N=9,444 NHs | 6 | For profit vs. nonprofit ↑ For profit: 3 of 4 QMs stronger association between profit margins and QMs after public reporting ↑ Nonprofit: 1 of 4 QMs stronger association between profit margins and QMs after public reporting Competitive Markets ↑ greater increased association between profit and quality in competitive markets after public reporting
Stevenson 2006^106^ (Poor) | Nationally posted Deficiencies and Staffing Levels for NHs | Compared Pre Reporting: 1996 - Oct. 15, 1998 (1996, 1997, 1998) to Post Reporting Years: (1999, 2000, 2001, 2002). | 4 | Change in occupancy rate as measure for patient selection Post quality rating: ↑ Increase in occupancy with fewer prior deficiencies, with fewer prior serious deficiencies with more LPN/RN staff ↓Decrease in occupancy with more aide staff (contrary to hypothesis)
Werner 2009a13 (Good) | NH Compare for Post Acute care | Compared all NHs with residents with postacute stays of at least 14 days pre 2002 NH Compare launch vs. post NH Compare and compared these to small nursing homes not included in NHC. N= 8,137 in NH Compare; 2,777 small NHs | 1 | ↑ 3 of 4 QMs Pain, delirium, walking ↓1 of 4 QMs Preventable rehospitalization Incorporation of secular trend ↑3 of 4 QMs Pain, smaller magnitude Delirium: no change in magnitude Walking: slight increase in magnitude ↓1 of 4 QMs Preventable rehospitalization Slight worsening, then stable but did not improve.
Werner 2009b74 (Good) | NH Compare for Post Acute Care | Compared all U.S. NHs using MDS data pre NH Compare and post NH Compare on postacute care measures on NH Compare. N=13,683 | 2 | Change After NH Compare ↑3 of 3 publicly reported QMs Pain, delirium, walking Not publicly reported QMs for same period ↑5 of 9 QMs Pain, locomotion, shortness of breath, incontinence, respiratory infection ↓4 of 9 UTI, ADLs, mid-loss ADLs, early-loss ADLs Non publicly reported for NHs with high score on publicly reported ↑6 of 9 QMs Pain, locomotion, shortness of breath, incontinence, respiratory infection, UTI ↓3 of 9 QMs ADLs, mid-loss ADLs, early-loss ADLs ↓Nurse staffing decline less for high score than low score on reported measures
Werner 2010^58^ (Good) | NH Compare for Post Acute Care | Compared all NHs reporting postacute measures twelve months before Public Report to twelve months after launch of NH Compare. Disaggregates change into portions due to QI, market share and residual N=8,137 | 1 | Post acute care measure change post NH Compare ↑ Pain overall ↑Pain due to QI ↑Pain due to market share ↓Pain due to residual ↔Delirium overall ↔Delirium due to QI ↑Delirium due to market share ↓Delirium due to residual ↔walking overall ↑Walking due to QI ↑Walking due to market share ↓Walking due to residual
Werner 2011^73^ (Good) | NH Compare for Post Acute Care | Compared pilot and non pilot States prior to and after NH Compare to determine if public reporting results in changes in the types of people choosing high and low quality providers (patient sorting) occurred for postacute care. N=8,139 NHs | 2 | Cream skimming ↔No evidence NHs admitted lower risk patients in order to improve NH Compare scores Down coding ↓Change in admission levels of pain (lower after public reporting) suggests facility may be down coding high risk patients
Werner 2011^73^ (Good) | NH Compare for Post Acute Care | | 4 | Patient sorting; high risk patients admitted to higher quality NHs ↑ 1 of 3 QMs. Pain (correlation between higher risk on admission and high quality increased after NH Compare. 10 point higher NH Compare score associated with 1% point increase in admission pain level for following quarter ↔ 2 of 3 QMs Delirium and difficultly walking. No change
Werner 2012^107^ (Good) | NH Compare for postacute care | To determine if public reporting influences patients’ selection of NHs for postacute care. | 4 | Selection of NHs (market share) ↑ 1 of 3 QMs; Pain Change in a Pain score from 25^th^ to 74^th^ percentile (fewer patients with pain) increases market share 1.3% ↔ 1 of 3 QMs; Delirium near zero ↓ 1 of 3 QMs; Walking Counter intuitive result: improvement in score associated with decline in market share
Werner 2012^107^ (Good) | NH Compare for postacute care | To determine if public reporting influences patients’ selection of NHs for postacute care. | 6 | Patient Education Level ↑ 3 of 3 QMs larger response to public reporting by patients with higher (High school or more) education level NH Occupancy/Capacity Constraints ↑ Greater impact on selection in markets with lower occupancy (lower capacity constraints Not reporting in NH Compare ↓ Smaller NHs not required to publicly report lose market share after public reporting, suggesting patients interpret the lack of data as a sign of poor quality.
Zinn 2005^59^ (Fair) | NH Compare | Assessed quality improvement using NH Compare quarterly reports from November 2002 (first publication) through January 2004 for all NHs reporting. (N=over 13,00 for long-stay resident measures, over 9,000 for short-stay resident measures) | 1 | Post NH Compare: ↑Long stay: pain, physical restraints Short stay: delirium, pain ↔Long stay: daily tasks, PU, PU risk adjusted, infection Short stay: delirium risk adjusted, walking
Zinn 2005^59^ (Fair) | NH Compare | | 6 | Characteristics compared on rate of improvement. End level was still higher even though improvement is faster for NH with characteristics (the trend lines do not cross) Long Stay Residents ↑ Pain higher rate of improvement in hospital-based vs. not hospital-based Short Stay Residents ↑ Delirium higher rate of improvement with low occupancy rate vs. high ↑ Pain higher rate of improvement in non chain vs. chain NH
Zinn 2008^79^ (Good) | NH Compare | Cross-sectional comparison of response to NH Compare by different types of strategic orientation: Prospectors changed frequently and valued innovation and flexibility. Defenders focused on core services and emphasize operating efficiencies. Analyzers blended characteristics of the first two. Reactors lacked a strategy. Survey responds for 10% sample of administrators. 724 completed survey (48.2%) | 3 | 37% took immediate action due to NH Compare; 30% took no action Found differences in responses by strategic type of administrator; - Respond immediately: Prospectors; - Take no action: Defenders; - Communicate with families about public report: No strategic type; - Investigate reasons for scores: Prospectors and analyzers; - Revise job descriptions: Prospectors; - Invest in equipment of technology: No strategic type
Zinn 2008^79^ (Good) | NH Compare | | 6 | 37% took immediate action due to NH Compare; 30% took no action Characteristics of NH more like to take these actions:; - Respond immediately: Nonprofits, high competition; - Take no action: Poor initial quality, low competition; - Communicate with families about public report: High competition, chain; - Investigate reasons for scores: Poor initial scores; - Revise job descriptions: Poor initial scores; - Invest in equipment of technology: different by no NH characteristics
Zinn 2010^78^ (Fair) | NH Compare | Likelihood of investing resources to response to NH compared by administrator perceptions and NH characteristics. 10% random sample of NH administrators at all facilities with at least one quality measure reported on NH Compare in 2006. 538 responses from1407 contacted (38.3%) | 3 | Likelihood of resource intensive changes in response to perceptions of NH Compare influence Believe NH Compare Influences Referrals ↑4 out of 6 actions ↔ 2 out 6 Believe NH Compare Influences Choice of NH ↑1 out of 6 actions ↔5 out 6 Believe NH Compare Influence State Survey ↑5 out of 6 actions ↔1 out 6 Have Managed Care Contract ↓ 3 out of 6 actions ↔ 3 out 5
Zinn 2010^78^ (Fair) | NH Compare | | 6 | ↑3 out of 6 actions More likely if NH had low-quality scores as opposed to high-quality scores and is in a highly competitive market

Notes: ADL = activities of daily living; CMS = Centers for Medicare and Medicaid Services; NH = nursing home; PU = pressure sores or ulcers; QI = quality improvement; QM = quality measure; SFF = special focus facility; U.S. = United States; UTI = urinary tract infection

#### Effectiveness by Outcome/Key Question: Detailed Analysis of Observational Studies

The results for each Key Question are discussed below.

##### Key Question 1 Quality of Health Care

All seven studies that examined health care outcomes for long- or short-stay NH residents analyzed changes in the QMs reported in NH Compare. Improvement was noted in some QMs and others had no significant change, while for a few, quality worsened during the period of study. At its launch NH Compare included 10 QMs, but items were dropped and added during the first few years (see superscripts in Table 6). Four of the studies examined all the measures available at the time of the study period for their population of interest. Three studies61–63 were restricted to a more limited set of QMs that could be reliability constructed from prior data for a pretest/posttest comparison.

Table 6 Study findings: change in Nursing Home Compare quality measures

First Author, Year (Quality Assessment) | Zinn, 2005^59^ (Fair) | Mukamel, 2008^63^ (Good) | Castle, 2008^60^ (Fair) | Werner, 2009^13^ short-stay only (Good) | Werner, 2010^58^ short-stay only (Good) | Grabowski, 2011^61^ (Good) | Gaudet, 2011^62^ (Good)
Quality Measure
Long-Stay Residents
Increased help with daily activities | ↔ | ↔ | ↓ | NR | NR | ↔ | ↓
Pain | ↑ | NR | ↑ | NR | NR | NR | ↑
Pressure sores^a^ | ↔ | ↓ | NR | NR | NR | NR | ↔
Pressure sores risk adjusted^a^ | ↔ | NR | NR | NR | NR | NR | NR
High-risk with pressure sores^b^ | NR | NR | ↑ | NR | NR | ↔ | NR
Low-risk with pressure sores^b^ | NR | NR | ↑ | NR | NR | ↔ | NR
Physically restrained^c^ | ↑ | ↑ | ↑ | NR | NR | ↔ | ↑
More depressed^b^ | NR | NR | ↑ | NR | NR | NR | NR
Lose control of bowel or bladder^b^ | NR | NR | ↓ | NR | NR | NR | NR
Catheter^b^ | NR | NR | ↑ | NR | NR | NR | NR
Infection^a^ | ↔ | ↔ | NR | NR | NR | NR | NR
Most time in bed or chair^b^ | NR | NR | ↔ | NR | NR | NR | NR
Worse ability to move around^b^ | NR | NR | ↓ | NR | NR | NR | NR
Urinary tract infection^c^ | NR | NR | ↓ | NR | NR | ↔ | NR
Lose too much weight^b^ | NR | NR | ↓ | NR | NR | NR | NR
Short-Stay Residents
Delirium | ↑ | NR | ↑ | ↑ | ↔ | NR | NR
Delirium risk adjusted^a^ | ↔ | NR | NR | NR | NR | NR | NR
Pain | ↑ | ↑ | ↑ | ↑ | ↑ | NR | NR
Pressure sores^b^ | NR | NR | ↑ | NR | NR | NR | NR
Walking^a^ | ↔ | NR | NR | ↑ | ↔ | NR | NR

Note: ↑improvement; ↓worse; ↔ no change

a Included only in 2002 and 2003.

b Added in 2004.

c Added in 2003.

NR = not reported

Table 6 demonstrates that four QMs consistently showed improvement across studies while the results for most other QMs were mixed. Some of the QMs that were dropped after 2003 (e.g., infection) or added in 2004 (e.g., lose too much weight) have not been reported in enough studies to identify a pattern. Pain and physical restraints in long-stay patients as well as pain and delirium in short-stay residents have been reported since 2002 or 2003 and multiple studies have found improvement.

The one identified study of Home Health Compare14 found that QMs for patients’ ability to manage four activities (bathing, transferring, taking medications, and walking) and pain improved after the publication of Home Health Compare. Changes ranged from a 7.1 percent improvement for transferring to a to 18.9 percent improvement for ability to walk around. Need for urgent care remained stable while hospitalizations increased (interpreted as worse quality) during the study period.

##### Key Question 2 Harms

Four studies examined different potential harms that could result from public reports about LTC. Mukamel et al. (2009)72 examined whether NHs changed their admission patterns and admitted residents likely to improve the facility’s NH Compare scores; Werner et al. (2009b)74 investigated whether NHs would focus on the publicly reported measures to the detriment of other aspects of quality of care; Konetzka et al.(2012)75 analyzed whether NHs were rehospitalizing high risk postacute care patients before their first post admission assessment thereby improving the NH’s reported performance; and Werner (2011)73 searched for evidence of both cream skimming (preferentially admitting low risk patients) and down coding (assessing patients at lower levels of an indicator in order to improve performance ratings).

Mukamel et al.72 analyzed the characteristics of NH admission cohorts to determine if NHs responded to the public report by changing their admission policies. Specifically, they examined whether NHs admitted less sick or frail people in order to improve their publicly reported quality ratings. This is referred to as “cream skimming.” To do this they examined six characteristics of admission cohorts and found that four (ADLs, diabetes, incontinence, and stage 2 or higher pressure ulcers) did not decline in people admitted post NH Compare, suggesting that there was no cream skimming. For these four admission characteristics in which there was no decline, a decline was also not found in stratified analyses by NH types, suggesting the overall analyses were not hiding cream skimming within specific types of NHs. For two characteristics, pain and memory loss, there were small declines; a 13 percent decline in admissions related to the prevalence of pain and a 0.7 percent decline in admissions for memory loss. For pain the evidence of some cream skimming was seen across the subgroups by NH ownership and initial quality with no differences by chain affiliation or region. For profits and nonprofits were more likely to cream skim than government-owned NHs and but the strongest association was that NHs with poorer quality scores at initial publication were more likely to cream skim. For memory loss, the subgroups with more cream skimming were for profits and NHs with chain affiliation.

The harm, or unintended consequence, investigated by Werner et al.,74 was that NHs will invest their resources in improving performance on what is reported in NH Compare and the quality of other unreported aspects of care will deteriorate. The idea is that with limited resources, improvement in the reported measures will crowd out improvement in the unreported activities or outcomes. To investigate this Werner et al.74 compared quality indicators for short-stay nursing home residents that were publically reported with other indicators for which NHs submit data but are not included in the public reporting. Data were available for both public and nonpublic indicators prior to, as well as after, the release of NH Compare. This allowed analyses of the trend before and after public reporting as well as point estimates of the change. All three of the publicly reported QMs improved (pain, delirium, and walking) while the nine unreported measures were split with five showing improvement (improvement in pain, locomotion, shortness of breath, incontinence, and respiratory function) and four worsening quality (urinary tract infection, ADLs, mid-loss ADLs, and early-loss ADLs). The QMs that worsened were trending downward prior to 2002 when NH Compare was released. While that might suggest the decline was not caused by NH Compare, it does not negate that possibility that focusing on the publicly reported QMs preempted QI on these. However, stratified analyses found that facilities that scored highest on the reported QMs were more likely to improve on the unreported measures. This suggests that crowding out is limited and that the difference may be in the capacity of the NHs to implement QI.

Researchers used a unique aspect of public reporting about NHs to determine if providers might be rehospitalizing high-risk patients to keep these patients from having a negative impact on their NH Compare scores. The publicly reported measures for NHs were based on an assessment done on 14 patients after admission, but postacute care patients who were readmitted to the hospital before day 14 were not included in the NH Compare reporting. Konetzka et al.75 analyzed postacute patients with lengths of stay in NHs of 10 to 20 days both before and after the launch of NH Compare in both the pilot States and nationwide. They categorized all rehospitalizations for these patients as discretionary or non discretionary and indicated whether they occurred before day 14 or not. This analysis revealed a 1.2 percentage point increase in discretionary hospitalizations before day 14 that persisted, though it was smaller (0.5 percentage points) after controlling for trends in hospitalization by comparing the pilot and non pilot States. Furthermore, the patients rehospitalized before day 14 were at higher risk of scoring poorly on NH Compare than those rehospitalized after day 14, even after controlling for risk at admission. This suggests that NHs may admit high-risk patients despite the potential to negatively impact their publicly-reported performance and then use selective rehospitalization to limit the impact of these patients on their NH Compare quality reports. In addition to the implications for quality reporting and quality of care in NHs, this suggests that providers attempting to “game” public reporting may be able to do this at points other than admission.

Werner (2011)73 used data from 2001 through 2003 for the pilot and non pilot States to examine two potential harms/unintended consequences: whether public reporting changes what patients facilities admit and whether NHs change their coding in assessments in order to improve their NH Compare reports. The analyses found no evidence of “cream skimming”, that is NHs did not try to admit more low-risk patients or patients with a better prognosis. However there was some evidence of down coding in the assessment of pain, suggested by lower levels of pain recorded at admission after public reporting that was not explained by changes in other patient characteristics.

##### Key Question 3 Impact on Providers

Five studies of public reporting explored the impact of the NH Compare on behaviors of organizations and individuals who provide care.63,78,80,81,227

Three of the studies used surveys to collect information from nursing home administrators on their specific responses to NH Compare. Zinn et al.79 and Mukamel et al.63 used data from the survey that was mailed in May and June 2004 to a 10 percent sample of administrators of nursing homes that were included in the first publication of NH Compare. Of the 1,502 surveys sent, 724 were completed (48.2 percent). Zinn78 conducted another survey with different questions in 2007 that was also mailed to 10 percent random sample of administrators of NHs included in NH Compare in 2006. This second survey was sent to 1,407 administrators and returned by 538 (38.3 percent).

In the first survey Zinn79 asked administrators if they took any of seven actions in response to NH Compare, had the administrators complete items to identify their strategic orientation using an existing typology, and then assessed whether differences in strategic orientation were associated with different responses to NH Compare. Administers identified as the strategic type most likely to change frequently and to value innovations were most likely to take four actions: respond immediately, investigate reasons for the score, revise job descriptions, and change priorities for QI. The administrators who were of the strategic type that focused on core services were more likely to say they took no action. For two actions, talking to families about NH Compare and purchasing new equipment or technology, no differences were found among the administrators.

Mukalmel et al.63 used the same survey and merged the results with the data on the QMs for the NHs the administrators directed prior and post NH Compare. These data were first used to identify trends in improvement (reported above) and then used to determine if improvements were linked to actions by the nursing home administrators. An analysis of the number of actions taken suggested that when more actions are taken, the quality of NHs improves more, but that the marginal improvement decreases, indicating diminishing returns. Comparing different actions with improvement in specific QMs revealed no consistent associations, suggesting there were different routes to improvement.

The second survey by Zinn et al.78 collected information on perceptions of NH administrators on the influence of NH Compare on referrals, choice of facility, and the State survey process. The main outcome was the association of these perceptions with the likelihood an administrator would take one of six actions that required a significant investment in resources (hiring more clinical staff or new nursing or medical director, increasing wages, initiatives to hire and retain staff, and purchases of new equipment or technology). Administrators took the most actions when they thought NH Compare influenced the survey process but took only one action (hired additional staff) when they though NH Compare influenced selection of facility.

Using a different approach, Mukalmel et al.80 studied the ratio of clinical to hotel (room and board) expenditure by NHs before and after public reporting based on the theory that NH Compare made visible clinical quality that was once invisible and motivated greater investment in clinical care. The ratio of clinical to hotel expenditures was stable for 2 years prior to NH Compare then increased in the 4 years after NH Compare. This increase persisted, though it decreased in magnitude when the difference in growth in the prices of clinical and hotel services was added to the analysis. Subgroups expected to be more sensitive to public reporting (e.g. those in competitive markets, lower occupancy, for profit, and chain-owned) shifted more resources to clinical services.

Focusing on the provision of one service, Cai81 examined whether the State rate of flu vaccination in NHs changed after this was added to NH Compare in 2004. Vaccinations rates increased (5.46 percent for short-term residents and 1.67 percent for long-term residents) for two flu seasons after NH Compare compared with what they were the flu season prior to the public release of the data. However, immunization rates also increased 6.41 percent in community dwelling elderly, suggesting the increase may not be due to public reporting. Facilities that had low baseline rates were more likely to increase their vaccination rate than facilities that had high rates when the information was first made public.

##### Key Question 4 Impact on Patients or Purchasers

Six studies attempted to determine if public reporting influenced the selection of NHs by patients or residents. One of the earlier studies of NHs used occupancy rates as a proxy for choice of NH. Stevenson106 examined whether public reporting of deficiencies from State surveys and staffing levels that predated NH Compare reporting of QMs resulted in changes in occupancy rates. All of the alternative models supported the hypothesis that public reporting has an impact on selection of NH, but the effect sizes are extremely small: An increase in 10 deficiencies would result in 0.4 percent decrease in occupancy and doubling of nursing staff would be needed to increase occupancy 0.5 percent.

Grabowski and Town61(reported that NH Compare had no meaningful impact on selection based on an analysis of the impact of scores on five QMs (urinary tract infection, ADL loss, physical restraints, and pressure ulcers in high and low risk residents) on market share over several years (1999–2005) before and after NH Compare was launched.

Werner et al.107 also used market share to measure selection of NHs, but limited the sample to postacute care admissions and found that NH Compare resulted in small increases in selection of high quality facilities associated with only one of three QMs, suggesting that public reporting has had a minimal impact on consumers of postacute care. This was based on finding that improvements in the pain measure were associated with increases in market share after public reporting but that better scores on the delirium and improvement in walking had no impact, or a small negative effect on market share.

Three studies used outcomes other than occupancy and market share to study selection. Focusing on the acute care market again, Werner et al.73 asked whether high-risk patients were more likely to select high-quality NHs after NH Compare data were public. They analyzed patient admission characteristics and facility QMs for 2001 to 2003 and compared these over time, as well as across the pilot and non pilot States for NH Compare, and found significantly better matching (high-risk to high quality; low-risk to low quality) occurred after NH Compare was launched for pain but not for the other two QMs (delirium or improvement walking).

In two articles, Park108,109 explored issues related to how quality of care is related to financial performance and whether this was affected by public reporting. In one study108 data from 1999–2002 and 2003–2005 were used to compare revenues, expenses, operating, and total profit margin before and after NH Compare. Nursing homes that improved in quality had increased revenues and higher profit margins than NHs that stayed the same or were worse. The authors attribute this to increases in Medicare admissions.

The second article109 used ten years of data 1997 to 2006 to demonstration that quality is associated with better financial performance, but only after NH Compare is available nationwide. However, the size of the effect are small and most likely not clinically meaningful.

##### Key Question 5 Public Report Characteristics

We identified no empirical studies that examined the impact of characteristics of public reports on quality of care.

##### Key Question 6 Context

Several studies of public reporting of LTC focused on contextual factors.^c^ Two common characteristics of the environment or the market included in studies were the amount of competition and the occupancy rate. The underlying idea was that public reporting is a market-based intervention and that public reports will have a greater impact on provider behavior, selection of providers, and ultimately the quality of care in markets where there is more competition or a lower occupancy rate.

c Studies often include contextual factors as part of their major analyses in which they serve as control variables, allowing a sensitivity analysis or supplement for the primary comparison. When this was the case in the studies identified for this review, the results were discussed in the section on the Key Question addressed by the primary outcome. Studies were included here if the contextual factors were the focus of the study.

Three studies focused specifically on the impact of competition and occupancy rates. Castle et al.115 found that five out of 14 QMs were significantly better in markets with higher competition while eight out of 14 QMs were better in markets with lower occupancy rates based on data from 2002 to 2004. The same group of researchers continued to study this question using different data (2004 to 2006) and incorporating a control for regression to the mean.60 The results were similar with or without this control. Eight out of 15 QMs were significantly better in markets with higher competition while 10 out of 15 QMs were bettering markets with lower occupancy rates. The overall quality differences were also higher in high competition and low occupancy markets. Grabowski and Town61 analyzed data from 1999 to 2005 and found that for two (pressure ulcers, high risk and pressure ulcers, low risk) of five QMs studied significant improvements in quality were more likely to occur after public reporting in NHs in more competitive markets. Their model predicted that an increase in competition equivalent to going from two to five average size facilities in a market would result in an improvement in pressure ulcers among high-risk residents equal to 15 percent of a standard deviation and among low-risk residents 89 percent of a standard deviation.

Gaudet62 examined whether nonprofit ownership, market competition, and percentage of Medicare residents mediated the impact of public reporting and found no significant effect for nonprofit ownership or competition and a very small difference in improvement in performance associated by with a high percentage of Medicare residents after public reporting. Gaudet also tested whether NHs with higher percentages of black residents differed in terms of both their QMs and their response to public reporting. The results were mixed with gaps in baseline quality favoring NHs with more black residents for some quality indicators; however for three of the four measures studied, the change after NH Compare was smaller in these NHs when compared to NHs with fewer black residents.

As part of a study of how the relationship between financial performance and quality of care is influenced by public reporting, Park and Werner109 found that the association increased more after public reporting in competitive markets (5.3 percent) than in less competitive markets (1.9 percent). Changes in the relationship between financial performance and four specific quality indicators after public reporting were significant for only one indicator (number of deficiencies) while for profit NHs had significantly higher profit margins when quality was higher on three of four quality indicators after public reporting.

We identified one study of a less commonly studied market characteristic: the presence of a chronically poor quality facility in the NH market. Castle et al.224 examined a small number of extremely poor performers that were publicly given the designation of SFF by CMS. They then separated all other NHs based on whether they were in the same county as a SFF and analyzed whether being in a county with a SFF had an impact on quality. The underlying assumption was that being in proximity to a facility receiving extra attention for a history of poor quality might motivate quality improvement. Little evidence of this spillover effect was found with only four of 22 quality indicators significantly better among NHs in the same county as a SFF.

Other studies considered characteristics of NHs or Home Health agencies such as for profit/nonprofit, chain affiliation, or hospital-based/free standing either separately or in combination with market characteristics. In one of the early studies of NH Compare, Zinn et al.59 looked at the change in QM over the first five reporting periods (see results under Quality of Health Care above). For those QMs in which a change was found, the change was examined by NH characteristics. Few differences were found by facility characteristics. A difference was found in the rate of change, but what type of facility had the better score did not change.

In the only Home Health Compare study, Jung et al.14 found that nonprofits, hospital-based agencies, and agencies with longer Medicare tenure improved more from 2003 to 2007. Nonprofit agencies started with lower scores than for profits on some QMs, but had higher scores on all by the end of the study period.

Another characteristic of NHs and home health agencies included in several studies were their QMs at baseline. Zinn et al. reported that NHs with low QM scores are three times likely to make investments;78 Jung et al. reported that agencies with lower baseline scores experience greater improvement;14 and Cai found that NHs that started with low influenza vaccination rates were more likely to improve.81 Whether these types of results represent regression to the mean or a ceiling effect for those providers with high scores requires more in-depth investigation.

Werner et al.107 2012 included extension of their study of patient choice of NHs for postacute care to test whether responsiveness to public reporting varies across levels of education. They found patients with a higher level of education (high school or higher) were slightly more responsive to public reports than people with less than a high school education. While this difference was small it was evident across all three of the QMs (pain, delirium. and difficulty walking).

#### Summary of Qualitative Studies

We identified six qualitative studies that focused on public reporting for NHs and addressed at least one of our Key Questions. Two were surveys of NH administrators,12,228 two were surveys of consumers,229,230 and two were lab-type experiments used to test comprehension and preferences for alternative formats.231,232 The studies were published between 2005 and 2010 and one was conducted in the Netherlands231 while the rest were conducted in the United States.

##### Administrators

The two surveys of administrators described awareness and self-reported actions taken in response to NH Compare (Key Question 3).

- Castle et al.228 mailed a survey to a 30 percent random sample of NH administrators in two States without a State NH public report (Maryland and Pennsylvania) and two States with a State NH public report (Connecticut and Tennessee). Three hundred and twenty-four were completed out of 477 mailed, a 68 percent completion rate. The survey asked administrators first for their own ratings on content, then for their opinion on consumers’ perspective on comprehension, navigation, and decision process related to NH Compare. The survey was conducted in January 2003. At that time 33 percent of administrators had used NH Compare in their facility and 51 percent planned to in the future. Administrator ratings of NH Compare were relatively high for themselves and lower for residents/families. Most ratings were not statistically different for two States with prior NH public report than for two States without prior NH public reports (1998).
- The second survey used a 10 percent random sample of all U.S. NH administrators in May and June of 2004 and had a response rate of 42 percent (n=724).12 Eighty-two percent of administrators had reviewed NH Medicare Compare and 60 percent believed that quality of care influences the reported QMs (though high percentages also attributed the QM scores to coding, case mix, and unusual events). Sixty-three percent reported taking actions that could lead to improvement in quality of care such as investigator reasons for scores, 41.6 percent reported changing priorities for QI, and 36.3 percent reported changing care protocols. NHs with more QM scores in the bottom 20 percent of their State reported more actions in response to NH Compare (2007).

##### Consumers

- A survey of consumers also asked about awareness of NH Compare and how it was used in the selection of a NH (Key Question 4). The two studies reporting surveys of consumers had overlapping samples. One included a sample of family members of people recently admitted to one of 200 randomly selected NHs (2008).229 The second survey combined this NH sample with a survey of family members of people admitted to 25 randomly selected assisted living facilities in Pennsylvania and a survey of elders living to in 25 randomly selected senior high-rise housing buildings.
  ○ The survey of family members of newly admitted NH residents received 4754 responses, a 59 percent response rate. Respondents were asked about use of the internet and NH Compare in looking for information about NHs. Thirty-one percent reported using the internet and 12 percent specifically recalled using NH Compare. Respondents were then provided with a hard copy of NH ratings from the site and they were asked a series of comprehension questions. The comprehension scores were moderate to high (mean of 5.56 across all indicators with 8 being the maximum score).
  ○ In the study that combined the survey of families of NH residents with family members of assisted living residents (496; 61 percent response rate) and elders in high-rise buildings (1252; 63 percent response rate), internet use was also high (53 percent for Assisted Living family and 23 percent for community elders). (2001)230 The rates reporting that they looked at a public report on NHs were 29 percent for NH family members, 47 percent for assisted living family members, and 15 percent for community elders. The most frequent actual use of the public reports was to find the location (35 to 49 percent). Respondents examining quality information ranged from 29 percent to 47 percent.

Two lab-type experiments were relevant to Key Question 5 as they tested different hypothetical formats for actual NH public reports and explored what characteristics of public reports were most likely to result in their use.

- One study recruited 90 volunteers in two U.S. cities to view seven different formats for actual NH Compare information.(1999)232 Participants were asked closed-ended questions to assess their comprehension and ability to interpret the information, followed by probes about why they responded as they did, and questions about their preference for a format as well as ease of use. Key finding are that (1) people preferred an evaluative table with words (Better, Average, Worse) or stars to a bar graph; (2) a major barrier to understanding is the use of a negative direction (lower numbers are better), which people find confusing in spite of the labels and directions on report; and (3) people prefer to be able to compare several NHs on one page.
- The second lab-type experience was conducted in the Netherlands with three different samples in order to test a prototype of an internet public report about NHs (2005).231 The samples included 181 members of a consumers-of-care organizations (63 percent out of 300 invited), 38 university students (91 percent out of 42 invited), and 59 NH managers and staff (66 percent out of 70 invited). All were given one practice case and then randomly assigned six cases where the public reports differed in one component. They were asked questions about the quality of the NH presented in each case, whether they would choose that nursing home, and about the content and format of each public report. Overall rating of the public reports were high and did not differ across the three types of respondents, however care consumers rated the public reports lower on completeness and whether they were understandable. Participants selected the consumer satisfaction section as the most important of their decisions and interpreted missing information as a sign of low quality. When asked what else should be included, participants ask for more explanation of the terms used in the report and more information about the opinions of relatives, informal caregivers, and volunteers.