# References

1 McGlynn EA, Asch SM, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. Jun. 26. 2003;348(26):2635-45. [pmid: 12826639].
2 NCQA. The State of Health Care Quality: 2009. NCQA. 2009.
3 AHRQ. National Healthcare Disparities Report: Summary. February. 2004. Agency for Healthcare Research and Quality. 2004.
4 Sequist TD, Adams A, Zhang F, et al. Effect of quality improvement on racial disparities in diabetes care. Arch Intern Med. Mar. 27. 2006;166(6):675-81. [pmid: 16567608].
5 Institute of Medicine. Crossing the quality chasm: a new health system for the 21st century. Washington, DC. National Academies Press. 2001.
6 Closing the quality gap: revisiting the state of the science: series overview. Rockville, MD. Agency for Healthcare Research and Quality. April. 2011. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=715. Accessed May 4, 2012.
7 Akerlof GA. The market for ‘lemons’: quality uncertainty and the market mechanism. QJE. 1970;84(3):488-500.
8 Stigler GJ. The economics of information. JPE. 1961;69(3):213-25.
9 Grol R. Beliefs and evidence in changing clinical practice. BMJ. 1997;315(7105):418-21. [pmid: 9277610].
10 Hibbard JH, Stockard J, Tusler M. Does publicizing hospital performance stimulate quality improvement efforts?. Health Aff (Millwood). Mar–Apr. 2003;22(2):84-94. [pmid: 12674410].
11 Hibbard JH, Stockard J, Tusler M. Hospital performance reports: impact on quality, market share, and reputation. Evidence from a controlled experiment shows the long-term effects of reporting hospitals’ performance ratings to the public. Health Aff (Millwood). 2005;24(4):1150-60. [pmid: 16012155].
12 Mukamel DB, Spector WD, Zinn JS, et al. Nursing homes’ response to the nursing home compare report card. J Gerontol B Psychol Sci Soc Sci. Jul. 2007;62(4):S218-25. [pmid: 17673535].
13 Werner RM, Konetzka RT, Stuart EA, et al. Impact of public reporting on quality of postacute care. Health Serv Res. Aug. 2009;44(4):1169-87. [pmid: 19490160].
14 Jung K, Shea D, Warner C. Agency characteristics and changes in home health quality after home health compare. J Aging Health. 2010;22(4):454-76. [pmid: 20231725].
15 Fung CH, Lim Y-W, Mattke S, et al. Systematic review: the evidence that publishing patient care performance data improves quality of care. Ann Intern Med. 2008;148(2):111-23. [pmid: 18195336].
16 Hibbard JH, Sofaer S. Best practices in public reporting no1: how to effectively present health care performance data to consumers. Agency for Healthcare Research and Quality. 2010. Jun.
17 Sofaer S, Hibbard JH. Best practices in public reporting no2: maximizing consumer understanding of public comparative quality reports: effective use of explanatory information. Agency for Healthcare Research and Quality. 2010. Jun.
18 Sofaer S, Hibbard JH. Best practices in public reporting no3: how to maximize public awareness and use of comparative quality reports through effective promotion and dissemination strategies. Agency for Healthcare Research and Quality. 2010. June.
19 Hibbard J, Greene J, Sofaer S, et al. An experiment shows that a well-designed report on costs and quality can help consumers choose high-value health care. Health Aff (Millwood). 2012;31(3):560-8. [pmid: 22392666].
20 Smith M, Wright A, Queram C, et al. Public reporting helped drive quality improvement in outpatient diabetes care among Wisconsin physician groups. Health Aff (Millwood). 2012;31(3):570-7. [pmid: 22392668].
21 Young G. Multistakeholder regional collaboratives have been key drivers of public reporting, but now face challenges. Health Aff (Millwood). 2012;31(3):578-84. [pmid: 22392669].
22 Health 2.0. San Francisco, CA. Accessed March 1, 2011.
23 Jin GZ, Sorensen AT. Information and consumer choice: the value of publicized health plan ratings. J Health Econ. Mar. 2006;25(2):248-75. [pmid: 16107284].
24 Vaiana ME, McGlynn EA. What cognitive science tells us about the design of reports for consumers. MCRR. 2002;59:3-35. [pmid: 11877877].
25 AHRQ. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Agency for Healthcare Research and Quality. 2011. February.
26 Owens DK, Lohr KN, Atkins D, et al. AHRQ Series Paper 5: Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
27 Atkins D, Chang S, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
28 Hannan EL, Kumar D, Racz M, et al. New York State’s Cardiac Surgery Reporting System: four years later. Ann Thorac Surg. Dec. 1994;58(6):1852-7. [pmid: 7979781].
29 Hannan EL, Kilburn H Jr, Racz M, et al. Improving the outcomes of coronary artery bypass surgery in New York State. JAMA. Mar. 27. 1994;1(10):761-6. [pmid: 8114213].
30 Cutler DM, Huckman RS, Landrum MB. The role of information in medical markets: an analysis of publicly reported outcomes in cardiac surgery. AER. 2004;94(2):342-46.
31 Jha AK, Epstein AM. The predictive accuracy of the New York State coronary artery bypass surgery report-card system. Health Aff (Millwood). May–Jun. 2006;25(3):844-55. [pmid: 16684751].
32 Peterson ED, DeLong ER, Jollis JG, et al. The effects of New York’s bypass surgery provider profiling on access to care and patient outcomes in the elderly. J Am Coll Cardiol. Oct. 1998;32(4):993-9. [pmid: 9768723].
33 Carey JS, Danielsen B, Junod FL, et al. The California Cardiac Surgery and Intervention Project: evolution of a public reporting program. Am Surg. Oct. 2006;72(10):978-83. [pmid: 17058749].
34 Bridgewater B, Grayson AD, Brooks N, et al. Has the publication of cardiac surgery outcome data been associated with changes in practice in northwest England: an analysis of 25,730 patients undergoing CABG surgery under 30 surgeons over eight years. Heart. Jun. 2007;93(6):744-8. [pmid: 17237128].
35 Hannan EL, Sarrazin MSV, Doran DR, et al. Provider Profiling and Quality Improvement Efforts in Coronary Artery Bypass Graft Surgery: The Effect on Short-Term Mortality Among Medicare Beneficiaries. Med Care. 2003;41(10):1164-72. [pmid: 14515112].
36 Moscucci M, Eagle KA, Share D, et al. Public reporting and case selection for percutaneous coronary interventions: an analysis from two large multicenter percutaneous coronary intervention databases. J Am Coll Cardiol. Jun. 2005;45(11):1759-65. [pmid: 15936602].
37 Romano PS, Marcin JP, Dai JJ, et al. Impact of public reporting of coronary artery bypass graft surgery performance data on market share, mortality, and patient selection. Med Care. 2011;49(12):1118-25. [pmid: 22002641].
38 Guru V, Fremes SE, Naylor CD, et al. Public versus private institutional performance reporting: what is mandatory for quality improvement?. Am Heart J. Sep. 2006;152(3):573-8. [pmid: 16923433].
39 Ghali WA, Ash AS, Hall RE, et al. Statewide Quality Improvement Initiatives and Mortality After Cardiac Surgery. JAMA. Feb. 5. 1997;277(5):379-82. [pmid: 9010169].
40 Rosenthal GE, Quinn L, Harper DL. Declines in hospital mortality associated with a regional initiative to measure hospital performance. Am J Med Qual. Summer. 1997;12(2):103-12. [pmid: 9161057].
41 Clough JD, Engler D, Snow R, et al. Lack of relationship between the Cleveland Health Quality Choice project and decreased inpatient mortality in Cleveland. Am J Med Qual. Mar–Apr. 2002;17(2):47-55. [pmid: 11941994].
42 Baker DW, Einstadter D, Thomas CL, et al. Mortality trends during a program that publicly reported hospital performance. Med Care. Oct. 2002;40(10):879-90. [pmid: 12395022].
43 Baker DW, Einstadter D, Thomas C, et al. The effect of publicly reporting hospital performance on market share and risk-adjusted mortality at high-mortality hospitals. Med Care. Jun. 2003;41(6):729-40. [pmid: 12773839].
44 Caron A, Jones P, Neuhauser D, et al. Measuring performance improvement: total organizational commitment or clinical specialization. Qual Manag Health Care. Oct–Dec. 2004;13(4):210-5. [pmid: 15532514].
45 Hibbard JH, Stockard J, Tusler M. Hospital performance reports: impact on quality, market share, and reputation. Health Aff (Millwood). Jul–Aug. 2005;24(4):1150-60. [pmid: 16012155].
46 Longo DR, Land G, Schramm W, et al. Consumer reports in health care. Do they make a difference in patient care? JAMA. Nov. 19. 1997;278(19):1579-84. [pmid: 9370503].
47 Shabino C, Richardson DB. In pursuit of excellence: the checkpoint journey. WMJ. Dec. 2006;105(8):34-7. [pmid: 17256706].
48 Lipley N. Nursing and Midwifery Council issues guidance to tackle age-old concerns. Nursing Management - UK. 2009;16(2):7.
49 Hollenbeak CS, Gorton CP, Tabak YP, et al. Reductions in mortality associated with intensive public reporting of hospital outcomes. Am J Med Qual. Jul–Aug. 2008;23(4):279-86. [pmid: 18658101].
50 Werner RM, Bradlow ET. Public Reporting On Hospital Process Improvements Is Linked To Better Patient Outcomes. Health Aff (Millwood). Jul. 2010;29(7):1319-24. [pmid: 20606180].
51 Elliott MN, Lehrman WG, Goldstein EH, et al. Hospital survey shows improvements in patient experience. Health Aff (Millwood). Nov. 2010;29(11):2061-7. [pmid: 21041749].
52 Jang WM, Eun SJ, Sagong P, et al. The change in readmission rate, length of stay and hospital charge after performance reporting of hip hemiarthroplasty. J Prev Med Public Health. 2010;43(6):523-34. [pmid: 21139413].
53 Lied TR, Sheingold S. HEDIS performance trends in Medicare managed care. Health Care Financ Rev. Fall. 2001;23(1):149-60. [pmid: 12500369].
54 Bardenheier B, Kong Y, Shefer A, et al. Managed care organizations’ performance in delivery of childhood immunizations (HEDIS, 1999–2002). Am J Manag Care. 2007;13(4):193-200. [pmid: 17408339].
55 Jung K. The impact of information disclosure on quality of care in HMO markets. Int J Qual Health Care. Dec. 2010;22(6):461-8. [pmid: 20940251].
56 Bost JE. Managed care organizations publicly reporting three years of HEDIS measures. Manag Care Interface. Sep. 2001;14(9):50-4. [pmid: 11569305].
57 Hendriks M, Spreeuwenberg P, Rademakers J, et al. Dutch healthcare reform: did it result in performance improvement of health plans? A comparison of consumer experiences over time. BMC Health Serv Res. Sept. 2009;9:167. [pmid: 19761580].
58 Werner R, Stuart E, Polsky D. Public reporting drove quality gains at nursing homes. Health Aff (Millwood). Sep. 2010;29(9):1706-13. [pmid: 20820030].
59 Zinn J, Spector W, Hsieh L, et al. Do trends in the reporting of quality measures on the nursing home compare web site differ by nursing home characteristics?. Gerontologist. Dec. 2005;45(6):720-30. [pmid: 16326653].
60 Castle NG, Liu D, Engberg J. The association of Nursing Home Compare quality measures with market competition and occupancy rates. J Healthc Qual. Mar–Apr. 2008;30(2):4-14. [pmid: 18411887].
61 Grabowski DC, Town RJ. Does information matter? Competition, quality, and the impact of nursing home report cards. Health Serv Res. 2011;46(6 PART 1):1698-719. [pmid: 21790590].
62 Gaudet J. Heller School for Social P, Management. Nursing home compare: predictors and consequences of differing organizational response. [Dissertation]. Massachusetts. Brandeis University, The Heller School for Social Policy and Management. 2011.
63 Mukamel DB, Weimer DL, Spector WD, et al. Publication of quality report cards and trends in reported quality measures in nursing homes. Health Serv Res. Aug. 2008;43(4):1244-62. [pmid: 18248401].
64 Apolito RA, Greenberg MA, Menegus MA, et al. Impact of the New York State Cardiac Surgery and Percutaneous Coronary Intervention Reporting System on the management of patients with acute myocardial infarction complicated by cardiogenic shock. Am Heart J. Feb. 2008;155(2):267-73. [pmid: 18215596].
65 Omoigui NA, Miller DP, Brown KJ, et al. Outmigration for coronary bypass surgery in an era of public dissemination of clinical outcomes. Circulation. Jan. 1996;93(1):27-33. [pmid: 8616936].
66 Dranove D, Kessler D, McClellan M, et al. Is More Information Better? The Effects of ‘Report Cards’ on Health Care Providers. JPE. 2003;111(3):555-88.
67 Friedberg MW, Mehrotra A, Linder JA. Reporting hospitals’ antibiotic timing in pneumonia: adverse consequences for patients?. Am J Manag Care. Feb. 2009;15(2):137-44. [pmid: 19284811].
68 Werner RM, Asch DA, Polsky D. Racial profiling: the unintended consequences of coronary artery bypass graft report cards. Circulation. Mar. 15. 2005;111(10):1257-63. [pmid: 15769766].
69 Glance LG, Dick A, Mukamel DB, et al. Are high-quality cardiac surgeons less likely to operate on high-risk patients compared to low-quality surgeons? Evidence from New York State. Health Serv Res. Feb. 2008;43(1 Pt 1):300-12. [pmid: 18211531].
70 Habermann EB, Virnig BA, Riley GF, et al. The impact of a change in Medicare reimbursement policy and HEDIS measures on stage at diagnosis among Medicare HMO and fee-for-service female breast cancer patients. Med Care. Aug. 2007;45(8):761-6. [pmid: 17667310].
71 Pham HH, Frick KD, Diener-West M, et al. Is health plan employer data and information set performance associated with withdrawal from medicare managed care?. Med Care. Mar. 2002;40(3):212-26. [pmid: 11880794].
72 Mukamel DB, Ladd H, Weimer DL, et al. Is there evidence of cream skimming among nursing homes following the publication of the Nursing Home Compare report card?. Gerontologist. Dec. 2009;49(6):793-802. [pmid: 19491363].
73 Werner RM, Konetzka RT, Stuart EA, et al. Changes in patient sorting to nursing homes under public reporting: improved patient matching or provider gaming?. Health Serv Res. 2011;46(2):555-71. [pmid: 21105869].
74 Werner RM, Konetzka RT, Kruse GB. Impact of public reporting on unreported quality of care. Health Serv Res. Apr. 2009;44(2 Pt 1):379-98. [pmid: 19178586].
75 Konetzka RT, Polsky D, Werner R. Shipping out instead of shaping up: rehospitalization from nursing homes as an unintended effect of public reporting. SSRN working paper. 2012.
76 Caron A, Neuhauser D. The Effect of Public Accountability on Hospital Performance: Trends in Rates for Cesarean Sections and Vaginal Births after Cesarean Section in Cleveland, Ohio. Qual Manag Health Care. 1999;7(2):1-10. [pmid: 10346457].
77 Jang WM, Eun SJ, Lee CE, et al. Effect of repeated public releases on cesarean section rates. J Prev Med Public Health. 2011;44(1):2-8. [pmid: 21483217].
78 Zinn JS, Weimer DL, Spector W, et al. Factors influencing nursing home response to quality measure publication: A resource dependence perspective. Health Care Manage Rev. Jul–Sep. 2010;35(3):256-65. [pmid: 20551773].
79 Zinn JS, Spector WD, Weimer DL, et al. Strategic orientation and nursing home response to public reporting of quality measures: an application of the miles and snow typology. Health Serv Res. Apr. 2008;43(2):598-615. [pmid: 18370969].
80 Mukamel DB, Spector WD, Zinn J, et al. Changes in clinical and hotel expenditures following publication of the nursing home compare report card. Med Care. Oct. 2010;48(10):869-74. [pmid: 20733531].
81 Cai S, Temkin-Greener H. Influenza vaccination and its impact on hospitalization events in nursing homes. J Am Med Dir Assoc. Sep. 2011;12(7):493-8. [pmid: 21450172].
82 Foreman S, Kenkel D, Shea D. Cost and quality information and health care market reform. Adv Health Econ Health Serv Res. 1995;15:137-53. [pmid: 10163094].
83 Wang J, Hockenberry J, Chou SY, et al. Do bad report cards have consequences? Impacts of publicly reported provider quality information on the CABG market in Pennsylvania. J Health Econ. Mar. 2011;30(2):392-407. [pmid: 21195494].
84 Mukamel DB, Mushlin AI. Quality of care information makes a difference: an analysis of market share and price changes after publication of the New York State Cardiac Surgery Mortality Reports. Med Care. Jul. 1998;36(7):945-54. [pmid: 9674613].
85 Romano PS, Zhou H. Do well-publicized risk-adjusted outcomes reports affect hospital volume?. Med Care. Apr. 2004;42(4):367-77. [pmid: 15076814].
86 Dranove D, Sfekas A. Start spreading the news: a structural estimate of the effects of New York hospital report cards. J Health Econ. Sep. 2008;27(5):1201-7. [pmid: 18420293].
87 Vladeck BC, Goodwin EJ, Myers LP, et al. Consumers and hospital use: the HCFA“death list”. Health Aff (Millwood). Spring. 1988;7(1):122-5. [pmid: 3360387].
88 Mennemeyer ST, Morrisey MA, Howard LZ. Death and reputation: how consumers acted upon HCFA mortality information. Inquiry. Summer. 1997;34(2):117-28. [pmid: 9256817].
89 Howard DH, Kaplan B. Do report cards influence hospital choice? The case of kidney transplantation. Inquiry. Summer. 2006;43(2):150-9. [pmid: 17004644].
90 Wübker A, Auerland D, Wübker A. Does better information about hospital quality affect patients’ choice? Empirical findings from Germany. MPRA. 2008.
91 Pope DG. Reacting to rankings: Evidence from “America’s Best Hospitals”. J Health Econ. Dec. 2009;28(6):1154-65. [pmid: 19818518].
92 Epstein AJ. Effects of report cards on referral patterns to cardiac surgeons. J Health Econ. Sep. 2010;29(5):718-31. [pmid: 20599284].
93 Bundorf MK, Chun N, Goda GS, et al. Do markets respond to quality information? The case of fertility clinics. J Health Econ. May. 2009;28(3):718-27. [pmid: 19328568].
94 Mukamel DB, Weimer DL, Zwanziger J, et al. Quality report cards, selection of cardiac surgeons, and racial disparities: a study of the publication of the New York State Cardiac Surgery Reports. Inquiry. Winter. 2004;41(4):435-46. [pmid: 15835601].
95 Chernew M, Scanlon DP. Health plan report cards and insurance choice. Inquiry. Spring. 1998;35(1):9-22. [pmid: 9597014].
96 Scanlon DP, Chernew M. HEDIS measures and managed care enrollment. Med Care Res Rev. 1999;56(Suppl 2):60-84. [pmid: 10327824].
97 Abraham JM, Feldman R, Carlin C, et al. The effect of quality information on consumer health plan switching: evidence from the Buyers Health Care Action Group. J Health Econ. Jul. 2006;25(4):762-81. [pmid: 16704882].
98 Fowles JB, Kind EA, Braun BL, et al. Consumer Responses to Health Plan Report Cards in Two Markets. Med Care. 2000;38(5):469-81. [pmid: 10800974].
99 Knutson DJ, Kind EA, Fowles JB, et al. Impact of report cards on employees: a natural experiment. Health Care Financ Rev. Fall. 1998;20(1):5-27. [pmid: 10387425].
100 Wedig GJ, Tai-Seale M. The effect of report cards on consumer choice in the health insurance market. J Health Econ. Nov. 2002;21(6):1031-48. [pmid: 12475124].
101 Tai-Seale M. Does consumer satisfaction information matter? Evidence on member retention in FEHBP plans. Med Care Res Rev. Jun. 2004;61(2):171-86. [pmid: 15155050].
102 Farley DO, Short PF, Elliott MN, et al. Effects of CAHPS health plan performance information on plan choices by New Jersey Medicaid beneficiaries. Health Serv Res. Aug. 2002;37(4):985-1007. [pmid: 12236394].
103 Farley DO, Elliott MN, Short PF, et al. Effect of CAHPS performance information on health plan choices by Iowa Medicaid beneficiaries. Med Care Res Rev. Sep. 2002;59(3):319-36. [pmid: 12205831].
104 McCormack LA, Garfinkel SA, Hibbard JH, et al. Health plan decision making with new medicare information materials. Health Serv Res. Jul. 2001;36(3):531-54. [pmid: 11482588].
105 Chernew M, Gowrisankaran G, McLaughlin C, et al. Quality and employers’ choice of health plans. J Health Econ. May. 2004;23(3):471-92. [pmid: 15120466].
106 Stevenson DG. Is a public reporting approach appropriate for nursing home care?. J Health Polit Policy Law. Aug. 2006;31(4):773-810. [pmid: 16971545].
107 Werner R, Norton EC, Konetzka R, et al. Do consumers respond to publicly reported quality information? Evidence from nursing homes. J Health Econ. 2012;31(1):50-61. [pmid: 22307033].
108 Park J, Konetzka RT, Werner RM. Performing Well on Nursing Home Report Cards: Does It Pay Off?. Health Serv Res. 2011;46(2):531-54. [pmid: 21029093].
109 Park J, Werner RM. Changes in the Relationship between Nursing Home Financial Performance and Quality of Care under Public Reporting. Health Econ. 2011;20(7):783-801. [pmid: 20578255].
110 Ranganathan M, Hibbard J, Rodday AM, et al. Motivating public use of physician-level performance data: an experiment on the effects of message and mode. Med Care Res Rev. Feb. 2009;66(1):68-81. [pmid: 18923193].
111 Evans JH, Yuhchang H, Nagarajan N, et al. Involuntary Benchmarking and Quality Improvement: The Effect of Mandated Public Disclosure on Hospitals. JAAF. Summer97. 1997;12(3):315-46.
112 Dafny L, Dranove D. Do report cards tell consumers anything they don’t know already? The case of Medicare HMOs Rand. J Econ. Autumn. 2008;39(3):790-821. [pmid: 19013864].
113 Beaulieu ND. Quality information and consumer health plan choices. J Health Econ. Jan. 2002;21(1):43-63. [pmid: 11845925].
114 Liu H, Phelps CE, Veazie PJ, et al. Managed care quality of care and plan choice in New York SCHIP. Health Serv Res. Jun. 2009;44(3):843-61. [pmid: 19208091].
115 Castle NG, Engberg J, Liu D. Have Nursing Home Compare quality measure scores changed over time in response to competition?. Qual Saf Health Care. Jun. 2007;16(3):185-91. [pmid: 17545344].
116 Tu JV, Donovan LR, Lee DS, et al. Effectiveness of public report cards for improving the quality of cardiac care: the EFFECT study: a randomized trial. JAMA. Dec. 2. 2009;302(21):2330-7. [pmid: 19923205].
117 Hartz AJ, Pulido JS, Kuhn EM. Are the best coronary artery bypass surgeons identified by physician surveys?. Am J Public Health. 1997;87(10):1645-8. [pmid: 9357346].
118 Putnam W, Bower KN, Cox J, et al. Quality indicators for cardiac care: national standards in a community context. J Health Serv Res Policy. Jan. 2006;11(1):5-12. [pmid: 16378527].
119 Richard SA, Rawal S, Martin DK. Patients’ views about cardiac report cards: a qualitative study. Can J Cardiol. Sep. 2005;21(11):943-7. [pmid: 16239978].
120 Bensimon CM, Nohara N, Martin DK. Stakeholders’ views about cardiac report cards: a qualitative study. Can J Cardiol. Mar. 15. 2004;20(4):433-8. [pmid: 15057320].
121 Tu JV, Cameron C. Impact of an acute myocardial infarction report card in Ontario, Canada. Int J Qual Health Care. Apr. 2003;15(2):131-7. [pmid: 12705706].
122 Ginsburg LS. Factors that influence line managers’ perceptions of hospital performance data. Health Serv Res. Feb. 2003;38(1 Pt 1):261-86. [pmid: 12650391].
123 Fasolo B, Reutskaja E, Dixon A, et al. Helping patients choose: how to improve the design of comparative scorecards of hospital quality. Patient Educ Couns. Mar. 2010;78(3):344-9. [pmid: 20171822].
124 Reeves R, Seccombe I. Do patient surveys work? The influence of a national survey programme on local quality-improvement initiatives. Qual Saf Health Care. Dec. 2008;17(6):437-41. [pmid: 19064659].
125 Magee H, Davis LJ, Coulter A. Public views on healthcare performance indicators and patient choice. J R Soc Med. Jul. 2003;96(7):338-42. [pmid: 12835446].
126 Mannion R, Davies H, Marshall M. Impact of star performance ratings in English acute hospital trusts. J Health Serv Res Policy. Jan. 2005;10(1):18-24. [pmid: 15667700].
127 Moser A, Korstjens I, van der Weijden T, et al. Themes affecting health-care consumers’ choice of a hospital for elective surgery when receiving web-based comparative consumer information. Patient Educ Couns. Mar. 2010;78(3):365-71. [pmid: 20006460].
128 de Groot IB, Otten W, Smeets HJ, et al. Is the impact of hospital performance data greater in patients who have compared hospitals?. BMC Health Serv Res. 2011;11. [pmid: 21906293].
129 Dijs-Elsinga J, Otten W, Versluijs MM, et al. Choosing a hospital for surgery: the importance of information on quality of care. Med Decis Making. Sep–Oct. 2010;30(5):544-55. [pmid: 20110514].
130 Kang HY, Kim SJ, Cho W, et al. Consumer use of publicly released hospital performance information: assessment of the National Hospital Evaluation Program in Korea. Health Policy. Feb. 2009;89(2):174-83. [pmid: 18619703].
131 Khang YH, Yun SC, Jo MW, et al. Public release of institutional Cesarean section rates in South Korea: which women were aware of the information?. Health Policy. Apr. 2008;86(1):10-6. [pmid: 17964680].
132 Mannion R, Goddard M. Public disclosure of comparative clinical performance data: lessons from the Scottish experience. J Eval Clin Pract. May. 2003;9(2):277-86. [pmid: 12787191].
133 Geraedts M, Schwartze D, Molzahn T. Hospital quality reports in Germany: patient and physician opinion of the reported quality indicators. BMC Health Serv Res. 2007;7:157. [pmid: 17903244].
134 Merle V, Germain JM, Tavolacci MP, et al. Influence of infection control report cards on patients’ choice of hospital: pilot survey. J Hosp Infect. Mar. 2009;71(3):263-8. [pmid: 19147258].
135 Aryankhesal A, Sheldon T. Effect of the Iranian hospital grading system on patients’ and general practitioners’ behaviour: an examination of awareness, belief and choice. Health Serv Manage Res. Aug. 2010;23(3):139-44. [pmid: 20702891].
136 Laschober M, Maxfield M, Felt-Lisk S, et al. Hospital response to public reporting of quality indicators. Health Care Financ Rev. Spring. 2007;28(3):61-76. [pmid: 17645156].
137 Chassin MR. Achieving and sustaining improved quality: lessons from New York State and cardiac surgery. Health Aff (Millwood). Jul–Aug. 2002;21(4):40-51. [pmid: 12117152].
138 Romano PS, Rainwater JA, Antonius D. Grading the graders: how hospitals in California and New York perceive and interpret their report cards. Med Care. Mar. 1999;37(3):295-305. [pmid: 10098573].
139 Hannan EL, Stone CC, Biddle TL, et al. Public release of cardiac surgery outcomes data in New York: what do New York state cardiologists think of it?. Am Heart J. Dec. 1997;134(6):1120-8. [pmid: 9424074].
140 Luce JM, Thiel GD, Holland MR, et al. Use of risk-adjusted outcome data for quality improvement by public hospitals. West J Med. May. 1996;164(5):410-4. [pmid: 8686297].
141 Schneider EC, Epstein AM. Influence of cardiac-surgery performance reports on referral practices and access to care. A survey of cardiovascular specialists. N Engl J Med. Jul. 1996;335(4):251-6. [pmid: 8657242].
142 Berwick DM, Wald DL. Hospital leaders’ opinions of the HCFA mortality data. JAMA. Jan. 12. 1990;263(2):247-9. [pmid: 2403602].
143 Bentley JM, Nash DB. How Pennsylvania hospitals have responded to publicly released reports on coronary artery bypass graft surgery. Jt Comm J Qual Improv. Jan. 1998;24(1):40-9. [pmid: 9494873].
144 Laschober MA. Hospital compare highlights potential challenges in public reporting for hospitals. Princeton, N.J. Mathematica Policy Research, Inc. 2006.
145 Guru V, Naylor CD, Fremes SE, et al. Publicly reported provider outcomes: the concerns of cardiac surgeons in a single-payer system. Can J Cardiol. Jan. 2009;25(1):33-8. [pmid: 19148340].
146 Longo DR, Everet KD. Health care consumer reports: an evaluation of consumer perspectives. J Health Care Finance. Fall. 2003;30(1):65-71. [pmid: 12967245].
147 Rainwater JA, Romano PS. What data do California HMOs use to select hospitals for contracting?. Am J Manag Care. Aug. 2003;9(8):553-61. [pmid: 12921233].
148 Schneider EC, Epstein AM. Use of public performance reports: a survey of patients undergoing cardiac surgery. JAMA. May. 27. 1998;279(20):1638-42. [pmid: 9613914].
149 Gross PA, Schaffer WA. Consumer awareness of hospital mortality data. J Health Care Mark. Dec. 1989;9(4):52-5. [pmid: 10304175].
150 Mazor KM, Dodd KS, Kunches L. Communicating hospital infection data to the public: a study of consumer responses and preferences. Am J Med Qual. Mar–Apr. 2009;24(2):108-15. [pmid: 19237552].
151 Schwartz LM, Woloshin S, Birkmeyer JD. How do elderly patients decide where to go for major surgery? Telephone interview survey. BMJ. Oct. 8. 2005;331(7520):821. [pmid: 16192286].
152 Mazor KM, Dodd KS. A qualitative study of consumers’ views on public reporting of health care-associated infections. Am J Med Qual. Sep–Oct. 2009;24(5):412-8. [pmid: 19525369].
153 Barr JK, Giannotti TE, Sofaer S, et al. Using public reports of patient satisfaction for hospital quality improvement. Health Serv Res. Jun. 2006;41(3 Pt 1):663-82. [pmid: 16704506].
154 Mehrotra A, Bodenheimer T, Dudley RA. Employers’ efforts to measure and improve hospital quality: determinants of success. Health Aff (Millwood). Mar–Apr. 2003;22(2):60-71. [pmid: 12674408].
155 Rosenthal GE, Hammar PJ, Way LE, et al. Using hospital performance data in quality improvement: the Cleveland Health Quality Choice experience. Jt Comm J Qual Improv. Jul. 1998;24(7):347-60. [pmid: 9689568].
156 Rainwater JA, Romano PS, Antonius DM. The California Hospital Outcomes Project: how useful is California’s report card for quality improvement?. Jt Comm J Qual Improv. Jan. 1998;24(1):31-9. [pmid: 9494872].
157 Pham HH, Coughlan J, O’Malley AS. The impact of quality-reporting programs on hospital operations. Health Aff (Millwood). Sep–Oct. 2006;25(5):1412-22. [pmid: 16966741].
158 Sofaer S, Crofton C, Goldstein E, et al. What do consumers want to know about the quality of care in hospitals?. Health Serv Res. Dec. 2005;40(6 Pt 2):2018-36. [pmid: 16316436].
159 Hibbard JH, Peters E, Dixon A, et al. Consumer competencies and the use of comparative quality information: it isn’t just about literacy. Med Care Res Rev. Aug. 2007;64(4):379-94. [pmid: 17684108].
160 Peters E, Dieckmann N, Dixon A, et al. Less is more in presenting quality information to consumers. Med Care Res Rev. Apr. 2007;64(2):169-90. [pmid: 17406019].
161 Mukamel DB, Weimer DL, Zwanziger J, et al. Quality of cardiac surgeons and managed care contracting practices. Health Serv Res. Oct. 2002;37(5):1129-44. [pmid: 12479489].
162 Mukamel DB, Mushlin AI, Weimer D, et al. Do quality report cards play a role in HMOs’ contracting practices? Evidence from New York State. Health Serv Res. Apr. 2000;35(1 Pt 2):319-32. [pmid: 10778818].
163 Cheng SH, Song HY. Physician performance information and consumer choice: a survey of subjects with the freedom to choose between doctors. Qual Saf Health Care. Apr. 2004;13(2):98-101. [pmid: 15069215].
164 Chen TT, Chung KP, Huang HC, et al. Using discrete choice experiment to elicit doctors’ preferences for the report card design of diabetes care in Taiwan - a pilot study. J Eval Clin Pract. Feb. 2010;16(1):14-20. [pmid: 20367811].
165 Marshall MN, Hiscock J, Sibbald B. Attitudes to the public release of comparative information on the quality of general practice care: qualitative study. BMJ. Nov. 30. 2002;325(7375):1278. [pmid: 12458248].
166 Marshall M, Noble J, Davies H, et al. Development of an information source for patients and the public about general practice services: an action research study. Health Expect. Sep. 2006;9(3):265-74. [pmid: 16911141].
167 Maytham G, Kessaris N. A change in opinion on surgeon’s performance indicators. Interact Cardiovasc Thorac Surg. 2011;12(4):586-9. [pmid: 21228042].
168 Pettijohn TL, Lawrence ME. The impact of outcomes data reporting on access to health care of high-risk patients to interventional cardiologists in the United States. J Invasive Cardiol. Mar. 1999;11(3):111-5. [pmid: 10745496].
169 Burack JH, Impellizzeri P, Homel P, et al. Public reporting of surgical mortality: a survey of New York State cardiothoracic surgeons. Ann Thorac Surg. Oct. 1999;68(4):1195-200. discussion 201–2. [pmid: 10543479].
170 Narins CR, Dozier AM, Ling FS, et al. The influence of public reporting of outcome data on medical decision making by physicians. Arch Intern Med. Jan. 10. 2005;165(1):83-7. [pmid: 15642879].
171 Casalino LP, Alexander GC, Jin L, et al. General Internists’ Views On Pay-For-Performance And Public Reporting Of Quality Scores: A National Survey. Health Aff (Millwood). March. 1. 2007. 2007;26(2):492-9. [pmid: 17339678].
172 Fanjiang G, von Glahn T, Chang H, et al. Providing patients web-based data to inform physician choice: if you build it, will they come?. J Gen Intern Med. Oct. 2007;22(10):1463-6. [pmid: 17653810].
173 Abraham J, Sick B, Anderson J, et al. Selecting a provider: what factors influence patients’ decision making?. J Healthc Manag. Mar–Apr. 2011;56(2):99-114. discussion -5. [pmid: 21495529].
174 Barr JK, Bernard SL, Sofaer S, et al. Physicians’ views on public reporting of hospital quality data. Med Care Res Rev. Dec. 2008;65(6):655-73. [pmid: 18596176].
175 Friedberg MW, SteelFisher GK, Karp M, et al. Physician Groups’ Use of Data from Patient Experience Surveys. J Gen Intern Med. May. 2011;26(5):498-504. [pmid: 21161419].
176 Stein BD, Kogan JN, Essock S, et al. Views of mental health care consumers on public reporting of information on provider performance. Psychiatr Serv. May. 2009;60(5):689-92. [pmid: 19411360].
177 Fung CH, Elliott MN, Hays RD, et al. Patients’ preferences for technical versus interpersonal quality when selecting a primary care physician. Health Serv Res. Aug. 2005;40(4):957-77. [pmid: 16033487].
178 Donelan K, Rogers RS, Eisenhauer A, et al. Consumer comprehension of surgeon performance data for coronary bypass procedures. Ann Thorac Surg. 2011;91(5):1400-5. discussion 5–6. [pmid: 21524448].
179 Schultz J, Thiede Call K, Feldman R, et al. Do employees use report cards to assess health care provider systems?. Health Serv Res. Jul. 2001;36(3):509-30. [pmid: 11482587].
180 Stanfill PH, Weber DG, Wayne C. Clinical patient information capture: the Columbia/HCA cancer care database experience. J Oncol Manag. 1998;7(9305645, cz6):17-21. [pmid: 10179008].
181 Scanlo DP, Chernew M, McLaughlin C, et al. The impact of health plan report cards on managed care enrollment. J Health Econ. Jan. 2002;21(1):19-41. [pmid: 11845924].
182 Dresner Y, Frank E, Baevsky T, et al. Screening practices of Israeli doctors’ and their patients. Prev Med. 2010;50(5–6):300-3. [pmid: 20167233].
183 Fox MH, Moore J, Zimmerman M, et al. The effectiveness of CAHPS among women enrolling in Medicaid managed care. J Ambul Care Manage. Oct. 2001;24(4):76-91. [pmid: 11680241].
184 Landercasper J, Linebarger JH, Ellis RL, et al. A quality review of the timeliness of breast cancer diagnosis and treatment in an integrated breast center. J Am Coll Surg. 2010;210(4):449-55. [pmid: 20347737].
185 Guadagnoli E, Epstein AM, Zaslavsky A, et al. Providing consumers with information about the quality of health plans: the Consumer Assessment of Health Plans demonstration in Washington State. Jt Comm J Qual Improv. Jul. 2000;26(7):410-20. [pmid: 10897458].
186 Marquis MS, Long SH. Prevalence of selected employer health insurance purchasing strategies in 1997. Health Aff (Millwood). Jul–Aug. 2001;20(4):220-30. [pmid: 11463079].
187 Farley Short P, McCormack L, Hibbard J, et al. Similarities and differences in choosing health plans. Med Care. Apr. 2002;40(4):289-302. [pmid: 12021685].
188 Rosenthal MB, Landon BE, Normand SL, et al. Employers’ use of value-based purchasing strategies. JAMA. Nov. 21. 2007;298(19):2281-8. [pmid: 18029832].
189 Sarfaty M, Myers RE. The effect of HEDIS measurement of colorectal cancer screening on insurance plans in Pennsylvania. Am J Manag Care. May. 2008;14(5):277-82. [pmid: 18471032].
190 Gabel JR. When employers choose health plans: do NCQA accreditation and HEDIS data count?. Commonwealth Fund. 1998.
191 Gibbs DA, Sangl JA, Burrus B. Consumer perspectives on information needs for health plan choice. Health Care Financ Rev. Fall. 1996;18(1):55-73. [pmid: 10165037].
192 Harris-Kojetin LD, McCormack LA, Jael EM, et al. Beneficiaries’ perceptions of new Medicare health plan choice print materials. Health Care Financ Rev. Fall. 2001;23(1):21-35. [pmid: 12500360].
193 Smith F, Gerteis M, Downey N, et al. The effects of disseminating performance data to health plans: results of qualitative research with the Medicare Managed Care plans. Health Serv Res. Jul. 2001;36(3):643-63. [pmid: 11482593].
194 Goldstein E, Fyock J. Reporting of CAHPS quality information to medicare beneficiaries. Health Serv Res. 2001;36(3):477-88. [pmid: 11482585].
195 O’Day B, Palsbo SE, Dhont K, et al. Health plan selection criteria by people with impaired mobility. Med Care. Sep. 2002;40(9):732-42. [pmid: 12218764].
196 Palsbo SE, Kroll T. Meeting information needs to facilitate decision making: report cards for people with disabilities. Health Expect. Sep. 2007;10(3):278-85. [pmid: 17678516].
197 Braun BL, Kind EA, Fowles JB, et al. Consumer response to a report card comparing healthcare systems. Am J Manag Care. Jun. 2002;8(6):522-8. [pmid: 12068959].
198 Jewett JJ, Hibbard JH. Comprehension of quality care indicators: differences among privately insured, publicly insured, and uninsured. Health Care Financ Rev. Fall. 1996;18(1):75-94. [pmid: 10165038].
199 Hibbard JH, Jewett JJ. What type of quality information do consumers want in a health care report card?. Med Care Res Rev. Mar. 1996;53(1):28-47. [pmid: 10156433].
200 Hibbard JH, Jewett JJ. Will quality report cards help consumers?. Health Aff (Millwood). May–Jun. 1997;16(3):218-28. [pmid: 9141339].
201 Harris-Kojetin LD, McCormack LA, Jael EF, et al. Creating more effective health plan quality reports for consumers: lessons from a synthesis of qualitative testing. Health Serv Res. Jul. 2001;36(3):447-76. [pmid: 11482584].
202 Rainwater JA. Evaluation of California’s Quality of Care Report Card. 2005.
203 Scanlon DP, Darby C, Rolph E, et al. The role of performance measures for improving quality in managed care organizations. Health Serv Res. Jul. 2001;36(3):619-41. [pmid: 11482592].
204 Teleki SS, Kanouse DE, Elliott MN, et al. Understanding the reporting practices of CAHPS sponsors. Health Care Financ Rev. 2007;28(3):17-30. [pmid: 17645153].
205 Damman OC, Hendriks M, Rademakers J, et al. How do healthcare consumers process and evaluate comparative healthcare information? A qualitative study using cognitive interviews. BMC Public Health. 2009;9:423. [pmid: 19930564].
206 Hibbard JH, Jewett JJ, Legnini MW, et al. Choosing a health plan: do large employers use the data?. Health Aff (Millwood). November. 1. 1997. 1997;16(6):172-80. [pmid: 9444825].
207 Spranca M, Kanouse DE, Elliott M, et al. Do consumer reports of health plan quality affect health plan selection?. Health Serv Res. Dec. 2000;35(5 Pt 1):933-47. [pmid: 11130805].
208 Hibbard JH, Harris-Kojetin L, Mullin P, et al. Increasing the impact of health plan report cards by addressing consumers’ concerns. Health Aff (Millwood). Sep–Oct. 2000;19(5):138-43. [pmid: 10992661].
209 Hibbard JH, Peters E, Slovic P, et al. Making health care quality reports easier to use. Jt Comm J Qual Improv. Nov. 2001;27(11):591-604. [pmid: 11708039].
210 Uhrig JD, Short PF. Testing the effect of quality reports on the health plan choices of Medicare beneficiaries. Inquiry. Winter. 2002;39(4):355-71. [pmid: 12638711].
211 Harris KM. Can high quality overcome consumer resistance to restricted provider access? Evidence from a health plan choice experiment. Health Serv Res. Jun. 2002;37(3):551-71. [pmid: 12132595].
212 Hibbard JH, Berkman N, McCormack LA, et al. The impact of a CAHPS report on employee knowledge, beliefs, and decisions. Med Care Res Rev. Mar. 2002;59(1):104-16. [pmid: 11877876].
213 Uhrig JD, Harris-Kojetin L, Bann C, et al. Do content and format affect older consumers’ use of comparative information in a Medicare health plan choice? Results from a controlled experiment. Med Care Res Rev. Dec. 2006;63(6):701-18. [pmid: 17099122].
214 Spranca MD, Elliott MN, Shaw R, et al. Disenrollment information and Medicare plan choice: is more information better?. Health Care Financ Rev. Spring. 2007;28(3):47-59. [pmid: 17645155].
215 Peters E, Dieckmann NF, Vastfjall D, et al. Bringing meaning to numbers: the impact of evaluative categories on decisions. J Exp Psychol Appl. Sep. 2009;15(3):213-27. [pmid: 19751072].
216 Hibbard JH, Sofaer S, Jewett JJ. Condition-specific performance information: assessing salience, comprehension, and approaches for communicating quality. Health Care Financing Review. 1996;18(1):95-109. [pmid: 10165040].
217 Hibbard JH, Slovic P, Peters E, et al. Is the informed-choice policy approach appropriate for Medicare beneficiaries?. Health Aff (Millwood). May–Jun. 2001;20(3):199-203. [pmid: 11585167].
218 Hibbard JH, Slovic P, Peters E, et al. Strategies for Reporting Health Plan Performance Information to Consumers: Evidence from Controlled Studies. Health Serv Res. 2002;37(2):291-313. [pmid: 12035995].
219 Veroff DR, Gallagher PM, Wilson V, et al. Effective reports for health care quality data: lessons from a CAHPS demonstration in Washington State. Int J Qual Health Care. Dec. 1998;10(6):555-60. [pmid: 9928595].
220 Sibbald B, Addington-Hall J, Brenneman D, et al. The role of counsellors in general practice. A qualitative study. Occas Pap R Coll Gen Pract. 1996;(74):1-19. [pmid: 9080766].
221 Marshall MN, Shekelle PG, Leatherman S, et al. The public release of performance data: what do we expect to gain? A review of the evidence. JAMA. 2000;283(14):1866-74. [pmid: 10770149].
222 Ketelaar NA, Faber MJ, Flottorp S, et al. Public release of performance data in changing the behaviour of healthcare consumers, professionals or organisations. Cochrane Database of Systematic Reviews. 2011;(11).
223 Amin AN, Deitelzweig SB. Optimizing the prevention of venous thromboembolism: recent quality initiatives and strategies to drive improvement. Jt Comm J Qual Patient Saf. 2009;35(11):558-64. [pmid: 19947332].
224 Castle NG, Sonon K, Antonova J. The impact of special focus facility nursing homes on market quality. Gerontologist. Aug. 2010;50(4):519-30. [pmid: 20154307].
225 Liu D, Castle NG. Have facilities changed their nursing home compare quality measure scores over time?. Long-Term Care Interface. 2005;6(11):21-4.
226 Eisen SV, Bottonari KA, Glickman ME, et al. The incremental value of self-reported mental health measures in predicting functional outcomes of veterans. J Behav Health Serv Res. 2011;38(2):170-90. [pmid: 21191819].
227 Appelbaum PS, Gold A. Psychiatrists’ relationships with industry: the principal-agent problem. Harv Rev Psychiatry. Oct. 2010;18(5):255-65. [pmid: 20825263].
228 Castle NG. Nursing home administrators’ opinions of the nursing home compare web site. Gerontologist. Jun. 2005;45(3):299-308. [pmid: 15933270].
229 Castle NG. The Nursing Home Compare report card: consumers’ use and understanding. J Aging Soc Policy. Apr–Jun. 2009;21(2):187-208. [pmid: 19333842].
230 Castle NG. Consumers’ use of internet-based nursing home report cards. Jt Comm J Qual Patient Saf. Jun. 2009;35(6):316-23. [pmid: 19565691].
231 Van Nie NC, Hollands LJ, Hamers JP. Reporting quality of nursing home care by an internet report card. Patient Educ Couns. Mar. 2010;78(3):337-43. [pmid: 20189748].
232 Gerteis M, Gerteis JS, Newman D, et al. Testing consumers’ comprehension of quality measures using alternative reporting formats. Health Care Financ Rev. Spring. 2007;28(3):31-45. [pmid: 17645154].
233 Christianson JB, Volmar KM, Alexander J, et al. A report card on provider report cards: current status of the health care transparency movement. Journal of General Internal Medicine. Nov. 2010;25(11):1235-41. [pmid: 20625849].
234 Candy B, King M, Jones L, et al. Using qualitative synthesis to explore heterogeneity of complex interventions. BioMed Central Medical Research Methodology. 2011;11(1):124. [pmid: 21871083].