# Methods

## Topic Nomination and Development

This evidence review about public reporting as a quality improvement strategy is one of eight reviews in the Closing the Quality Gap: Revisiting the State of the Science series (CQG series). The CQG series aims to assemble the evidence about effective strategies to close the “quality gap”—the difference between what is expected to work well for patients based on known evidence and what actually happens in day-to-day clinical practice across populations of patients.

The CQG series focuses on improving the quality of health care through critical assessment of relevant evidence for selected settings, interventions, and incentives. Topics for the eight CQG reviews were solicited from the portfolio leads at Agency for Healthcare Research and Quality (AHRQ). The nominations included a brief background and context; the importance and/or rationale for the topic; the focus or population of interest; relevant outcomes; and references to recent or ongoing work. Among the topics that were nominated, the following considerations were made in selection for inclusion in the series: the ability to focus and clarify the topic area appropriately; relevance to quality improvement and a systems approach; applicability to the Evidence-based Practice Center (EPC) program/amenable to systematic review; the potential for duplication and/or overlap with other known or ongoing work; relevance and potential impact in improving care; and fit of the topics as a whole in reflecting the AHRQ portfolios.

Topic development occurred during preliminary work with the lead EPC that is coordinating the series, the AHRQ Task Order Officer (TOO) for the series, and the investigators at the EPCs working on the other topics in order to assure that the objectives and methodology conformed to the goals of the series. Topic development then continued with the TOOs and a Technical Expert Panel (TEP) specific to this review. The TEP included clinicians, researchers, producers of public reports, as well as consumer advocates. This second phase included refining the definition of public reporting to be used for this review and developing and refining the Key Questions in order to make the review feasible and relevant, while maintaining the focus on quality improvement, as this is the topic for the series. Both the definition and the Key Questions are presented in the prior section. Topic development also involved developing the analytic framework (see Figure 1) and setting the parameters for what studies were to be included in the review.

Figure 1 Analytic framework

Note: Dotted lines indicate relationships between intermediate outcomes and ultimate improvement in the quality of care. KQ = Key Question; QI = quality improvement.

Figure 1. This figure depicts how the intervention, public reporting of health care quality data, may impact two populations: 1. Individuals and organizations that deliver care and 2. Patients, their representatives and organizations that purchase care. The figure shows public reporting ultimately having an impact on quality of care through actions of either population. Public reporting may result in improvements in the quality of health care (Key Question 1) harms (Key Question 2) directly or through intermediate outcomes that precede, but may ultimately contribute to improvements in the quality of health care. These intermediate outcomes include changes in structures and processes by those that deliver care (Key Question 3) and changes in patients’ or purchasers’ related behavior (Key Question 4). The figure also represents the possibility that the characteristics of the public reports may affect the impact of public reports on the quality of care and intermediate outcomes (Key Question 5). Finally the figure illustrates that contextual factors may influence the impact of public reporting on the intermediate outcomes or the quality of care (Key Question 6).

## Search Strategy

Research on the public reporting of health care quality information spans multiple disciplines. For this reason we searched bibliographic databases covering psychology, economics, and public policy as well as health care. We conducted searches for both reviews and individual studies in MEDLINE^®^, Embase^®^, EconLit, PsychINFO^®^ Business Source^®^ Premier, CINAHL^®^ (Cumulative Index of Nursing and Allied Health Literature), and PAIS (Public Affairs Information Services). We also searched for systematic reviews, studies and evaluations in The Cochrane Database of Systematic Reviews, The Cochrane Effective Practice and Organization of Care Group (EPOC) Register of Studies, Database of Abstracts of Reviews of Effects (DARE), National Health Service Economic Evaluation Database (NHS EED), and Health Economic Evaluations Database (HEED). The Grey Literature Report database maintained by the New York Academy of Medicine and AARP Ageline were searched for additional studies and reports.

Additionally in order to supplement our search for grey literature, we contacted known public report producers through the Scientific Resource Center (SRC) of the EPC program. Individuals in organizations that had contributed reports to a clearing house or participated in community quality collaboratives were sent an email explaining the review and asking for any published or unpublished evaluations or data related to their public reports.

The initial searches included studies published or reported between January 1980 and May 2011. Two of the earliest public reports in the United States were the data on hospital mortality rates issued by the Health Care Financing Administration in 1986 and the mortality reports issued by the New York Cardiac Surgery Reporting System in 1989. Starting from January 1980 ensured that the entire contemporary history of public reporting was represented. In January 2012 the search was updated to include citations through December 31, 2011 and additional studies were added. In a few cases studies were identified through conference abstracts and online advance publication, and were included if the final manuscript was available even though the publication date was in 2012.

Key word and index term searches were based on strategies used in previous systematic reviews and on words and terms used in selected recent articles. Public reporting does not map to standardized index terms in citation databases, so terms related to key concepts were used to identify search strings that were then combined to identify articles. These concepts and terms are listed in Table 1. The list of search terms was developed based on the index terms used for seminal articles supplemented by review and input from the TEP and AHRQ TOOs. The search term lists were reviewed and refined by librarians with expertise in both biomedical and social science literature searching. We also tested the search against the studies identified in prior systematic reviews and asked experts in the field to review the citation list resulting from these searches. The actual search strings are included in Appendix A.

Table 1 Public reporting concepts and corresponding search terms

Concept | Search Terms
Information dissemination and quality | Benchmarking/ or Information Services/ or Information Dissemination/ or Disclosure/ or Access to Information/ or Mandatory Reporting/ or Quality indicators, health care/ or Quality assurance, health care/ or Quality improvement/ or “process assessment (health care)”/ or “outcome assessment (health care)”/ or (quality adj2 indicator$).ti,ab
Health care settings | exp Hospitals/ or exp Physicians/ or Nursing Homes/ or Home Care Services/ or Competitive Medical Plans/ or Health Maintenance Organizations/ or Managed Care Programs/ or Insurance, Health/ or Medicare/ or Medicaid/ or Hospices/ or Ambulatory Care/ or Skilled Nursing Facilities/ or Group Practice/ or exp Primary Health Care/ or Institutional Practice/ or Private Practice/ or Family Practice/ or Physicians, Family/ or Professional Practice/ or Allied Health Personnel/ or Outpatient clinics, hospital/ or Academic Medical Center/ or Health Care Sector/ or Hospital Administration/ or Public Health Administration/ or Long Term Care Facilit$.ti,ab. or health care cent$3.ti,ab. or health care provider$.ti,ab. or (coronary or cardiac or cardiolog$).ti,ab.
Patient/consumer and provider behavior | Consumer Participation/ or Consumer Advocacy/ or Consumer Satisfaction/ or Patient Satisfaction/ or Decision Making/ or Choice Behavior/ or Attitude of Health Personnel/ or Physician’s Practice Patterns/ or Nurse’s Practice Patterns/ or Professional Practice/ or Guideline Adherence/ or Patient Selection/ or Patient Participation/ or Hospital Mortality/ or (decision$ or choice$ or choos$ or behav$ or patient outcome$).ti,ab.
Title abstract adjacency | (((Dissem$ or Disclos$ or Profil$ or Inform$ or Indicator$ or Metric$ or Rank$ or Compar$ or Score$ or Rating$ or Rate$ or data or measure$ or criteria or standard$ or account$ or report$ or release$ or initiative$ or Star) adj5 (Performan$ or assessment$ or evaluat$ or quality or public$ or consumer$ or patient$ or transparen$ or provider$)) or score card$ or (quality adj2 report$) or report card$ or league table$ or (star adj2 rating) or (Star adj2 performance)).ti,ab.
Known public reports | (Medicare Compare or nursing home compare or Calhospital Compare or California State Report Card or California Hospital Outcomes or myhealthcareadvisor or Massachusetts Health Quality or (Pennsylvania adj3 coronary) or (Hospital Quality adj2 Safety Survey) or Home health Compare or Physician Compare or (New York adj2 Cardiac adj2 Report$) or (New York adj5 surg$) or Cleveland Health Quality Choice or (HCFA adj5 mortality) or (HCFA adj5 death) or Federal employee health benefit guide or QualityCounts or CAHPS or HEDIS).ti,ab.

The search resulted in the identification of 13,318 citations and 11,809 articles after duplicates were removed. All citations were initially imported into an electronic database, EndNote X3^®^, and then uploaded to Distiller^®^, a specialized application for systematic reviews, for title and abstract triage, full text review, and abstraction. Twenty-five new studies were added to the review based on the updated search as well as recommendations from peer reviewers and public comments.

## Study Selection

Studies were selected from the identified citations through title and abstract triage followed by full text review. Research studies were included if they conformed to the definition of public reporting and objectives (see above) as well as the Population, Intervention, Comparators, Outcomes, Timing, and Settings PICOTS (see below) and addressed at least one of the stated Key Questions for this review. A variety of study designs were included, such as trials/experiments, nonrandomized experiments, observational studies, systematic reviews, and evaluation case studies. Studies were not excluded based on study design. The inclusion and exclusion criteria lists are included in Appendix B.

Title and abstracts were triaged by five reviewers, including the Lead Investigator and Co-Investigator (Ph.D. research faculty) and three Research Associates/Assistants (masters-level research staff trained in systematic review methods) for the first 300 articles then discrepancies and differences were discussed and reconciled. Another 200 titles and abstracts were submitted to dual review to confirm consistency. Once an acceptable level of agreement was reached, the remainder were divided among the reviewers and triaged. A second review of all excluded abstracts was conducted during the time period when the report was undergoing peer review.

Articles identified as potential inclusions for the review based on title and abstract were then advanced to full text review. In the full text review two reviewers classified all articles and inclusion/exclusion conflicts were resolved through discussion and consensus. Decisions made by reviewers were documented at each stage. We retained data on excluded studies and documented the reasons for their exclusion (Appendix C).

At the title and abstract triage stage, most studies that were excluded were dropped because they were not about the right topic. Given our search strategy and the lack of precise terms, many of the retrieved titles and abstracts were not about public reporting of health care quality data. These studies were about some other aspect of health care quality or about measures not publicly reported. Other studies did not meet our definition of public reporting and were excluded. Specifically, studies were excluded if:

- The quality data were not clearly publicly available or were unavailable to a large group such as all members of a health plan. Following the advice of our TEP we included studies of the impact of employer-provided data to employees about health plans because these data were made available to a large group even if they were not available to the general public. Studies in which the data were available to a limited number of stakeholders or to a certain type of stakeholder for feedback, quality improvement, benchmarking, or internal organization operations were not included as these data were not publicly available.
- The data were available but had to be purchased for more than a nominal subscription fee (e.g., a nominal fee would be a subscription to Consumer Reports or a similar publication or Web site).
- Data on individual clinicians was not about physicians or nurses. This exclusion was developed in consultation with the TEP and AHRQ. Other providers such as dentists and therapists were excluded in order to keep the review manageable and focused on quality rating of general health care services.
- Data included in the report were only for one organization or individual and were not comparative, meaning the single organization or individual could not be compared to others directly or to data for a national, State, or regional group of organizations or individuals.

Other studies that were excluded were articles about research that involved publicly reported health care quality data but did not correspond to our Key Questions. There were two main categories of these studies. One category included studies in which publicly reported data were used as the outcome measure in an evaluation of a different health care intervention. In these cases the public reports were not interventions that affect actions by health care providers or patients and lead to better outcomes. Instead they were an easily accessible source of data to use in the evaluation of other interventions after a problem was identified and an intervention executed.

Another category of studies excluded were articles that considered methodological issues related to the creation of the public report or the specific quality measures included in the reports. Many of these studies analyzed the validity of the measures that were reported or the risk adjustment scheme used to facilitate comparisons. Other studies described the development of the surveys used to collect the data that were ultimately publicly reported. While it is important that quality measures that are publicly reported are credible, evaluating the quality measures directly or the research evidence about the measures were deemed separate tasks that would require significant resources and expertise that were outside the scope of this review.

The remaining criteria used to exclude articles were:

- The public reporting was only about services that are not medical or directly health-related (e.g., food service, room décor).
- The study population was not human.
- The study had no original data or was a commentary, an editorial, or a nonsystematic review.
- The study was published before 1980.
- No English abstract was available for a non-English language article.

If an English abstract was available for non-English language article, it was evaluated according to the same criteria as English language articles at title and abstract triage. At full text review, English articles were reviewed first and then a judgment was made as to whether any non-English articles were likely to add significantly to the literature based on the English abstract, any data available in tables, and preliminary translations of section headings and titles of tables or figures. Articles that were likely to make a significant contribution to the results were then considered for full translation in accordance with current practice and standards for the conduct of systematic reviews. This resulted in the translation of one article for inclusion in this review.

## PICOTS Framework

This review is about the public reporting of quality information as a quality improvement strategy in health care. It focuses on the impact of public reporting on quality of care as the ultimate outcome of interest and the behaviors of two populations: patients, families, and purchaser of care and organizations and individuals who provide or facilitate the provision of health services as intermediate outcomes.

Specifying the Population, Intervention, Comparators, Outcomes, Timing, and Settings (PICOTS) for a systematic review is an approach used to generate answerable research questions, to structure the literature search, to determine inclusion/exclusion criteria, and to organize reports.

For our review of public reporting as a quality improvement strategy, the PICOTS are as follows:

### Populations

- Individuals or organizations that deliver health care and make decisions about how to deliver care.
  These included health care providers in all settings (inpatient, outpatient, nursing facility, home care, etc.) and at all levels (health plan, facility, group practice, individual clinician, etc.) unless specifically excluded in the scope or exclusion-inclusion criteria (e.g., individual clinicians included nurses and physicians in any specialty while other individuals such as dentists were excluded). Organizations such as hospitals and health plans have been the subject of many public reports as how they organize care and their policies have an impact on quality of care even though all care is ultimately delivered by individuals.
- Patients (or their representatives) making health care decisions and organizations that purchase health care services.
  Patients included any person seeking or receiving health care services. Patients may also be represented by family or designated guardians in specific decisions or by advocacy groups that call for changes in care delivery. Purchasers or organizations that purchase care for patients were included in this population as they make choices concerning which individuals and organizations that provide care are available to patients or they promote the use of certain providers. Advocacy groups may act for patients when they use their influence to promote improvements in the quality of care.

### Intervention

The intervention is public reporting of performance data on patient outcomes or health care delivery. Public reporting for this review is defined in detail in the Scope and Key Questions in the Introduction section.

### Comparators

In most studies, public reporting of quality data is compared with situations in which the data are not available or not publicly reported. Occasionally comparisons are made across different reports, different contexts for public reports, or differences in content and formats of reports. This detail is provided in the Evidence Tables and the study descriptions included in summary tables and the narrative.

### Outcomes (Specified for Each Key Question)

- Key Question 1. Improvements in quality of health care.
  Improvements in care and patient outcomes may be combined in some studies and reviews under the heading of “clinical outcomes.” For this Key Question the focus was on improvement. Examples of potential outcomes in this category included decline in mortality for cardiac surgery patients, an increase in actual implementation of a guideline, or greater provision of a service known to provide value. The actual improvements in care delivery and patient outcomes were the goals of quality improvement and public reporting when it was used as a quality improvement strategy.
  Change in intermediate outcomes were included in Key Question 3, as it was not a given that all change will lead to improvement; furthermore, some studies may only measure the change in care processes, organizational performance, or clinician behaviors and not have sufficient data to determine the impact of that change.
  Quality improvement in health care was the focus of the CQG series, and this review conforms to the definition for the series, which states that the “series aims to assemble the evidence about effective strategies to close the ‘quality gap,’” which simply refers to the difference between what is expected to work well for patients based on known evidence and what actually happens in day-to-day clinical practice across populations of patients. In this statement the implied definition of quality is “what is expected to work well,” which is similar to the Institute of Medicine definition, “the degree to which health services for individuals and populations increase the likelihood of desired health outcomes and are consistent with current professional knowledge.”25 We applied this broad definition when determining if the public reporting in studies to be included were aimed at improving quality of care.
- Key Question 2. Harms included any unintended negative consequence or adverse events for any members of the populations listed above that resulted from public reporting. Harms are outcomes that can result in a reduction in quality of care.
  Harms could occur for either patients and purchasers, or the individuals and organizations that provide care. Examples of harms could include:
  Potential harms to patients
  1. Reduced access to services if providers select patients or offer services in a different way (e.g., pull out of a market) in order to improve their publically reported quality ranking or score.
  2. Compromised data quality and reduced confidence in data if people attempt to manipulate the publicly reported data.
  3. Reduced patient engagement and/or negative outcomes if patients believe, based on a report, that they are receiving services from a high-quality provider and therefore do not need to be vigilant and involved in their own care; a report provides too much information and reduces comprehension; or the meaning of the data is not understood and therefore not used.
  4. Increased anxiety due to understanding that health care is not perfect and worrying about one’s own health condition or care.
  Potential harms to providers
  5 Misclassification of providers by the reporting, resulting in negative impacts on their market share, contracting arrangements, or reputation.
  Potential harms to patients or providers
  6 Public reporting that results in worsening of quality for any reason (including those listed above.
- Key Question 3. Changes in health care delivery structures and processes.
  This intermediate outcome, changes in health care delivery, may be of particular interest in this review. Individual providers or organizations might change processes (e.g., adopt guidelines, change policies, increase quality improvement efforts, or monitor individual providers) or structures (e.g., electronic ordering, automated reminders, and staff capacity) in an effort to improve their performance on the outcomes or indicators that are publically reported. However, this change in delivery may or may not necessarily lead to improvement in quality of care—the ultimate outcome of interest. Changes could result in improvement, no improvement, or worsening of outcomes, or the study design may not include measures of the ultimate impact on quality of care.
- Key Question 4. Changes in patient, or their representative, or purchaser health care behavior.
  Patient and purchaser behaviors include but are not limited to their selection of health care providers or use of health services. Their behaviors may also include more general advocacy for higher quality of care and for better information and decision support. Patient behaviors are limited to those related to the reporting of quality data. Changes can be negative as well as positive. An example of a positive change would be increased comprehension of health information by patients. Negative changes could include patients becoming overwhelmed by data and dismissing all reports, relying too much on a rating and not becoming engaged in their own care, or not understanding reports and relying on less reputable sources of information. These negative changes could result in harms. Change in behaviors can also include information seeking and developing the ability to retrieve the information desired.
- Key Questions 5 and 6.
  These Key Questions focus on evidence that the outcomes listed above are affected by characteristics of the reports and contextual factors. This is particularly important given the quality improvement focus of this review, which makes the emphasis different from other reviews. Quality improvement requires consideration not just of what works but also of what works for whom and when. Understanding if the literature can tell us more about how the impact of public reporting varies across report characteristics (Key Question 5) and different contexts (Key Question 6) is important if the results of our review are to help inform future public reporting efforts. Particular attention was paid to these characteristics and factors as we abstracted information from the identified articles.

### Timing

No minimum duration of followup time from the availability of the public report to the measurement of the intermediate or ultimate outcome was required.

### Settings

Studies of public reporting in any level or setting for health care delivery including health plans, health systems, hospitals, outpatient services or practices, individual clinicians, hospice, home health care, or nursing facilities were included in this review.

## Types of Studies

At the title and abstract triage phase we did not exclude any study based on study design if it would have been included based on the other inclusion and exclusion criteria. Public reporting is a public health, public policy, or educational intervention rather than a strictly clinical intervention. We wanted to identify and consider all types of evidence available as we proceeded with the review.

At the full-text review stage, we identified the designs of the studies that met all other criteria and we refined our approach. Trials and observational studies that contained empirical data on an outcome that corresponded to a stated Key Question were retained for both abstraction and quality assessment. This included the rare randomized trials in this field. Most studies in this category are observational and differed predominately by whether there was a non public reporting group or time period for comparison. Many of the studies were time series, either interrupted time series or multiple measures post public reporting only. For the study design terminology used in this review see Appendix D.

The search identified many qualitative studies, including interviews, focus groups, and descriptive surveys that reported outcomes that were necessary but not sufficient precursors to the outcomes in the stated Key Questions (e.g., awareness of reports, comprehension of content, attitudes toward public reporting including specific presentations, and intention to use). Also we identified results from lab-type experiments that involved hypothetical choices or decisions tasks that usually used mock reports based on some actual data. Both of these types of studies may be particularly relevant to the Key Questions 5 and 6 about how the characteristics of the public reports and contextual factors affect the impact of public reporting on quality of care and they may add to our understand of the impact of public reporting on outcomes. For this reason they were retained, but they were not assessed for quality and their abstraction was abbreviated. In order to maintain the distinction between these two groups of studies, they are reported in separate evidence tables and the qualitative studies, descriptive surveys, and lab-type experiments are summarized separately at the end of each results section for each health care setting. Since they did not measure the outcomes stated in the Key Questions they are also not included in the strength of evidence assessments.

When study types were excluded at this stage this was because based on the full text review they did not meet our original inclusion/exclusion criteria. For example:

1. The single case studies we excluded did not have comparators.
2. Descriptive studies of implementation of public reports were excluded for lack of included outcomes.
3. Descriptive surveys or other qualitative studies that were predominately about another subject (not about public reporting) but contained one item or question about the public disclosure of some type of data were excluded for not being studies of public reporting.

## Analytic Framework

The analytic framework in Figure 1 represents relationships among the Populations, Intervention, and Outcomes that are the focus of this systematic review and illustrates how these relationships translate into the Key Questions. The relationships between the intervention (public reporting) and intermediate outcomes (Key Questions 3 & 4), as well as the relationship between the intermediate outcomes and the ultimate improvement in the quality of health care (Key Question 1), are included. Harms are another potential consequence of public reporting (Key Question 2). The relationship between the intermediate outcomes and ultimate improvement is represented with dashed lines and do not have corresponding Key Questions because this review does not explicitly evaluate evidence about these relationships. Rather this framework shows key pathways by which public reporting may lead to harms, intermediate outcomes and ultimate improvements in quality of health care.

## Data Extraction

Following full text review, we extracted the following data from all included studies:

- Type of health care setting or provider
- Study objective
- Geographic location
- Sample and groups or time period used for comparisons
- Study design
- Name and any descriptive information about the public report (format, content and availability, etc.)
- Reported contextual factors (environmental characteristics and characteristics of the decisionmaker)
- Outcomes measured
- Findings for each Key Question
- The sponsors of the research or article

All study data are presented by health care setting in the Evidence Tables in the Appendixes. These data were then used to generate the summary tables and narratives in the text. A number of public reports have been the subject of multiple studies. Descriptive information about the reports that were the subject of multiple studies is included in Appendix E. Ongoing accuracy of extraction was monitored by randomly selecting articles abstracted by one abstractor to be checked by a second reviewer.

## Quality Assessment of Individual Included Studies

Our assessments of the quality of individual studies are based on the recommendations in chapter titled “Assessing the Risk of Bias of Individual Studies when Comparing Medical Interventions” in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter, Methods Guide).25,26 Our approach is summarized below and more detail is provided in Appendix F.

We pre specified six key criteria that could be applied to the various types of observational studies as well as the few studies that use random assignment to evaluate public reporting. We did not use evaluation tools that are study design-specific. We reviewed the types of bias and the corresponding suggested criteria discussed in the Methods Guide chapter and followed the recommendation that those most relevant to the topic and appropriate for the study designs be employed.

Based on this evaluation we selected six criteria for this review:

1. How adequate was randomization (for randomized studies) or how appropriate was selection of comparison group or time (for observational studies)?
2. How similar are groups at baseline (or time periods) or how well did the analysis control for differences?
3. How well does the design or analyses account for important potential confounding and modifying variables?
4. How well does the study rule out any impact from an unintended exposure or a concurrent intervention that might bias results?
5. How well are all potential outcomes prespecified, and are the prespecified outcomes reported?
6. How well are primary outcomes assessed? Were valid and reliable measures used and implemented consistently across all study participants/groups?

Criteria 1, 2, and 3 concern selection bias; criteria 4, performance bias; criteria 5, reporting bias; and criteria 6, detection bias. Applying these criteria consistently across raters for an intervention like public reporting required that we specify the definitions of different types of bias and explicitly state how they were applied in our assessment of studies of public reporting. This detail is provided in Appendix F.

These six criteria were used by two raters who independently rated each article on these six criteria and made an overall assessment of “good”, “fair”, or “poor” quality based on definitions from the Methods Guide cited above. These definitions apply to all the included quantitative studies and are:

- Good quality/low risk of bias implies confidence on the part of the reviewers that results represent the true treatment effects (study results are considered valid). In the case of this review “treatment effects” is interpreted as the impact of the intervention and public reporting on any of the specified outcomes regardless of the study design. The study reporting is adequate to judge that no major or minor sources of bias are likely to influence results.
- Fair quality/medium risk of bias implies some confidence that the results represent true treatment effect. The study is susceptible to some bias and the problems are not sufficient to invalidate the results (i.e., no flaw is likely to cause major bias). The study may be missing information, making it difficult to assess limitations and potential problems.
- Poor quality/high risk of bias implies low confidence that results represent true treatment effect. The study has significant flaws that imply biases of various types that may invalidate its results; these may arise from serious errors in conduct, analysis, or reporting, large amounts of missing information, or discrepancies in reporting.

The overall assessment was not derived from a direct linear combination of the six criteria. Given the nature of public reporting as an intervention, the criteria corresponding to selection bias (criteria 1, 2, and 3 listed above), specifically how the comparison was structured, the degree of similarity at baseline and possible confounding, were of greatest concern when determining the level of confidence we could have in the result of each study. For this reason it is possible for a study to be given an overall assessment of “poor” even if some individual criteria were rated as “good”.

After completing the ratings independently, ratings were compared and differences reconciled through discussion and input of a third rater when needed. The quality assessment rating for all included quantitative studies are included in Appendix G. We did not assess the quality of the qualitative and lab-type experiments with hypothetical public reports. While there are tools available to rate the quality of qualitative research, none have been recommended in guidance to the EPCs, used consistently in AHRQ-sponsored reviews, nor is one going to be used in the CQG series. We also did not assess the quality of identified systematic reviews as they were used only to identify studies for inclusion and their results were not incorporated into this review.

## Data Synthesis

We separated studies into four groups by the health care settings that were the subject of the public reports of quality. These four settings are hospitals, individual clinicians and outpatient group practices, health plans, and long-term care services (predominately nursing homes). Public reporting has a different history in each of these settings and the public reports are different in terms of content and presentation. Abstracting the studies and synthesizing the evidence first by setting allowed patterns of evidence within setting to then be summarized by the Key Questions across all four settings.

Summary tables are included at the end of the sections on results by settings. These are the source of the results by Key Question across settings presented at the beginning of the result sections. The heterogeneity of outcomes precluded formal quantitative meta-analysis.

## Rating the Body of Evidence for Each Key Question

The strength of the body of evidence for each Key Question was rated according to the recommendations in the chapter “Grading the Strength of a Body of Evidence When Comparing Medical Interventions” in the AHRQ Methods Guide.25,26 This approach includes assessing groups of studies that address the same Key Question and the same outcome on four criteria: quality of the studies, consistency of the results, directness, and precision. Based on these and the nature of studies (number of studies, number of subjects, and study designs) the strength of a body of evidence available to answer the questions that are the subject of the systematic review is given an overall rating of high, moderate, or low. This is an adaptation of the GRADE approach developed and endorsed by the EPCs.

These assessments were based on the results of the quantitative studies. Ratings were made for each Key Question by two raters and then were presented and discuss by the entire study team in order to reach consensus and assure consistency in the ratings.

The evidence for outcomes across the included studies was graded as high (high confidence that the evidence reflects the true effect; further research is unlikely to change our confidence or and the estimate of the effect), moderate (moderate confidence that the evidence reflects the true effect; further research may change our confidence or the estimate of the effect), low (low confidence that the evidence reflects the true effect; further research is likely to change our confidence and the estimate of the effect), or insufficient (evidence is unavailable or does not permit a conclusion). When only one or two studies were available for a specific outcome they were labeled insufficient unless the studies were large or had particularly strong designs in terms of reducing risk of bias.

## Applicability

Applicability involves “judgments about whether the available research evidence reflects ‘real world’ practice” and whether it is “clear for which patients and which circumstances the review’s conclusions can be used to make clinical or policy decisions.”27 Applicability for a review includes assessing the extent to which the literature identified can answer the question posed in the review.

The applicability of the group of studies included in this review about public reporting depends on the user and the intended use of the report. Applicability is assessed, rather than scored or rated, and may vary according to the characteristics of the population studied and to the characteristics of the public reports. For example, national studies may be more generally applicable, whereas studies conducted in one geographic area may or may not be applicable to other geographic areas because of differences in their health care markets, particularly with regard to the availability of health care providers or health plans. Alternatively, national studies conducted in one country may be more or less applicable to other countries depending on whether the health care systems differ significantly. Characteristics of the specific populations studied (e.g., high education and health literacy, older age, etc.) may also limit the generalization of research findings to expected results in populations with very different characteristics. Differences in the data included in the public reports, their formatting, and their mode of delivery (e.g., paper, Web, apps, etc.) may limit the applicability of findings from studies of specific types of public reports to expected results from reports that are substantially different in form and content. For these reasons, we abstracted data about the reports and the context when it was reported in the articles and provided these to allow an assessment of applicability to different situations.

An additional issue related to applicability concerns differences in health care decisions. Public reporting has been, and continues to be, used for a variety of settings and levels. As was done in prior reviews, we have included all studies we could locate regardless of setting or level. However, to combine all studies would be implying that selecting a cardiac surgeon is the same as selecting a nursing home is the same as selecting a health plan for multiple types of needed care in the future. For this reason our first level of analyses and the reporting of our results are by four types of settings (Hospitals, Individual Clinicians, Health Plans, and Long-Term Care). Then in the results summary, overview, and discussion we attempt to look for lessons across settings. However, we are cognizant of the fact that such an approach may have limitations and mask the very real differences among health care decisions and the potential differential impact public reporting could have on specific types of health care decisions.

## Peer Review and Public Commentary

Experts in public reporting and decisionmaking and individuals representing stakeholder and user communities were invited to provide external peer review of this Comparative Effectiveness Review (CER); AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ website for 4 weeks to elicit public comment. We addressed all reviewer and public comments, revised the text as appropriate, and documented disposition of comments in a report that will be made available 3 months after the Agency posts the final CER on the AHRQ Web site.