# Introduction

A substantial amount of research exists demonstrating that health care frequently fails to meet the current standards of quality care.1,2 Errors, suboptimal management or control of disease, and overutilization or underutilization of services are more likely to occur when high-quality, evidence-based health care is not provided. The potentially serious consequences for patients and their families include higher mortality, increased morbidity, decreased quality of life, and higher cost of care. Additionally, low-quality care and inconsistencies in quality are linked to health care disparities.3,4

Three general approaches are hypothesized to address quality gaps in a quality improvement framework: measuring quality, influencing quality, and improving quality.5,6 In this quality improvement framework, making quality, safety, or performance data publicly available is categorized as a means of influencing quality. Public reporting may influence quality by providing incentives for change.

This report focuses on how the public reporting of health care quality information may provide incentives for quality improvement that ultimately produce higher quality care. It is one in a series of reports titled Closing the Quality Gap: Revisiting the State of the Science (CQG series) that examines the role of several interventions in promoting quality health care. This focus is not meant to suggest that quality improvement is the only goal of public reporting or that public reporting does not play other roles in health care and health policy. Public reporting can be an important element in transparency, accountability, patient engagement, community support, and trust in addition to its impact on selection by patients, provider behavior, and independent of its potential impact on quality of care.

Applying the quality improvement framework to public reporting led us to consider how quality might be influenced based on the different incentives public reports create for different people and organizations. The incentives may be for the “consumers” of health care including patients, families, or advocates who act on the behalf of patients, or other purchasers of health care services such as employers, who select the options available to their employees. Public reporting could also provide incentives for the individuals and organizations that provide or arrange care including individual clinicians, hospitals, long-term facilities or services, and health plans. The ways these two populations could respond to public reporting constitute the various ways public reporting can lead to improved quality of care. Underlying these are two major assumptions: (1) given choices and information, patients and purchasers will choose higher-quality providers; and (2) health care providers (both individual clinicians and organizations) and groups or plans that arrange health care services will strive to provide high-quality care when information about their performance is publicly available to patients, health plan members, their peers, policymakers, and the media. It is assumed that patients are motivated by the desire to maximize the benefits they derive from health care by obtaining the highest quality of care available. Individual clinicians, hospitals, and other organizations that provide or arrange health care want to attract new patients or members and avoid losing existing ones. They may also be motivated by concern about their reputation among their peers or by professional and organizational commitments to providing high quality care.

These assumptions provided the rationale for considering public reporting as a quality improvement strategy. Historically, these assumptions have been partially based on theories from economics7,8 and behavior change.9 According to economic theory, public reporting corrects asymmetries in information. Public reporting accomplishes this by making previously unobservable quality of health care more transparent so everyone involved in a transaction has access to essential information and can use this information in making choices. Behavior change models and quality improvement theories stress the importance of accessible information on measurable, actionable processes and outcomes as motivation for practice improvement. Public reporting in this context can provide data that translates to goals or targets for practice change and incentives to improve.

While these theories may help understand how public reporting is expected to work, they do not completely explain patients or providers behaviors nor do they necessarily require that public reporting be the sole motivator for behaviors that impact quality of care directly or indirectly. They also do not address the challenges inherent in producing and transmitting information to multiple audiences with different expectations and skills. As is the case with other social interventions, the impact of public reporting is mitigated by many factors such as the extent to which patients have choices, the competing demands on individual clinicians or provider organizations, the relevance, timeliness, and accessibility of the reported information, and the different uses of quality measures in health care delivery and policy. These are only a few examples of the several factors operating in the complex realm of health care and decisions in which public reporting occurs.

The modern history of public reporting dates to over 25 years ago when the Health Care Financing Administration (HCFA) in the United States released hospital mortality data in 1986. Dubbed the “death list,” this received media and public attention. Critiques in the health care community focused on both issues with the quality of the data and the appropriateness of public reporting overall, and in 1992 the program was suspended. Some other public reports have shared this fate and are no longer produced (e.g., the hospital report created by the Cleveland Health Quality Choice program) while others now have almost a 2-decade history (e.g., the New York and Pennsylvania Coronary Artery Bypass Graft [CABG] reports and the Healthcare Effectiveness Data and Information Set [HEDIS]).

The relatively long history of public reporting in health care has provided numerous opportunities for the impact of public reporting on quality to be studied in a variety of settings and levels including health plans, hospitals,10,11 individual clinicians, nursing homes,12 postacute care,13 and home care.14 However, the results of these studies have been inconsistent. For example, some studies have reported improvements in specific health services, while other studies have documented unintended negative consequences, including motivating providers to select lower-risk patients in order to improve their quality score. A review published in 2008 (including studies of health plans, hospitals and individual clinicians through 2006) concluded that although there is scant evidence that publishing performance data improves quality of care and that evaluation of public reporting systems is needed, some evidence suggests that public reports stimulate quality improvement activities at the hospital level.15

Today, Federal and State government agencies, community quality collaboratives, and other organizations are continuing to invest resources in public reporting as one possible intervention to bridge the gap between current and high-quality practice in health care. The Agency for Healthcare Research and Quality (AHRQ) and the Robert Wood Johnson Foundation has supported public reporting through their Chartered Value Exchange (CVE) (www.ahrq.gov/qual/value/lncveover.htm) and Aligning Forces for Quality (www.rwjf.org/qualityequality/af4q/) programs. The CVEs, also known as community quality collaboratives, are committed to public reporting and transparency as part of their mission to promote quality improvement. They involve more than 600 health care leaders and cover more than one-third of the U.S. population. Public reporting is also a component of the transparency initiatives of several government agencies that include more explicit decisionmaking procedures and open meetings, in addition to the routine release of documents and data.

As part of their efforts to promote public reporting, government agencies are making technical assistance resources available. The CVEs have a learning network (www.ahrq.gov/qual/value/lncveover.htm); an AHRQ Web site (www.talkingquality.ahrq.gov/) is devoted to public reporting resources including a recent series of reports on best practices in public reporting,16–18 and a National Summit on the Future of Public Reporting for Consumers was convened by AHRQ in March 2011 (a subset of the commissioned papers were published in a leading health policy journal19–21). These programs, along with other conferences about creating and using reports and other decision-support tools to engage consumers and providers, demonstrate the continued interest in public reporting as a quality improvement strategy for a variety of types of health care organizations and individual providers.

This report was designed to be timely, given the significant changes that have occurred in the scope and nature of public reporting since the last published systematic review15 and the questions that remain regarding the extent to which public reports result in quality improvements and higher-quality health care. Medicare has substantially expanded its public reporting program and now provides quality data via sections of the Medicare.gov Web site that include Medicare Plan Ratings, Hospital Compare, Nursing Home Compare, Home Health Compare, and Dialysis Facility Compare. Physician Compare will soon be available. Additionally, health data from many more sources are now available with minimal restrictions to patients, health care providers, and purchasers. New technologies allow for innovative data collection (e.g., Global Positioning System tracking of asthma inhaler use), aggregating data from consumer feedback sites, customization of data with apps that simplify the combination of data from multiple sources, and accessing more data available in real time.22 These efforts and continuing commitments to transparency and patient-centered health care are likely to contribute to substantial increases in the amount of publicly available health care-quality data. Changes under the 2010 Affordable Care Act (Public Law 111-48) may also increase the availability of data and the number of people making decisions about health care services. These new programs and trends suggest that public reporting may be undergoing a transformation. The caveat to this, however, is that as a systematic review this report is limited to an assessment of the public reporting that has been the subject of research and evaluation studies.

## Definition of Public Reporting and Scope

Our definition of public reporting was designed to situate public reporting in the context of quality improvement in health care as that is the theme of the CQG series. We developed the definition based on the history of public reporting, prior reviews, our preliminary review of the literature, our initial research on current health care public reports, and our understanding of other transparency-driven initiatives in health care. An initial draft definition was refined based on input from the Technical Expert Panel (TEP). The result of this process was the following definition that shaped the scope of this review. Additional detail is provided in the Methods section about how this definition shaped our inclusion and exclusion criteria.

Public reporting is data, publicly available or available to a broad audience free of charge or at a nominal cost, about a health care structure, process, or outcome at any provider level (individual clinician, group, or organizations [e.g., hospitals, nursing facilities])or at the health plan level. While public reporting is generally understood to involve comparative data across providers, for purposes of this review we are adopting a broader approach to include findings in which one provider is compared to a national/regional data report on performance for which there are accepted standards or best practices.

The potential contribution of this review to the consideration of public reporting as a quality improvement strategy is that identified studies may offer insights not only into the effectiveness of public reporting for quality improvement, but also into such issues as when information is needed,23 how it is best formatted and presented, and what is perceived as useful by different audiences.24 Our synthesis attempted to include these considerations and other characteristics of reports and contextual factors in order to inform decisions about the use and development of public reporting as a more effective quality improvement strategy. However the extent to which this is possible is limited by whether studies of public reporting provide this type of information.

## Objectives and Key Questions

Given the resources devoted to public reporting and the desire to synthesize existing research knowledge to inform future public reporting efforts, the objectives of this systematic review were:

- To determine the effectiveness of public reporting as a quality improvement strategy by evaluating the evidence available about whether public reporting results in improvements in health care delivery and patient outcomes (Key Question 1) and evidence of harms resulting from public reporting (Key Question 2).
- To determine whether public reporting leads to changes in health care delivery or changes in patients’ or purchasers’ behaviors (intermediate outcomes) that may contribute to improved quality of care (Key Questions 3 and 4).
- To identify characteristics of public reports and contextual factors that can increase or decrease the impact of public reporting (Key Questions 5 and 6).

The Key Questions correspond to these objectives. The Key Questions were reviewed and refined in consultation with TEP as well as the researchers and the AHRQ staff coordinating the series. The Key Questions are first listed divided by the objective they address and then each question is repeated with additional description and clarification:

### Objective 1

#### Key Question 1

Does public reporting result in improvements in the quality of health care (including improvements in health care delivery structures, processes, or patient outcomes)?

#### Key Question 2

What harms result from public reporting?

### Objective 2

#### Key Question 3

Does public reporting lead to change in health care delivery structures or processes (at levels of individual providers, groups, or organizations [e.g., health plans, hospitals, nursing facilities])?

#### Key Question 4

Does public reporting lead to change in the behavior of patients, their representatives, or organizations that purchase care?

### Objective 3

#### Key Question 5

What characteristics of public reporting increase its impact on quality of care?

#### Key Question 6

What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care?

### Key Question 1 Does public reporting result in improvements in the quality of health care (including improvements in health care delivery structures, processes, or patient outcomes)?

Improvements in care and patient outcomes may be combined in some studies and reviews under the heading of “clinical outcomes.” For this Key Question the focus is on improvement. Examples of potential outcomes in this category include decline in mortality for cardiac surgery patients, an increase in actual implementation of a guideline, or greater availability of service with known value. The actual improvements in care delivery and patient outcomes are the goals of quality improvement and public reporting when it is used as a quality improvement strategy.

Change in provider behavior or policy is an intermediate outcome included in Key Question 3. This is separate because it is not a given that all change will lead to improvement; furthermore, some studies may only measure the change in care processes or providers’ behaviors that are expected to lead to better quality and may not measure the ultimate health care outcome.

### Key Question 2 What harms result from public reporting?

Harms include any unintended negative consequence or adverse events resulting from public reporting. Harms could affect patients and purchasers, or the individuals and organizations that provide care. Examples of harms include:

- Reduced access to services if providers select patients or offer services in a different way (e.g., treat only low-risk patients or pull out of a home care market) in order to improve their publically reported quality ranking or score.
- Reduced patient engagement and/or negative outcomes if patients believe, based on a report, that they are receiving services from a high-quality provider and therefore do not need to be vigilant and involved in their own care; a report provides too much information and reduces comprehension; or the meaning of the data is not understood and therefore not used.
- Increased anxiety due to understanding that health care is not perfect and increased worry about one’s own health condition or care.
- Misclassification of providers by the public reports resulting in declines in market share, contracting arrangements, or reputation.
- Compromised data quality and reduced confidence in data if people attempt to manipulate the publically reported data.
- Public reporting that results in no improvement or worsening of quality for any reason.

### Key Question 3 Does public reporting lead to change in health care delivery structures or processes (at levels of individual providers, groups, or organizations [e.g., health plans, hospitals, nursing facilities])?

This intermediate outcome, changes in health care delivery, may be of particular interest in this review. Individual providers or organizations might change processes (e.g., adopt guidelines, change policies, increase quality improvement efforts) or structures (e.g., electronic ordering, automated reminders, staff capacity) in an effort to improve their performance on the outcomes or indicators that are publically reported, maintain their reputation, attract more patients, or secure more contracts. However, this change in delivery may or may not necessarily lead to improvement in quality of care—the ultimate outcome of interest. Changes could result in improvement, no improvement, or worsening of outcomes, or the study design may not include measures of the ultimate impact on quality of care.

### Key Question 4 Does public reporting lead to change in the behavior of patients, their representatives, or organizations that purchase care?

Patients’ and purchasers’ behaviors include but are not limited to their selection of health care providers or use of health services. Their behaviors may also include more general advocacy for higher quality of care and for better information and decision support. Patient behaviors are limited to those related to the reporting of quality data in this review and do not include responses to health care education materials. Purchasers may change their contracting practices based on public quality information. Changes can be negative as well as positive. An example of a positive change would be increased comprehension of health information by patients. Negative changes could include patients becoming overwhelmed by data and dismissing all reports, relying too much on a rating and not becoming engaged in their own care, or not understanding reports and relying on less reputable sources of information. These negative changes could result in harms. Change in behaviors can also include information seeking and developing the ability to retrieve the information desired.

### Key Question 5 What characteristics of public reporting increase its impact on quality of care?

The way in which health care data are publicly reported may affect the impact they have on intermediate and ultimate outcomes. Specific examples of important report characteristics are:

- Acceptable/Appropriate. Patients and health care providers find the data believable and have confidence in data quality/accuracy, and the data are applicable to their situation, including whether reports are general, disease specific, or specific to subgroups of the population.
- Accessible. The reports can be understood by people in the populations. The format, language, and graphics can be understood by the target audiences. The target population can understand the meaning of the report. Accessibility also includes how reports are publicized and promoted.
- Actionable. Patients: Reports are available when and where a decision needs to be made. Individuals or organizations that provide care: Reports are related to practices they can, or perceive they can, change, or reports are related to other factors they can influence.

### Key Question 6 What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care?

Contextual factors that could make a health care decision more or less amenable to influence from public reports include three nested levels. First, there are the characteristics of the specific decision to be made (e.g., what type of care is needed, how many health care options are available, how much time before the decision needs to be made, and what a provider can influence). Second, a person or organization makes each specific decision, and the characteristics of the decisionmaker (patient/patient representative/purchaser or individuals/health care organizations that deliver care) may be important. For example, patient literacy is assumed to affect the impact of public reports or the importance of peer approval to a provider may motivate change. Third, the decision and the decisionmaker exist in an environment that includes factors such as market characteristics, public policies (e.g., other incentive programs), and organizational requirements, all of which may enhance or diminish the impact of public reporting.