# Peer Reviewers

Anne-Marie J. Audet, M.D., M.Sc., S.M.

Vice President, Health System Quality and Efficiency

The Commonwealth Fund

New York, NY

Margaret Gerteis

Senior Researcher

Mathematica Policy Research

Cambridge, MA

Edward L. Hannan, Ph.D., M.S., M.S., FACC

Distinguished Professor, School of Public Health

Department of Health Policy, Management and Behavior

Department of Public Administration and Policy

University at Albany, State University of New York

Rensselaer, NY

Lauren McCormack, Ph.D., M.S.P.H.

Senior Director, Health Communication Program

RTI International

Research Triangle Park, NC

Diane Stollenwerk, M.P.P.

Vice President of Community Alliances

National Quality Forum

Washington, DC

Susan Schwartz Woods, M.D., M.P.H.

Consumer Informatics Specialist and Staff Physician,

Portland Veterans Affairs Medical Center

Assistant Professor, Oregon Health & Science University

Portland, OR