# Technical Expert Panel

Tanya Alteras

Associate Director, Consumer-Purchaser Disclosure Project

National Partnership for Women & Families

Washington, DC

Carol Cronin

Executive Director, Informed Patient Institute

Annapolis, MD

Joseph Francis, M.D., M.P.H.

Chief Quality and Performance Officer

Veterans Health Administration

Washington, DC

David Hopkins, Ph.D.

Director of Quality Measurement, Pacific Business Group on Health

San Francisco, CA

Vince Kerr, M.D.

President, Care Solutions at Uniprise, a United HealthCare Group Company

United Healthcare National Accounts

New York, NY

Jill LeMasters

Project Leader, Indiana Health Information Exchange

Indianapolis, IN

Dana Richardson, R.N., M.H.A.

Director, PCPI Operations

American Medical Association

Chicago, IL

Patrick S. Romano, M.D., M.P.H.

Professor of General Medicine and Pediatrics

UC Davis School of Medicine

Davis, CA

Dale Shaller

Shaller Consulting Group

Stillwater, MN