# Discussion

Publicly reporting quality information on health care is a population-level intervention that can serve many purposes for a variety of stakeholders. For this review we considered public reporting as a mechanism designed to influence health care delivery, and ultimately health care outcomes, by creating incentives that encourage the provision of high-quality care. Our focus conforms to the theme of the Closing the Quality Gap: Revisiting the State of the Science series (CQG series) but it is not meant to suggest that public reporting is intended only as a quality improvement strategy. This purpose does delineate what was included in the review and how we assess the identified research.

Public reporting has a 25-year modern history that began in the United States but has gained traction in other countries as efforts to use market mechanisms and transparency to promote quality improvement and the provision of high-quality health care services have become increasingly popular.

Early public reports on hospital mortality in the United States and hospital-level and then surgeon-specific cardiac surgery outcomes in New York State and Pennsylvania generated a significant amount of controversy and research. Studies of reports on health plans came after the public reports were created and were based on Healthcare Effectiveness Data and Information Set (HEDIS) and Consumer Assessment of Healthcare Providers and Systems (CAHPS) data. Their public release was first voluntarily, then later mandated by many States and the Federal government for some programs. Most recently, the creation and release of quality measures for long-term care services (nursing homes and home health agencies) in 2002 and 2003 has been the subject of public reporting through the Medicare Compare Web sites. Through the Medicare.gov Web site the Centers for Medicare and Medicaid Services (CMS) provides information on a variety of health services and reports on additional services that are being added to Medicare Compare as data and measures are available. These above-mentioned public reports are the subject of the majority of public reporting research and the volume of research has increased as these public reports have become available. Most of this research has been funded by U.S. government agencies or private foundations (the funder of each study is included in the evidence tables in the Appendixes). Figure 3 below presents the number of quantitative studies identified for this review by publication year and by health care setting in order to illustrate trends in research production.

Figure 3 Number of included quantitative studies by year and health care setting

Note: 2011 includes two studies that were available online or presented at conferences in 2011 but were not published until 2012.

Figure 3. This figure presents the number of quantitative studies identified for this review by publication year and by health care setting. This is provided in order to demonstrate trends in research production. The period of time is 1988 through 2011. Studies of hospitals occur consistently from 1988 forward, studies involving health plans first appear in 1998, studies involving individual clinicians appear sporadically over the period, and studies of long term care settings first appear in 2005 and increase markedly through 2011. The number of articles per year varies from a low of one (in 1988, 1995, and 1996) to 14 in 2010.

The main findings from this review are summarized in Table 8. The results in this table are presented by Key Question and then by outcome across health care settings. We have also assessed the strength of the body of evidence and this determination is included in Table 8. The assessments of the criteria that contributed to these determinations of the strength of evidence are included in Appendix P. The variety of outcomes underscores the heterogeneity of the research literature about health care public reports. Different outcomes have been used across studies, prohibiting quantitative synthesis and making even qualitative synthesis difficult on some topics.

Table 8 Summary evidence table: effectiveness of public reporting of health care quality as a quality improvement strategy

Key Question | Outcome: Conclusion | Total Studies^a^ Settings (Number of Studies) | Strength of Evidence
Key Question 1 Does public reporting result in improvements in the quality of health care (including improvements in health care delivery structures, processes, or patient outcomes)? | Reduction in mortality: Public reporting was associated with a small decline in mortality after controlling for trends in reductions in mortality. | 19 Hospitals (18) Individual clinicians (1) | Moderate
Key Question 1 Does public reporting result in improvements in the quality of health care (including improvements in health care delivery structures, processes, or patient outcomes)? | Quality and process Indicators. (e.g. CAHPS, HEDIS, Nursing Home Compare): Most studies found that public reporting is associated with improvement in quality and process indicators, though this varies across specific measures. | 19 Hospitals (5) Health plans (5) Long-term care (9) | High
Key Question 2 What harms result from public reporting? | Increase in Mortality: In one study an increase in mortality was attributed to public reporting. | 1 Hospitals | Insufficient
Key Question 2 What harms result from public reporting? | Inappropriate diagnosis and treatment: In one study the hypothesis that a publicly reported measure would lead to over diagnosis and prescribing was not supported. | 1 Hospitals | Insufficient
Key Question 2 What harms result from public reporting? | Access restrictions: Most studies concluded that public reporting does not contribute to reduced access for patients (e.g., avoiding high-risk patients, referring high-risk patients out of State). Fewer studies have identified instances of reduced access, suggesting this conclusion could be changed based on future research. | 13 Hospitals (8) Individual clinicians (2) Long-term care (3) | Low
Key Question 2 What harms result from public reporting? | Unintended provider behavior: There was some evidence from LTC that public reporting motivates NHs to change coding and readmitting patients to the hospital. No evidence supported a link with surgeons or organizations withdrawing from the market or with declines in quality for items not measured (crowding out). | 5 Individual clinicians (1) Health plans (2) Long-term care (2) | Moderate
Key Question 3 Does public reporting lead to change in health care delivery structures or processes? | Provider actions: The evidence suggested that individual clinicians and organizations respond to public reporting in positive ways including adding services, changing policy and increasing focus on clinical care. One study found that low-quality surgeons leave practice (considered a positive action). A study of vaccination rates was the only one that found no effect. | 10 Hospitals (4) Individual clinicians (1) Long-term care (5) | Moderate
Key Question 4 Does public reporting lead to change in the behavior of patients, their representatives, or organizations that purchase care? | Selection (market share/volume): Studies found no or minimal impact of public reporting on selection as measured by market share or volume. Contracting patterns suggested purchasers give only minimal consideration to publicly reported quality when selecting providers. | 47 Hospitals (15) Individual clinicians (9) Health plans (17) Long-term care (6) | Moderate
Key Question 5 What characteristics of public reporting increase its impact on quality of care? | Mode and tone of message: One study found that mode (email vs. mail) affects use of public reports, while tone of the message (risks vs. benefits) does not. | 1 Individual clinicians | Insufficient
Key Question 5 What characteristics of public reporting increase its impact on quality of care? | Accuracy and usefulness: One study found that the quality information contained in public reports is accurate and useful for patient selection even if there is a substantial delay between data collection and publication. | 1 Individual clinicians | Insufficient
Key Question 6 What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care? | Competitive market: Studies have found that public reporting is more likely to result in improvements in quality if the clinician or provider is in a competitive market. | 7 Hospitals (2) Long-term care (5) | High
Key Question 6 What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care? | Baseline performance: The likelihood of improvement after public reporting was greater for entities with lower quality before or at the first instance of reporting. | 5 Health plans (2) Long-term care (3) | High
Key Question 6 What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care? | Nursing home characteristics: Characteristics (e.g., ownership) did not reliably predict how NHs react to public reporting. Studies found no consistent difference across characteristics. | 6 Long-term care (6) | Low
Key Question 6 What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care? | Patient characteristics/subgroups: Different patient characteristics such as age, specific health care needs, and insurance coverage may have increased the likelihood that publicly reported data affects choice. | 3 Health plans (1) Individual clinicians (2) | Low
Key Question 6 What contextual factors (population characteristics, decision type, and environmental) increase the impact of public reporting on quality of care? | Variation in quality: Public reporting was more likely to influence quality if the level of quality varies across plans in market | 1 Health plans | Insufficient

Notes: CAHPS = Consumer Assessment of Healthcare Providers and Systems; HEDIS = Healthcare Effectiveness Data and Information Set; LTC = long-term care; NH = nursing home

a Conclusions and strength of evidence are based on the 97 included quantitative studies. Studies that examined more than one outcome are included separately for each outcome.

We synthesized across health care settings for the same outcome (e.g., we considered the impact of public reporting on market share for hospitals, individual providers, health plans, and long-term care). Combining across settings was possible because the outcomes overlapped sufficiently across settings even though all of the same outcomes were not studied in all settings (e.g. mortality was studied in hospitals and individual providers but not long-term care and health plans).

## Discussion by Key Question

There is some evidence that public reporting has an impact on the quality of health care (Key Question 1), but this is less consistent for changes in mortality, which has been the subject of research in hospitals, and more evident in improvement in care processes and quality indicators that have been the subject of public reporting on health plans and long-term care services as well as hospitals. The evidence that supports this came from 19 studies; nine of these from long-term care where there have been more studies of improvements in quality measures that are part of Nursing Home Compare and Home Health Compare. The strength of evidence was rated as high because the results are consistent and many of the included studies were rated as good quality.

Harms (Key Question 2), or unintended consequences that could result from public reporting, are frequently discussed but less consistently studied and the results of the identified studies do not support that the harms are common or widespread. The included studies consisted of evidence for two types of harms: access restrictions and unintended (negative) provider behavior. Twelve studies examined various ways that public reporting could have a negative impact on access to services. Mechanisms that restrict access that were studied included providers avoiding high-risk patients or selecting low-risk patients (referred to as cream skimming), referring high risk patients out of State, delaying treatment of high risk patients, or discriminating against patients from racial or ethnic groups that might be considered higher risk. The results of these studies were inconsistent, with most finding that access was not restricted; however studies that found that access is adversely affected merit attention because restricting access can have persistent effects and contribute to health care disparities (e.g., the finding that an increase in racial and ethnic disparities in access to services increased after public reporting and that it persisted for 9 years.68

The other type of harm that has been studied is provider behaviors that reflect either perverse incentives or attempts to “game” public reporting. These types of behaviors include any actions designed to improve performance reporting without actually improving quality, such as changing the way data are recorded as well as a focus on the reported measures to the detriment of other aspects of care (referred to as crowd out). Crowd out was not confirmed in studies of either long-term care or health plans and studies of individual clinicians and health plans did not find that providers left markets in order to improve public reporting scores. However, long-term care evidence from one study suggested that providers changed how they assessed pain in order to improve their performance scores73 while the results of another study indicated that nursing homes readmitted patients to the hospital who could lower their performance ratings before they are assessed.75

Recent discussions of the theory and justification for public reporting have focused on its impact on individual clinicians and organizations that provide care (Key Question 3). The suggestion is that one of the primary pathways from public reporting to improved quality is via the influence on provider behavior. Whether the motivation is fear of losing patients, desire to obtain more contract or referrals, or concern about reputation, the assumption is that health care providers will want to improve and will not want to appear to be negative outliers in relation to their peers. This outcome was not always included in earlier studies of public reporting about hospitals and health plans in part because the issue had not been raised and the focus was on mortality. The processes that lead to mortality were a “black box” in that it was left to the providers to manipulate as they saw fit to get to the outcome. Isolating the impact of public reporting on providers is difficult because many other factors could be the cause of the change in behavior. More recent studies have attempted to address the impact of public reporting on provider behavior and care processes through innovative study design. Studies identified in this review found that individual clinicians and organizations respond to public reporting as intended by changing policies, offering more services, and increasing focus on clinical and quality improvement activities. This research included mixed mode studies that collected information on quality improvement activities via interviews or observations and then linked this to administrative data to confirm whether the reported actions resulted in improvement. This suggests the possibility that additional research using data from sources such as electronic health records and clinical registries could be useful in evaluating public reporting.

The idea that public reports affect the choices made by patients and families, or people acting as their agents, is part of the rationale for public reporting (Key Question 4). Addressing asymmetries in the availability of information should encourage more efficient market function and may have other effects as well such as increased patient engagement. However public reporting has been evaluated in terms of its ability to affect selection. As a core concept in the economic theory-based rationale for public reporting, selection has been more frequently studied than most other outcomes. While the strength of the evidence differs somewhat across setting, the conclusion is that public reporting has no or very little impact on selection. The most positive conclusion that could be made is that results are mixed, but it is hard to say more given the weak designs of most of the included studies.

The qualitative research provided insights into why this might be case. The primary reasons public reports did not influence selection were that people are not aware that the quality information is available; the information provided in public reports was not what they needed or valued, the information was not always available when they need it to make a decision; or the information was not presented in a way that is comprehensible. Much of the qualitative research has focused on how presentation and format could increase comprehension. Perhaps if all producers of public reports followed the resulting recommendations on format and presentation, the impact of public reports on selections of providers would increase. However, this is not a given. Neither the design of most public reports, nor the design of studies of public reporting adequately consider that health care decisions are complex and that consumer preferences may differ significantly from those of health care providers and policymakers. To effectively influence the selection of providers, public reporting would need to be significantly redesigned to address these issues in addition to changing format and presentation.

While the literature on decisionmaking and public reporting acknowledges that several different characteristics of the intervention likely determine its effectiveness (Key Question 5), this was rarely examined directly in quantitative studies and it was even difficult to assess indirectly. We found only two quantitative studies that either varied on some characteristics or empirically examined the impact of existing variation. Assessing this indirectly would require having access to more comprehensive descriptions of the public reports and determining if selected characteristics of the public reports are associated with variation in results. This is discussed in Future Research Needs below in more detail.

The idea that context matters (Key Question 6) is reflected in the fact that some environmental factors are studied in relation to public reporting. Within each setting there is not enough evidence to draw conclusions; however across settings there were consistent findings related to competition and baseline performance. An economic model of public reporting suggests that in competitive markets the public reporting may have a greater impact on quality of care. The idea is that public reporting allows health care providers to compete on quality whereas when these data were not available they had to compete on other factors like price and amenities.

## Applicability

Drawing our conclusions about public reporting from evidence across different health care settings but also across different geographic areas and different time periods limits the applicability of our results. Not all of our overarching conclusions would be applicable to a present-day public reporting effort for one health care setting in a specific geographic region. We included dates and geographic information (whether the public reporting was national or region, in the United States or in other countries) in the description of studies in the sections of the report that present the results by settings and when study results are presented in detail in order to make this as transparent as possible. However, we did not develop a schema that weighted more recent studies or studies from particular geographic regions more heavily in our conclusions.

For these reasons, this review does not result in a guide to how to produce the most effective public reports in a given setting. Nevertheless, we believe the summary of prior research, even if that research is not representative of the scope of current public reporting, may be useful to several audiences. The results of this review can be used to help set realistic expectations for how much public reporting can influence decisionmaking and result in improvements in quality. These realistic expectations should be used to inform both the design of public reporting programs and the research designed to evaluate these efforts. Organizations or individuals promoting of public reporting should specify their objectives in term of in terms of other goals such as increasing transparency as well as expected levels of quality improvement.

Another importance role for this review is to identify for policymakers, research funders, and researchers the state of the current science of public reporting. This review summaries how public reporting efforts have been evaluated in the past and underscores the need for both improvements in methods for the evaluation of public reporting and similar population-level interventions and the need for research to be representative of more contemporary public reporting programs.

## Limitations of the Review

The major limitations of this review are related to the nature of public reporting as an intervention and affect both what studies were included and how they were summarized.

Public reporting is multidisciplinary and population-based and has a 25-year history in several countries and geographic regions. Additionally, it is often viewed as a policy, management, or educational activity that focuses on disseminating existing information rather than generating new knowledge. Each of these characteristics creates a challenge in adapting systematic review methods in health care that have been developed primarily for comparing and evaluating medical interventions.

Public reporting quality information in health care is an intervention based on theories in economics, decision science, psychology of behavior change, organizational sociology, and public policy, and this list is not complete. While our search was not limited to only biomedical databases, it is likely there is literature from some relevant disciplines in social science, humanities index in discipline-specific databases that we did not search. The large number of articles we triaged and reviewed, combined with input from experts with significant experience limits, does not negate the possibility that we missed significant studies or other types of relevant research. Also, although we included qualitative literature in our narratives, our review is not a true qualitative review. While we did not exclude studies based on study design, our search was not tailored specifically to identify qualitative studies. We summarized these qualitative studies, but we did not employ qualitative synthesis methods that usually involve iterative cycles of review, synthesis, and revision of the study questions until saturation is reached.

We believe as well, but cannot definitively prove, that there are studies of public reporting that exist but that have not been published in peer review journals or distributed through the grey literature sources that we were able to access or identify despite searches and a targeted email request for unpublished research sent to identified producers of public reports. This belief is based on discussion with our expert panel, as well as other indications. For example, in one of the qualitative studies we identified, 50 percent of public report sponsors reported in interviews that they had evaluated their public report initiatives,204 but there were not corresponding research publications in the literature we searched. The likely reason is that these studies are done as part of operations or program evaluations to meet the specific needs of a stakeholder such as the public report producer, a State agency, or an advocacy group. Once these needs are met, there may be no motivation to publish the results, particularly for non academic producers or stakeholders. Even if academics are involved in the evaluation, if the study is designed for a narrow purpose or specific use, the researcher and/or journal editor may not be interested in publishing the results if they are not perceived as adding to the larger body of knowledge, regardless of how useful they may be to the client or how useful a synthesis of these evaluations might be to the field.

Public reports exist for various reasons and are implemented by different agencies or organizations. In a systematic review of literature we are limited to what has been studied and published. As a result we are limited to drawing conclusions based on what public reporting was at the time the included studies were conducted. If the field has evolved so that public reporting today is materially different than what was studied, the review may not represent the current, state-of-the-art public reporting and it is unlikely to include cutting edge innovations.

This review included a broad range of public reports across about four different health care settings. There is significant variation in what is the subject of public reporting within settings (e.g., hospitals include cardiac surgery, obstetrics, hip replacement) as well as across them. It stands to reason that the decisions patients and clinicians need to make, how they make them, and the potential utility of public reports could also different significantly. We debated the validity of drawing conclusions across settings. While we decided to do this and present the conclusions by Key Question and outcome across settings, we acknowledge that summarizing on this level may mask important differences that might have been identified if more research was available and the body of evidence could be summarized at the level of more specific decisions about distinct types of health services.

## Limitations of the Research on Public Reporting

Public reporting is a population-based intervention that more closely resembles public health activities like putting fluoride in drinking water or smoking bans than it resembles clinical, medical, or health care interventions which treat specific individuals. Public reporting makes information available to anyone who wants it and may involve marketing and dissemination, but it is difficult to identify exactly who is poised to make a health care decision, and we rarely know who actually receives and uses the information. This makes designing studies and conducting research challenging because there are almost always many potential sources of confounding.

Collecting outcomes data and identifying appropriate comparisons is often difficult. The fact that conducting rigorous studies in this field is challenging is mirrored in the challenges we faced in assessing individual studies and the body of evidence based on tools and interventions rooted in the evaluation of clinical research. The focus on randomized trials and observational designs common in clinical research is understandable given that clinic medicine is the basis of evidence-based practice and early comparative effectiveness research. However, the result is that there is limited consensus about how to systematically assess evidence for questions in health services, public health, and quality improvement. While we attempted to adapt the methods recommended by the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program, our approach is only one of several, and others may be equally or more valid.

The majority of the research we identified focused on the intermediate and final outcomes included in our analytic framework and correspond to Key Questions 1, 2, 3, and 4. We included Key Questions 5 and 6 because understanding the implications of variation in the intervention and content are important from a quality improvement perspective in which the desire is not just to know if something works, but also who it works for and when. From this perspective the results of our review were limited by the current state of the literature. Studies rarely reported enough (if anything at all) about the public report or the context. Without this information it was impossible to compare and contrast studies where public reporting had an impact to those where it did not and hypothesize if the difference was due to specifics of the nature of the public reports or the context. This leaves several important questions unanswered. For example, the current research does not adequately address the correspondence between what patients want to know and what is publicly provided or whether the information is assessable (e.g., do consumers have the level of health literacy required to correctly interpret the information?). Similarly for providers we do not know how well the publicly reported measure corresponds to what they believe they can influence or their quality improvement goals.

There is a substantial amount of research on risk adjustment and creation of measures that was not included in this review. The validity and acceptability of measures is essential if public reporting is to have any impact. Research on the impact of public reporting often mentions the importance of the validity of the measures and the research on risk adjustments will often discuss the implications for public reporting, but research rarely links the two.

While we may not be sure if our review missed evaluations of public reports (see limitations of the review above), we know that many more public reports exist than have been studied. An AHRQ-maintained clearinghouse contained over 200 public reports and a recent study identified 263 public reports in 21 geographic areas.233 This diversity of reports is not reflected in the research literature. Public reports on cardiac surgery outcomes in three States (New York State, Pennsylvania, and California) and Nursing Home Compare are the subject of just under half of the total quantitative studies in this report. The fact that research has been narrowly focused on a few public reporting initiatives may limit the generalizability and applicability of its results to other reporting efforts and broader public policies.

## Future Research

We identified a large number of studies in this review, but the return in terms of credible guidance on how to maximize the impact of public reporting on quality of health care is generally low. The reasons for this are translated into ideas for future research for both public reporting and the synthesis of research on this type of intervention in this section. However this is not an exhaustive inventory of future research needs; it is limited to what can be directly based on or extrapolated from the experience of conducting this review, background materials including many editorials and commentaries, as well as input from our expert panel, peer reviewers, and public comments. These recommendations are limited in that they are not based on a systematic interaction with stakeholders or prioritization of future research needs.

Research Reflecting the Diversity of Public Reporting. The research available on public reporting does not appear to correspond to the current state of practice in several ways. Producers of public reports have a wide range of motivations and goals for the public reports that appear to be broader than the outcomes that are most frequently included in research. Additionally, public reporting may be part of a multifaceted strategy designed to achieve these goals. The current research does not reflect the scale of the public reporting enterprise, its connection to other initiatives, or innovations in the field. Only a very few of the public reports have been the subject of research. It is possible that studying a wider variety of reports as well as public reporting in a broader context of transparency, patient engagement, and reducing disparities could produce stronger, more nuanced, if not totally different, conclusions. The challenge is that in order to include more public reports in research, the existence of the reports needs to be more widely known and corresponding data needs to be available. Cataloging and tracking a larger number of public reporting efforts and linking them to data would require considerable resources.

Coordinated Agenda for Research on Public Reporting. When the outcomes of the identified studies are examined by setting and Key Question, the impact of heterogeneity in this body of literature becomes clear. There are few outcomes for which it is possible to draw a conclusion based on only research in one setting, requiring summaries across settings. Looking across settings provides the potential to answer some questions, but not others. This is one example of how the research in this field appears to be ad hoc in the sense that studies do not seem to build on prior studies by addressing either previously identified methodological or knowledge gaps. There are some researchers who individually have conducted several studies in the field and it is possible to see how their approach has become more sophisticated with time, perhaps due to increasing experience or availability of data. However, these few cases are not enough to create a pattern in the complete body of literature.

Future research needs to build on what came before with an eye toward advancing understanding and focus on developing the science rather than repeating past approaches that have had a relative low yield. This review may help by uniting more literature in one place than has been done before on this topic. However, it may be unrealistic to expect a coordinated approach to happen without outside intervention given that much of this research appears to be driven predominately (though not completely) by the availability of data. Stakeholders including producers of public reports, researchers, and funding agencies need to identify key issues for the field, and then develop and conduct research targeted to these issues. To do this effectively may require identifying or developing data sources that are appropriate to the research questions and outcomes of interest.

Attention to the Specifics of Public Reporting Including Interventions and the Context. Considering the research on public reporting in a quality improvement or comparative effectiveness framework requires an understanding of the how the characteristics of the intervention and the context impact whether public reporting leads to higher quality of care. We do not just want to know if it works (efficacy), we want to know who it works for and in what situations (effectiveness). While this may seem obvious, it is not consistently reflected in either the information available in most currently published quantitative research or in the research questions and designs.

It seems unlikely that one approach to public reporting would be effective given the different needs, preferences, and skills of the various users. Considering patients as users of reports, levels of literacy/numeracy, facilities with computers, and values can be expected to be quite diverse. This would suggest that public reports may need to be targeted to smaller audiences to be effective. While this is a policy more than a research issue, research could contribute to the identification of both the subgroups of patients who make up these smaller audiences and the most effective ways to aim distribution and communicate information.

It is also important to understand of what the intervention, in this case public reporting, consists. Most quantitative research articles provided very little or no information about the content or format of the public report that is the subject of study, or about the context in which the intervention was implemented and studied. This lack of specification of the characteristics and components of public reports and the context makes it difficult to think about how to apply the research results in the future or move from experimentation to implementation on a larger scale. Often, the reason for this lack of detail in descriptions has been attributed to journal policies on article length and content. However, with the use of supplemental Web materials and the creation of clearing houses and databases on interventions, insufficient space is no longer an acceptable excuse. Future research should include finding a way to document, share, and preserve this vital information. Additionally, useful research needs to go beyond simply describing intervention characteristics and context to direct examination of the impact of public report characteristics and context on quality of care.

Our review found very few quantitative studies that tried to go beyond simple description to answer the important questions about what works best when and for whom. More frequently these topics were addressed in qualitative research. This supports the idea that integrating qualitative and quantitative evidence in systematic reviews may lead to more meaningful results. One promising approach that has been suggested is to use qualitative research to develop a list of important intervention characteristics from patients’ perspectives, and then assess the quantitative research in terms of whether the interventions incorporate these characteristics and whether there is a pattern of positive quantitative results when this is the case.234 Unfortunately, the lack of descriptions of the public reports and context in the published literature precluded this approach in our review of public reporting. Implementing this approach would require primary data collection on the characteristics of the reports, which is beyond the scope of this review. Our approach was to categorize the qualitative research and provide narrative summaries of the main results. Development of additional approaches would benefit future reviews.

Systematic Approach to the Study of Harms/Unintended Consequences. Public reporting has the potential to produce perverse incentives that lead to unintended consequences and potential harm to patients and providers. When harms were studied they were reported in the results. Critics of public reporting often describe harms although there is currently limited evidence supporting the occurrence of harms. That does not mean harms do not need to be studied. In fact serious, potentially harmful effects such as increasing disparities or the use of more health services (e.g., more hospital re admissions from long-term care) require more study to identify the extent of the harms and how they can be avoided. Rigorous studies that focus on perverse incentives and unintended consequences are needed in order to provide information that can be used to develop programs and oversight so that harm does not occur in the future.

Methods Development. Both our assessment of the quality of individual studies and our work on this systematic review have sensitized us to the need for more developmental research in methods. Study designs and analyses in individual studies were frequently not able to create adequate comparisons or adequately address important sources of confounding. Methods used in clinical studies (randomized controlled trials, large cohort studies) are often not practical approaches to reducing bias in health services, public health, or quality improvement research. However, an increasing number of the questions of interest to stakeholders including patients, clinicians, and policymakers are in these fields. Changes in technology and the increasing availability of large quantities of electronic data open up many possibilities, but data alone cannot improve the quality and ultimately the impact of research. By the same token, systematic review and comparative effectiveness research methodology has been predominately developed for the synthesis of research on clinical interventions. The heterogeneity in the body of evidence on public reporting and its limited ability to address major practice and policy issues suggests that research syntheses might have an important role in focusing and driving future research. The chances of success are lowered when the tools used for the synthesis are adaptations that sometimes seem to be wedging square pegs in round holes.

## Conclusion

Based on the studies identified in this review we can conclude: Public reporting is associated with improvement in health care performance measures such as those included in Nursing Home Compare. Quality measures that are publicly reported do improve over time. Almost all identified studies found no evidence or only weak evidence that public reporting affects the selection of health care providers by patients or their representatives. Studies of health care providers’ response to public reports suggest they do engage in activities to improve quality when performance data are made public. Characteristics of the intervention and the context, which are likely to be important when considering the diffusion of quality improvement activities, were rarely studied or even described. Although the potential for harms are frequently cited by commentators, the amount of research on harms is limited and most studies do not confirm the potential harm.