# Long-Term Care: Qualitative Evidence

Table O1 Long-term care qualititative studies: Columns 1–9 of 9 (pages O-1 to O-6)