# Long-Term Care: Quantitative Evidence

## Section A

Table N1 Long-term care quantitative studies: Columns 1–10 of 18 (pages N-1 to N-6)

## Section B

Table N2 Long-term care quantitative studies: Columns 11–18 of 18 (pages N-7 to N-24)