# Health Plans: Qualitative Evidence

Table M1 Health plans qualitative studies: Columns 1–9 of 9 (pages M-1 to M-23)