# Health Plans: Quantitative Evidence

## Section A

Table L1 Health plans quantitative studies: columns 1–10 of 18 (pages L-1 to L-9)

## Section B

Table L2 Health plans quantitative studies: Columns 11–18 of 18 (pages L-10 to L-25)