# Individual Providers: Qualitative Evidence

Table K1 Individual provider qualitative studies: columns 1–9 of 9 (pages K1 to K14)