# Individual Providers: Quantitative Evidence

## Section A

Table J1 Individual provider quantitative studies: Columns 1–10 of 20 (pages J-1 to J-4)

## Section B

Table J2 Individual provider quantitative studies: columns 10–20 of 20 (pages J-5 to J-15)