# Hospitals: Qualitative Evidence

## Section A

Table I1 Hospital qualitative studies: columns 1–9 of 15 (pages I-1 to I-18)

## Section B

Table I2 Hospital qualitative studies: Columns 10–15 of 15 (pages I-19 to I-51)