# Hospitals: Quantitative Evidence

## Section A

Table H1 Hospital quantitative studies: columns 1–8 of 18 (pages H-1 to H-18)

## Section B

Table H2 C Hospital quantitative studies: Columns 9–13 of 18 (pages H-19 to H-39)

## Section C

Table H3 Hospital quantitative studies: Columns 14–18 of 18 (pages H-40 to H-51)