# Quality Assessment of Individual Quantitative Studies

Table G1 Quality assessment criteria for quantitative studies

Author | Year | Adequate Randomization (for RCTs) or appropriateness of the comparison groups or time periods? | How similar are groups at baseline or how well did the analysis control for differences? | How well does the design or analyses account for important potential confounding? | How well does the study rule out any impact from an unintended exposure or a concurrent intervention or that might bias results? | How well are all potential outcomes prespecified and are the prespecified outcomes reported? | How well are primary outcomes assessed? Were valid and reliable measures used and implemented consistently across all study participants/groups? | Overall QA
Hospitals
Apolito3 | 2008 | Good | Good | Good | Fair | Good | Good | Good
Baker4 | 2003 | Good | Good | Fair | Good | Good | Good | Fair
Baker5 | 2002 | Good | Fair | Fair | Good | Good | Good | Fair
Bridgewater6 | 2006 | Good | Good | Good | Unclear | Good | Good | Good
Carey7 | 2006 | Good | Good | Poor | Unclear | Good | Fair | Fair
Caron8 | 2004 | Fair | Fair | Poor | Good | Fair | Fair | Fair
Caron9 | 1999 | Fair | Fair | Poor | Poor | Good | Good | Poor
Clough10 | 2002 | Good | Fair | Fair | Good | Good | Good | Fair
Cutler11 | 2004 | Good | Good | Fair | Good | Fair | Good | Fair
Dranove12 | 2008 | Good | Good | Good | Good | Good | Good | Good
Dranove13 | 2003 | Good | Good | Fair | Good | Good | Good | Good
Elliot14 | 2010 | Good | Good | Good | Good | Good | Good | Good
Evans15 | 1997 | Good | Good | Fair | Good | Fair | Fair | Fair
Foreman16 | 1995 | Fair | Unclear | Poor | Good | Good | Good | Poor
Friedberg17 | 2009 | Good | Good | Good | Good | Good | Good | Good
Ghali18 | 1997 | Poor | Poor | Good | Good | Good | Good | Fair
Guru19 | 2005 | Good | Fair | Fair | Good | Good | Good | Fair
Hannan20 | 2003 | Fair | Good | Good | Good | Good | Good | Good
Hannan21 | 1994 | Good | Good | Good | Good | Good | Good | Good
Hannan22 | 1994 | Good | Good | Good | Good | Good | Good | Good
Hibbard23 | 2005 | Unclear | Unclear | Good | Good | Good | Good | Fair
Hibbard24 | 2003 | Unclear | Fair | Fair | Fair | Fair | Fair | Fair
Hollenbeak25 | 2008 | Good | Good | Good | Good | Good | Good | Good
Howard26 | 2006 | Fair | Good | Fair | Good | Good | Good | Fair
Jang27 | 2010 | Fair | Fair | Good | Unclear | Good | Good | Fair
Jang28 | 2011 | Fair | Fair | Good | Good | Fair | Good | Fair
Jha29 | 2006 | Good | Good | Good | Good | Good | Good | Good
Longo30 | 1997 | Fair | N/A | Fair | Good | Good | Good | Fair
Mennemeyer31 | 1997 | Good | Fair | Good | Fair | Good | Good | Fair
Moscucci32 | 2005 | Fair | Fair | Fair | Good | Good | Fair | Fair
Mukamel33 | 1998 | Good | Good | Poor | Good | Good | Good | Fair
Omoigui34 | 1996 | Poor | Fair | Fair | Good | Good | Fair | Poor
Peterson35 | 1998 | Good | Good | Good | Good | Good | Good | Good
Pope 36 | 2009 | Good | Good | Good | Poor | Good | Good | Fair
Romano37 | 2004 | Good | Good | Fair | Good | Good | Good | Good
Romano38 | 2011 | Fair | Fair | Good | Good | Good | Good | Fair
Rosenthal39 | 1997 | Good | Good | Good | Good | Good | Good | Good
Shabino40 | 2006 | Good | Poor | Poor | Fair | Good | Good | Poor
Tu41 | 2009 | Unclear | Good | Good | Fair | Good | Good | Fair
Vladeck42 | 1988 | Good | Unclear | Unclear | NR | Good | Poor | Poor
Wang43 | 2011 | Good | Fair | Good | Good | Good | Good | Good
Werner44 | 2010 | Good | Good | Good | Good | Good | Good | Good
Wübker45 | 2008 | Good | Unclear | Fair | Good | Good | Good | Fair
Individual Clinicians
Bundorf46 | 2009 | Good | Good | Good | Good | Good | Good | Good
Epstein47 | 2010 | Fair | Fair | Fair | Fair | Good | Good | Fair
Glance48 | 2008 | Good | Fair | Fair | Good | Good | Good | Fair
Hannan21 | 1994 | Good | Good | Good | Good | Good | Good | Good
Jha29 | 2006 | Good | Good | Good | Good | Good | Good | Good
Mukamel49 | 2002 | Good | Unclear | Fair | Good | Good | Good | Fair
Mukamel50 | 2000 | NA | Fair | Poor | Good | Good | Good | Fair
Mukamel33 | 1998 | Good | Good | Poor | Good | Good | Good | Fair
Mukamel51 | 2004 | Good | Fair | Good | Good | Good | Good | Good
Ranganathan52 | 2009 | Unclear | NR | Fair | Good | Good | Good | Fair
Wang43 | 2011 | Good | Fair | Good | Good | Good | Good | Good
Werner53 | 2005 | Good | Good | Good | Fair | Good | Good | Good
Health Plans
Abraham54 | 2006 | Good | Poor | Fair | Good | Fair | Good | Poor
Bardenheier55 | 2007 | Good | Fair | Fair | Fair | Good | Good | Fair
Beaulieu56 | 2002 | Fair | Fair | Fair | Good | Good | Good | Fair
Bost57 | 2001 | Fair | Poor | Poor | Good | Good | Good | Poor
Chernew58 | 2004 | Fair | NA | Fair | Fair | Good | Good | Fair
Chernew59 | 1998 | NA | Good | Good | Good | Good | Good | Fair
Dafney60 | 2008 | Fair | Good | Fair | Good | Good | Fair | Fair
Farley61 | 2002 | Fair | Good | Good | Good | Good | Good | Good
Farley62 | 2002 | Fair | Fair | Fair | Good | Good | Good | Good
Fowles63 | 2000 | Poor | Fair | Fair | Good | Good | Good | Fair
Fox64 | 2001 | Poor | Poor | Fair | Poor | Good | Good | Poor
Haberman65 | 2007 | Good | Fair | Fair | Good | Good | Good | Fair
Hedricks66 | 2009 | Good | Fair | Poor | Poor | Good | Good | Poor
Jin67 | 2006 | Fair | Good | Good | Good | Good | Good | Good
Jung68 | 2010 | Fair | Good | Fair | Good | Good | Good | Good
Knutson69 | 1998 | Fair | Fair | Fair | Good | Good | Good | Fair
Lied70 | 2001 | Fair | Fair | Fair | Good | Good | Good | Fair
Liu71 | 2009 | Good | Fair | Fair | Fair | Good | Good | Fair
McCormack72 | 2001 | Fair | Good | Fair | Good | Fair | Fair | Fair
Pham73 | 2002 | Good | Good | Good | Good | Good | Good | Good
Scanlo74 | 2002 | Good | Good | Fair | Good | Good | Good | Good
Scanlon75 | 1999 | NA | Good | Fair | Fair | Good | Good | Fair
Tai-Seale76 | 2004 | Good | Fair | Fair | Good | Good | Good | Fair
Wedig77 | 2020 | Good | Good | Fair | Fair | Good | Good | Fair
Long-term Care
Cai78 | 2010 | Good | Fair | Fair | Good | Good | Good | Fair
Castle79 | 2007 | Fair | Good | Fair | Good | Good | Good | Fair
Castle80 | 2008 | Fair | Good | Good | NR | Good | Good | Fair
Castle81 | 2010 | Fair | Good | Good | NA | Good | Good | Fair
Gaudet82 | 2011 | Good | Good | Good | Good | Good | Good | Good
Grabowski83 | 2011 | Good | Good | Fair | Good | Good | Good | Good
Konetza84 | 2012 | Good | Good | Good | Good | Good | Good | Good
Jung85 | 2010 | Fair | Fair | Good | NA | Good | Good | Fair
Mukamel86 | 2008 | Good | Good | Fair | Good | Good | Good | Good
Mukamel87 | 2009 | Good | NR | Fair | Good | Good | good | Fair
Mukamel88 | 2010 | Good | Fair | Fair | Good | Good | Good | Fair
Park89 | 2010 | Good | Good | Good | Fair | Good | Good | Good
Park90 | 2010 | Fair | Good | Good | Good | Good | Good | Good
Stevenson91 | 2006 | Good | Fair | Fair | Good | Good | Poor | Poor
Werner92 | 2009 | Good | Good | Good | Good | Good | Good | Good
Werner93 | 2009 | Good | Good | Good | Good | Good | Good | Good
Werner94 | 2010 | Good | Good | Fair | Good | Good | Good | Good
Werner95 | 2011 | Good | Fair | Good | Good | Good | Good | Good
Werner96 | 2012 | Fair | Good | Good | Good | Good | Good | Good
Zinn97 | 2005 | Good | Good | Fair | NA post only | Good | Good | Fair
Zinn98 | 2008 | Good | Good | Good | Good | Good | Fair | Good
Zinn99 | 2010 | NA | Fair | Good | Unclear | Good | Fair | Fair

Abbreviations: NA, not applicable; NR, not reported; QA, quality assessment; RCT, randomized controlled trial.