# Method for Quality Assessment of Individual Quantitative Studies

## Overall Ratings

Individual studies were rated as “good”, “fair”, or “poor” based on definitions from the chapter titled “Assessing the Risk of Bias of Individual Studies when Comparing Medical Interventions” in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter, Methods Guide).1,2

Good quality/Low risk of bias implies confidence on the part of the reviewer that results represent the true treatment effects (i.e., study results are considered valid). The study reporting is adequate to judge that no major or minor sources of bias are likely to influence results.

Fair quality/Medium risk of bias implies some confidence that the results represent true treatment effect. The study is susceptible to some bias, but the problems are not sufficient to invalidate the results (i.e., no flaw is likely to cause major bias). The study may be missing information, making it difficult to assess limitations and potential problems.

Poor quality/High risk of bias implies low confidence that results represent true treatment effect. The study has significant flaws that imply biases of various types that may invalidate its results; these may arise from serious errors in conduct, analysis, or reporting, large amounts of missing information, or discrepancies in reporting.

## Assessment Criteria

We prespecified six key criteria that could be applied to the various types of observational studies as well as the few studies that use random assignment to evaluate public reporting.

The selected criteria are based on recommendations in the AHRQ chapter in the Methods Guide, “Assessing the Risk of Bias of Individual Studies when Comparing Medical Interventions.” We reviewed the types of bias and the suggested criteria discussed in this chapter and followed the recommendation that those most relevant to the topic and appropriate for the study designs be employed.

Based on this assessment we selected six criteria for this review:

1. How adequate was randomization? (for randomized studies) or how appropriate was selection of comparison groups or times? (for observational studies)
2. How similar were groups at baseline (or time periods) or how well did the analysis control for differences?
3. How well did the design or analyses account for important potential confounding and modifying variables?
4. How well did the study rule out any impact from an unintended exposure or a concurrent intervention that might bias results?
5. How well were all potential outcomes prespecified and were the prespecified outcomes reported?
6. How well were primary outcomes assessed? Were valid and reliable measures used and implemented consistently across all study participants/groups?

The overall assessment was not derived from a direct linear combination of the six criteria. Given the nature of public reporting as an intervention, the criteria corresponding to selection bias (1, 2, and 3) were of greatest concern when determining how much confidence we could have in each study’s result. For this reason it is possible for a study to be given an overall assessment of “poor” even if some individual criteria were rated as “good.”

## Guidelines Used for Quality Assessment: Type of Bias, Related Criteria, and Examples

Included below are the definitions of the types of bias considered in our quality assessments, the corresponding criteria, and elaboration on how they might apply to public reporting. The definitions are the Cochrane definitions provided in the Methods Guide chapter cited above.

### Selection Bias

#### Definition

“Systematic differences that arise from self-selection of treatments, physician-directed selection of treatments, or association of treatment assignments with demographic, clinical, or social characteristics. Includes confounding by indication (when patient prognostic characteristics, such as disease severity or co-morbidity, influence both treatment source and outcomes).”

#### Application for Public Reporting

In assessing our confidence in the results of a study about public reporting, selection bias was the greatest concern in that the comparison (either between groups or across time periods) was less valid because factors that affected the two groups/time periods differently impacted the results and these may not be addressed sufficiently in the study design or analyses. Few studies in this field were trials (where the researcher controls the assignment of public reporting); most were observational studies of various kinds. For observational studies selection bias is a critical issue.

#### Assessment Questions

1a. [for RCTs only] Was treatment adequately randomized?

1b. [for observational studies only] How appropriate is the selection of the comparison groups or the time periods?

Raters need to ask, “Does what was selected for comparison make sense given the study questions?” If the authors do not justify the selection, the raters have to make their own assessments. If the authors do explain the selection, the raters still have to decide if the groups are appropriate, considering both what the authors said and their own assessment.

#### Prompts

Examples of study characteristics to consider. If comparing on the level of geographic regions (e.g., States, Countries, Counties, etc.) do the researchers justify the selection? Does the researcher demonstrate that they are similar on key variables? If the comparison is pre-post, are the time periods actually prior to the public reporting and after it has been distributed/disseminated, and do the time periods seem reasonable? Are sample sizes sufficient? Are there any other aspects of the comparison groups that make them inappropriate for comparison?

2. How similar are groups at baseline (or the time periods) or how well did the analysis control for differences?

Simply listing baseline variables in a table or adding them into an equation is not sufficient. In addition to the variables reported, the rater should consider what variables would be important and rate the article lower if key differences are not reported.

3. How well does the design or analyses account for important potential confounding?

Confounding means something is different across the groups or time periods that is also associated with the outcome. We are worried that something is “muddying up” the relationship between the intervention and the results. Confounding is important to consider given that public reporting is an intervention that is evaluated in situations where few factors can be controlled by the researchers. Raters need to be skeptical, but they cannot assess all possible confounding. The focus is on important potential confounding that could invalidate the results.

Specific concerns are: (1) If something changes (say a public policy or the number of health care options) the concern is that it could be different across the groups. If everyone in the universe of the study is equally affected, it is not confounding. (2) The confounding variable would likely impact the results. If something changes that has no conceptual link to results, it should not be considered—and is unlikely to be measured/mentioned in article.

Raters should be most worried that what is different would increase the difference across groups or time periods that is being reported as the result. That is, the bias is in the same direction as the impact of the intervention. If the confounding is likely to counteract the impact of the intervention, then it is possible that a study will not address it and the results might be considered a conservative estimate of the true impact.

Study design/structure can be more or less likely to account for confounding. Because of this, study design can be considered when thinking about confounding even though it should not be used as the sole basis for the rating

Analyses can also be used to address confounding if it cannot be controlled for in the design (e.g. sensitivity analyses, regression diagnostics, statistical approaches to identifying or controlling for gaming/codings/measurement issues).

### Performance Bias

#### Definition

“Systematic differences in the care provided to participants and protocol deviation. Examples include: contamination of the control group with the exposure or intervention, unbalanced provision of additional interventions or co-interventions, difference in co-interventions, and inadequate blinding of providers and participants.”

#### Application to Public Reporting

This bias is about the intervention, which in this case is public reporting. Here the main concern is that either the non-public reporting group or time period really was exposed to public reporting. This is contamination.

Concurrent interventions are less likely in public reporting, but possible. Example: the study is of hospitals before and after Medicare reporting in two states. In one state between the pre and post period the state department of health issues a report card; that would be a co-intervention. Using these states would then be a poor study design as the performance bias would affect our confidence in the results.

#### Assessment Question

4. How well does the study rule out any impact from an unintended exposure or a concurrent intervention that might bias results?” (i.e., is contamination across the groups or time periods minimized?)

### Reporting Bias

#### Definition

“Systematic differences between reported and unreported findings, e.g., differential reporting of outcomes or harms, incomplete reporting of study findings, potential for bias in reporting through source of funding”

#### Application to Public Reporting

We were unlikely to have protocols to compare the article to, so this was based on the article alone. We looked for results that sounded like they were exploratory, but were not presented that way. For example this would be “poor” if a study were to say the objective is to compare mortality and readmission across groups of hospitals with and without public reporting, but the results reported did not include mortality but reported an increase in quality improvement activities, and did not mention readmission.

NOTE: If the study said number of quality improvement activities was the outcome, then reported it, this would be fine. The issue is agreement between what the researchers say the outcomes are and what is reported.

#### Assessment Question

5. How well are all potential outcomes prespecified and are the prespecified outcomes reported?

### Detection Bias

#### Definition

“Systematic differences in outcomes assessment among groups being compared, including systematic misclassification of the exposure or intervention, covariates, or outcomes because of variable definitions and timings, diagnostic thresholds, recall from memory, inadequate assessor blinding, and faulty measurement techniques. Erroneous statistical analysis might also affect the validity of effect estimates.”

#### Application to Public Reporting

This bias was about how things were measured: whether they were measured well (valid and reliable) and/or whether this was the same across groups or time periods.

#### Assessment Question

6. How well are primary outcomes assessed? Were valid and reliable measures used and implemented consistently across all study participants/groups?”

### Considerations When Selecting and Applying Criteria

Public reporting as a quality improvement strategy does not lend itself to all of the same types of study designs common to studies of clinical interventions for several reasons. The following are factors we considered when selecting the criteria for assessing the quality of these studies:

- Blinding people (patients, researchers) to the intervention is not practical.
- Public reporting is often a “population level” intervention rather than targeted at individuals. Sometimes it is easier to think about this as a public health intervention, such as putting fluoride in the water or banning smoking in public places. Outcomes for individuals are measured and combined to evaluate the intervention that is designed to affect the entire population, but it is often unknown whether individuals experienced the intervention.
- The outcomes in studies of public reporting vary. They might include mortality, quality improvement activity, or choice of a provider by a patient or by the selection of provider by payers. They may also include actual behavior, reports of what people would do in a hypothetical situation, or their attitudes toward or willingness to use a tool. Risks of bias may differ according to the outcome.
- Public reporting is one of many things that could influence a decision/outcome. This is what makes design and conduct of a good study challenging. In a situation where it is difficult to control influential factors, it is important to be particularly aware of selection bias and confounding. The study design and analyses need to be constructed to increase confidence in the comparison made in the study.

For quality rating the issue is not necessarily that other factors influence the decision, it is whether these other factors are distributed differently across the groups or time periods used in the comparisons.