# Description of Public Reports From the Included Studies

This appendix includes descriptive information about public reports on health care quality that are the subject of two or more included studies in this systematic review in order to avoid repeating these descriptions in the text and evidence tables. This is not an exhaustive list of all available public reports.

Table E1 Descriptive information about public reports from the included studies