# Study Design Terminology

The study design terminology used in this review and included in the evidence tables were based on the definitions from the glossary at the Health Services Research Methods website maintained by AcademyHealth http://www.hsrmethods.org/Home.aspx. Minor changes were made in the names for consistency.

One Group Post-test Only

A type of experimental study in which only one group receives a treatment and is then measured in a post test -- after treatment. In this design, there is no control group or baseline condition to compare with.

One Group Pretest Posttest

A study design in which a sample is observed twice, one prior to (pre), and once after (post) an intervention or experiment.

Time Series Posttest Only

Study design in which outcomes are measured repeatedly in a single group of participants only after a manipulation or a natural event.

Interrupted Time Series

Study design in which outcomes are measured repeatedly in a single group of participants both before and after a manipulation or a natural event.

Comparison Group(s) Posttest Only

A study design in which two or more groups, at least one study group and one control group, are measured at one point in time following an intervention or experiment. The study group experiences an intervention or experiment while the control group does not.

Comparison Group(s) Pretest Posttest

A study design in which two or more groups subject to different experiences or treatments are compared. The purpose is to make statistical comparisons between two or more groups and demonstrate a causal relationship between the independent variable and outcome of interest.

Multiple Group Interrupted Time Series

A form of Time Series Design that adds an equivalent control group to the Interrupted Time Series Design.

Cross Sectional

Studies that conduct measurements on a group of subjects at one point in time. Cross-sectional studies look at both exposure and outcomes at one point in time and are designed to evaluate associations between risk factors and outcomes in a specific population.