# Included and Excluded Studies

## Included Studies

1 Abraham J, Sick B, Anderson J, et al. Selecting a provider: what factors influence patients’ decision making?. J Healthc Manag. Mar–Apr. 2011;56(2):99-114. discussion -5. [pmid: 21495529].
2 Abraham JM, Feldman R, Carlin C, et al. The effect of quality information on consumer health plan switching: evidence from the Buyers Health Care Action Group. J Health Econ. Jul. 2006;25(4):762-81. [pmid: 16704882].
3 Apolito RA, Greenberg MA, Menegus MA, et al. Impact of the New York State Cardiac Surgery and Percutaneous Coronary Intervention Reporting System on the management of patients with acute myocardial infarction complicated by cardiogenic shock. Am Heart J. Feb. 2008;155(2):267-73. [pmid: 18215596].
4 Aryankhesal A, Sheldon T. Effect of the Iranian hospital grading system on patients’ and general practitioners’ behaviour: an examination of awareness, belief and choice. Health Serv Manage Res. Aug. 2010;23(3):139-44. [pmid: 20702891].
5 Baker DW, Einstadter D, Thomas C, et al. The effect of publicly reporting hospital performance on market share and risk-adjusted mortality at high-mortality hospitals. Med Care. Jun. 2003;41(6):729-40. [pmid: 12773839].
6 Baker DW, Einstadter D, Thomas CL, et al. Mortality trends during a program that publicly reported hospital performance. Med Care. Oct. 2002;40(10):879-90. [pmid: 12395022].
7 Bardenheier B, Kong Y, Shefer A, et al. Managed care organizations’ performance in delivery of childhood immunizations (HEDIS, 1999–2002). Am J Manag Care. 2007;13(4):193-200. [pmid: 17408339].
8 Barr JK, Bernard SL, Sofaer S, et al. Physicians’ views on public reporting of hospital quality data. Med Care Res Rev. Dec. 2008;65(6):655-73. [pmid: 18596176].
9 Barr JK, Giannotti TE, Sofaer S, et al. Using public reports of patient satisfaction for hospital quality improvement. Health Serv Res. Jun. 2006;41(3 Pt 1):663-82. [pmid: 16704506].
10 Beaulieu ND. Quality information and consumer health plan choices. J Health Econ. Jan. 2002;21(1):43-63. [pmid: 11845925].
11 Bensimon CM, Nohara N, Martin DK. Stakeholders’ views about cardiac report cards: a qualitative study. Can J Cardiol. Mar. 15. 2004;20(4):433-8. [pmid: 15057320].
12 Bentley JM, Nash DB. How Pennsylvania hospitals have responded to publicly released reports on coronary artery bypass graft surgery. Jt Comm J Qual Improv. Jan. 1998;24(1):40-9. [pmid: 9494873].
13 Berwick DM, Wald DL. Hospital leaders’ opinions of the HCFA mortality data. JAMA. Jan. 12. 1990;263(2):247-9. [pmid: 2403602].
14 Bost JE. Managed care organizations publicly reporting three years of HEDIS measures. Manag Care Interface. Sep. 2001;14(9):50-4. [pmid: 11569305].
15 Braun BL, Kind EA, Fowles JB, et al. Consumer response to a report card comparing healthcare systems. Am J Manag Care. Jun. 2002;8(6):522-8. [pmid: 12068959].
16 Bridgewater B, Grayson AD, Brooks N, et al. Has the publication of cardiac surgery outcome data been associated with changes in practice in northwest England: an analysis of 25,730 patients undergoing CABG surgery under 30 surgeons over eight years. Heart. Jun. 2007;93(6):744-8. [pmid: 17237128].
17 Bundorf MK, Chun N, Goda GS, et al. Do markets respond to quality information? The case of fertility clinics. J Health Econ. May. 2009;28(3):718-27. [pmid: 19328568].
18 Burack JH, Impellizzeri P, Homel P, et al. Public reporting of surgical mortality: a survey of New York State cardiothoracic surgeons. Ann Thorac Surg. Oct. 1999;68(4):1195-200. discussion 201–2. [pmid: 10543479].
19 Cai S, Temkin-Greener H. Influenza vaccination and its impact on hospitalization events in nursing homes. J Am Med Dir Assoc. Sep. 2011;12(7):493-8. [pmid: 21450172].
20 Carey JS, Danielsen B, Junod FL, et al. The California Cardiac Surgery and Intervention Project: evolution of a public reporting program. Am Surg. Oct. 2006;72(10):978-83. [pmid: 17058749].
21 Caron A, Jones P, Neuhauser D, et al. Measuring performance improvement: total organizational commitment or clinical specialization. Qual Manag Health Care. Oct–Dec. 2004;13(4):210-5. [pmid: 15532514].
22 Caron A, Neuhauser D. The Effect of Public Accountability on Hospital Performance: Trends in Rates for Cesarean Sections and Vaginal Births after Cesarean Section in Cleveland, Ohio. Qual Manag Health Care. 1999;7(2):1-10. [pmid: 10346457].
23 Casalino LP, Alexander GC, Jin L, et al. General Internists’ Views On Pay-For-Performance And Public Reporting Of Quality Scores: A National Survey. Health Aff (Millwood). March. 1. 2007;26(2):492-9. [pmid: 17339678].
24 Castle NG. Nursing home administrators’ opinions of the nursing home compare web site. Gerontologist. Jun. 2005;45(3):299-308. [pmid: 15933270].
25 Castle NG. Consumers’ use of internet-based nursing home report cards. Jt Comm J Qual Patient Saf. Jun. 2009;35(6):316-23. [pmid: 19565691].
26 Castle NG. The Nursing Home Compare report card: consumers’ use and understanding. J Aging Soc Policy. Apr–Jun. 2009;21(2):187-208. [pmid: 19333842].
27 Castle NG, Engberg J, Liu D. Have Nursing Home Compare quality measure scores changed over time in response to competition?. Qual Saf Health Care. Jun. 2007;16(3):185-91. [pmid: 17545344].
28 Castle NG, Liu D, Engberg J. The association of Nursing Home Compare quality measures with market competition and occupancy rates. J Healthc Qual. Mar–Apr. 2008;30(2):4-14. [pmid: 18411887].
29 Castle NG, Sonon K, Antonova J. The impact of special focus facility nursing homes on market quality. Gerontologist. Aug. 2010;50(4):519-30. [pmid: 20154307].
30 Chassin MR. Achieving and sustaining improved quality: lessons from New York State and cardiac surgery. Health Aff (Millwood). Jul–Aug. 2002;21(4):40-51. [pmid: 12117152].
31 Chen TT, Chung KP, Huang HC, et al. Using discrete choice experiment to elicit doctors’ preferences for the report card design of diabetes care in Taiwan - a pilot study. J Eval Clin Pract. Feb. 2010;16(1):14-20. [pmid: 20367811].
32 Cheng SH, Song HY. Physician performance information and consumer choice: a survey of subjects with the freedom to choose between doctors. Qual Saf Health Care. Apr. 2004;13(2):98-101. [pmid: 15069215].
33 Chernew M, Gowrisankaran G, McLaughlin C, et al. Quality and employers’ choice of health plans. J Health Econ. May. 2004;23(3):471-92. [pmid: 15120466].
34 Chernew M, Scanlon DP. Health plan report cards and insurance choice. Inquiry. Spring. 1998;35(1):9-22. [pmid: 9597014].
35 Clough JD, Engler D, Snow R, et al. Lack of relationship between the Cleveland Health Quality Choice project and decreased inpatient mortality in Cleveland. Am J Med Qual. Mar–Apr. 2002;17(2):47-55. [pmid: 11941994].
36 Cutler DM, Huckman RS, Landrum MB. The Role of Information in Medical Markets: An Analysis of Publicly Reported Outcomes in Cardiac Surgery. American Economic Review. 2004;94(2):342-46.
37 Dafny L, Dranove D. Do report cards tell consumers anything they don’t know already? The case of Medicare HMOs. Rand J Econ. Autumn. 2008;39(3):790-821. [pmid: 19013864].
38 Damman OC, Hendriks M, Rademakers J, et al. How do healthcare consumers process and evaluate comparative healthcare information? A qualitative study using cognitive interviews. BMC Public Health. 2009;9:423. [pmid: 19930564].
39 de Groot IB, Otten W, Smeets HJ, et al. Is the impact of hospital performance data greater in patients who have compared hospitals?. BMC Health Serv Res. 2011;11. [pmid: 21906293].
40 Dijs-Elsinga J, Otten W, Versluijs MM, et al. Choosing a hospital for surgery: the importance of information on quality of care. Med Decis Making. Sep–Oct. 2010;30(5):544-55. [pmid: 20110514].
41 Donelan K, Rogers RS, Eisenhauer A, et al. Consumer comprehension of surgeon performance data for coronary bypass procedures. Ann Thorac Surg. 2011;91(5):1400-5. discussion 5–6. [pmid: 21524448].
42 Dranove D, Kessler D, McClellan M, et al. Is More Information Better? The Effects of ‘Report Cards’ on Health Care Providers. J Polit Econ. 2003;111(3):555-88.
43 Dranove D, Sfekas A. Start spreading the news: a structural estimate of the effects of New York hospital report cards. J Health Econ. Sep. 2008;27(5):1201-7. [pmid: 18420293].
44 Elliott MN, Lehrman WG, Goldstein EH, et al. Hospital survey shows improvements in patient experience. Health Aff (Millwood). Nov. 2010;29(11):2061-7. [pmid: 21041749].
45 Epstein AJ. Effects of report cards on referral patterns to cardiac surgeons. J Health Econ. Sep. 2010;29(5):718-31. [pmid: 20599284].
46 Evans JH, Yuhchang H, Nagarajan N, et al. Involuntary Benchmarking and Quality Improvement: The Effect of Mandated Public Disclosure on Hospitals. JAAF. Summer97. 1997;12(3):315-46. [pmid: 11874415].
47 Fanjiang G, von Glahn T, Chang H, et al. Providing patients web-based data to inform physician choice: if you build it, will they come?. J Gen Intern Med. Oct. 2007;22(10):1463-6. [pmid: 17653810].
48 Farley DO, Elliott MN, Short PF, et al. Effect of CAHPS performance information on health plan choices by Iowa Medicaid beneficiaries. Med Care Res Rev. Sep. 2002;59(3):319-36. [pmid: 12205831].
49 Farley DO, Short PF, Elliott MN, et al. Effects of CAHPS health plan performance information on plan choices by New Jersey Medicaid beneficiaries. Health Serv Res. Aug. 2002;37(4):985-1007. [pmid: 12236394].
50 Farley Short P, McCormack L, Hibbard J, et al. Similarities and differences in choosing health plans. Med Care. Apr. 2002;40(4):289-302. [pmid: 12021685].
51 Fasolo B, Reutskaja E, Dixon A, et al. Helping patients choose: how to improve the design of comparative scorecards of hospital quality. Patient Educ Couns. Mar. 2010;78(3):344-9. [pmid: 20171822].
52 Foreman S, Kenkel D, Shea D. Cost and quality information and health care market reform. Adv Health Econ Health Serv Res. 1995;15:137-53. [pmid: 10163094].
53 Fowles JB, Kind EA, Braun BL, et al. Consumer Responses to Health Plan Report Cards in Two Markets. Med Care. 2000;38(5):469-81. [pmid: 10800974].
54 Fox MH, Moore J, Zimmerman M, et al. The effectiveness of CAHPS among women enrolling in Medicaid managed care. J Ambul Care Manage. Oct. 2001;24(4):76-91. [pmid: 11680241].
55 Friedberg MW, Mehrotra A, Linder JA. Reporting hospitals’ antibiotic timing in pneumonia: adverse consequences for patients?. Am J Manag Care. Feb. 2009;15(2):137-44. [pmid: 19284811].
56 Friedberg MW, SteelFisher GK, Karp M, et al. Physician Groups’ Use of Data from Patient Experience Surveys. J Gen Intern Med. May. 2011;26(5):498-504. [pmid: 21161419].
57 Fung CH, Elliott MN, Hays RD, et al. Patients’ preferences for technical versus interpersonal quality when selecting a primary care physician. Health Serv Res. Aug. 2005;40(4):957-77. [pmid: 16033487].
58 Gabel JR. When employers choose health plans: do NCQA accreditation and HEDIS data count?. 1998.
59 Gaudet J. Heller School for Social P, Management. Nursing home compare: predictors and consequences of differing organizational response. [Dissertation]. Massachusetts. Brandeis University, The Heller School for Social Policy and Management. 2011.
60 Geraedts M, Schwartze D, Molzahn T. Hospital quality reports in Germany: patient and physician opinion of the reported quality indicators. BMC Health Serv Res. 2007;7:157. [pmid: 17903244].
61 Gerteis M, Gerteis JS, Newman D, et al. Testing consumers’ comprehension of quality measures using alternative reporting formats. Health Care Financ Rev. Spring. 2007;28(3):31-45. [pmid: 17645154].
62 Ghali WA, Ash AS, Hall RE, et al. Statewide Quality Improvement Initiatives and Mortality After Cardiac Surgery. JAMA. Feb. 5. 1997;277(5):379-82. [pmid: 9010169].
63 Gibbs DA, Sangl JA, Burrus B. Consumer perspectives on information needs for health plan choice. Health Care Financ Rev. Fall. 1996;18(1):55-73. [pmid: 10165037].
64 Ginsburg LS. Factors that influence line managers’ perceptions of hospital performance data. Health Serv Res. Feb. 2003;38(1 Pt 1):261-86. [pmid: 12650391].
65 Glance LG, Dick A, Mukamel DB, et al. Are high-quality cardiac surgeons less likely to operate on high-risk patients compared to low-quality surgeons? Evidence from New York State. Health Serv Res. Feb. 2008;43(1 Pt 1):300-12. [pmid: 18211531].
66 Goldstein E, Fyock J. Reporting of CAHPS quality information to medicare beneficiaries. Health Serv Res. 2001;36(3):477-88. [pmid: 11482585].
67 Grabowski DC, Town RJ. Does information matter? Competition, quality, and the impact of nursing home report cards. Health Serv Res. 2011;46(6 PART 1):1698-719. [pmid: 21790590].
68 Gross PA, Schaffer WA. Consumer awareness of hospital mortality data. J Health Care Mark. Dec. 1989;9(4):52-5. [pmid: 10304175].
69 Guadagnoli E, Epstein AM, Zaslavsky A, et al. Providing consumers with information about the quality of health plans: the Consumer Assessment of Health Plans demonstration in Washington State. Jt Comm J Qual Improv. Jul. 2000;26(7):410-20. [pmid: 10897458].
70 Guru V, Fremes SE, Naylor CD, et al. Public versus private institutional performance reporting: what is mandatory for quality improvement?. Am Heart J. Sep. 2006;152(3):573-8. [pmid: 16923433].
71 Guru V, Naylor CD, Fremes SE, et al. Publicly reported provider outcomes: the concerns of cardiac surgeons in a single-payer system. Can J Cardiol. Jan. 2009;25(1):33-8. [pmid: 19148340].
72 Habermann EB, Virnig BA, Riley GF, et al. The impact of a change in Medicare reimbursement policy and HEDIS measures on stage at diagnosis among Medicare HMO and fee-for-service female breast cancer patients. Med Care. Aug. 2007;45(8):761-6. [pmid: 17667310].
73 Hannan EL, Kilburn H Jr, Racz M, et al. Improving the outcomes of coronary artery bypass surgery in New York State. JAMA. Mar. 1994;271(10):761-6. [pmid: 8114213].
74 Hannan EL, Kumar D, Racz M, et al. New York State’s Cardiac Surgery Reporting System: four years later. Ann Thorac Surg. Dec. 1994;58(6):1852-7. [pmid: 7979781].
75 Hannan EL, Sarrazin MSV, Doran DR, et al. Provider Profiling and Quality Improvement Efforts in Coronary Artery Bypass Graft Surgery: The Effect on Short-Term Mortality Among Medicare Beneficiaries. Med Care. 2003;41(10):1164-72. [pmid: 14515112].
76 Hannan EL, Stone CC, Biddle TL, et al. Public release of cardiac surgery outcomes data in New York: what do New York state cardiologists think of it?. Am Heart J. Dec. 1997;134(6):1120-8. [pmid: 9424074].
77 Harris KM. Can high quality overcome consumer resistance to restricted provider access? Evidence from a health plan choice experiment. Health Serv Res. Jun. 2002;37(3):551-71. [pmid: 12132595].
78 Harris-Kojetin LD, McCormack LA, Jael EF, et al. Creating more effective health plan quality reports for consumers: lessons from a synthesis of qualitative testing. Health Serv Res. Jul. 2001;36(3):447-76. [pmid: 11482584].
79 Harris-Kojetin LD, McCormack LA, Jael EM, et al. Beneficiaries’ perceptions of new Medicare health plan choice print materials. Health Care Financ Rev. Fall. 2001;23(1):21-35. [pmid: 12500360].
80 Hendriks M, Spreeuwenberg P, Rademakers J, et al. Dutch healthcare reform: did it result in performance improvement of health plans? A comparison of consumer experiences over time. BMC Health Serv Res. Sept. 2009;9:167. [pmid: 19761580].
81 Hibbard JH, Berkman N, McCormack LA, et al. The impact of a CAHPS report on employee knowledge, beliefs, and decisions. Med Care Res Rev. Mar. 2002;59(1):104-16. [pmid: 11877876].
82 Hibbard JH, Harris-Kojetin L, Mullin P, et al. Increasing the impact of health plan report cards by addressing consumers’ concerns. Health Aff (Millwood). Sep–Oct. 2000;19(5):138-43. [pmid: 10992661].
83 Hibbard JH, Jewett JJ. What type of quality information do consumers want in a health care report card?. Med Care Res Rev. Mar. 1996;53(1):28-47. [pmid: 10156433].
84 Hibbard JH, Jewett JJ. Will quality report cards help consumers?. Health Aff (Millwood). May–Jun. 1997;16(3):218-28. [pmid: 9141339].
85 Hibbard JH, Jewett JJ, Legnini MW, et al. Choosing a health plan: do large employers use the data?. Health Aff (Millwood) 1997. November. 1. 1997;16(6):172-80. [pmid: 9444825].
86 Hibbard JH, Peters E, Dixon A, et al. Consumer competencies and the use of comparative quality information: it isn’t just about literacy. Med Care Res Rev. Aug. 2007;64(4):379-94. [pmid: 17684108].
87 Hibbard JH, Peters E, Slovic P, et al. Making health care quality reports easier to use. Jt Comm J Qual Improv. Nov. 2001;27(11):591-604. [pmid: 11708039].
88 Hibbard JH, Slovic P, Peters E, et al. Strategies for Reporting Health Plan Performance Information to Consumers: Evidence from Controlled Studies. Health Serv Res. 2002;37(2):291-313. [pmid: 12035995].
89 Hibbard JH, Slovic P, Peters E, et al. Is the informed-choice policy approach appropriate for Medicare beneficiaries?. Health Aff (Millwood). May–Jun. 2001;20(3):199-203. [pmid: 11585167].
90 Hibbard JH, Sofaer S, Jewett JJ. Condition-specific performance information: assessing salience, comprehension, and approaches for communicating quality. Health Care Financ Rev. 1996;18(1):95-109. [pmid: 10165040].
91 Hibbard JH, Stockard J, Tusler M. Does publicizing hospital performance stimulate quality improvement efforts?. Health Aff (Millwood). Mar–Apr. 2003;22(2):84-94. [pmid: 12674410].
92 Hibbard JH, Stockard J, Tusler M. Hospital performance reports: impact on quality, market share, and reputation. Health Aff (Millwood). Jul–Aug. 2005;24(4):1150-60. [pmid: 16012155].
93 Hollenbeak CS, Gorton CP, Tabak YP, et al. Reductions in mortality associated with intensive public reporting of hospital outcomes. Am J Med Qual. Jul–Aug. 2008;23(4):279-86. [pmid: 18658101].
94 Howard DH, Kaplan B. Do report cards influence hospital choice? The case of kidney transplantation. Inquiry. Summer. 2006;43(2):150-9. [pmid: 17004644].
95 Jang WM, Eun SJ, Lee CE, et al. Effect of repeated public releases on cesarean section rates. Journal of preventive medicine and public health = Yebang Uihakhoe chi. 2011;44(1):2-8. [pmid: 21483217].
96 Jang WM, Eun SJ, Sagong P, et al. The change in readmission rate, length of stay and hospital charge after performance reporting of hip hemiarthroplasty. Journal of Preventive Medicine and Public Health. 2010;43(6):523-34. [pmid: 21139413].
97 Jewett JJ, Hibbard JH. Comprehension of quality care indicators: differences among privately insured, publicly insured, and uninsured. Health Care Financ Rev. Fall. 1996;18(1):75-94. [pmid: 10165038].
98 Jha AK, Epstein AM. The predictive accuracy of the New York State coronary artery bypass surgery report-card system. Health Aff (Millwood). May–Jun. 2006;25(3):844-55. [pmid: 16684751].
99 Jin GZ, Sorensen AT. Information and consumer choice: the value of publicized health plan ratings. J Health Econ. Mar. 2006;25(2):248-75. [pmid: 16107284].
100 Jung K. The impact of information disclosure on quality of care in HMO markets. Int J Qual Health Care. Dec. 2010;22(6):461-8. [pmid: 20940251].
101 Jung K, Shea D, Warner C. Agency characteristics and changes in home health quality after home health compare. J Aging Health. 2010;22(4):454-76. [pmid: 20231725].
102 Kang HY, Kim SJ, Cho W, et al. Consumer use of publicly released hospital performance information: assessment of the National Hospital Evaluation Program in Korea. Health Policy. Feb. 2009;89(2):174-83. [pmid: 18619703].
103 Khang YH, Yun SC, Jo MW, et al. Public release of institutional Cesarean section rates in South Korea: which women were aware of the information?. Health Policy. Apr. 2008;86(1):10-6. [pmid: 17964680].
104 Knutson DJ, Kind EA, Fowles JB, et al. Impact of report cards on employees: a natural experiment. Health Care Financ Rev. Fall. 1998;20(1):5-27. [pmid: 10387425].
105 Konetzka RT, Polsky D, Werner R. Shipping out instead of shaping up: rehospitalization from nursing homes as an unintended effect of public reporting. SSRN working paper. 2012.
106 Laschober M, Maxfield M, Felt-Lisk S, et al. Hospital response to public reporting of quality indicators. Health Care Financ Rev. Spring. 2007;28(3):61-76. [pmid: 17645156].
107 Laschober MA. Hospital compare highlights potential challenges in public reporting for hospitals. Princeton, N.J. Mathematica Policy Research, Inc. 2006.
108 Lied TR, Sheingold S. HEDIS performance trends in Medicare managed care. Health Care Financ Rev. Fall. 2001;23(1):149-60. [pmid: 12500369].
109 Liu H, Phelps CE, Veazie PJ, et al. Managed care quality of care and plan choice in New York SCHIP. Health Serv Res. Jun. 2009;44(3):843-61. [pmid: 19208091].
110 Longo DR, Everet KD. Health care consumer reports: an evaluation of consumer perspectives. J Health Care Finance. Fall. 2003;30(1):65-71. [pmid: 12967245].
111 Longo DR, Land G, Schramm W, et al. Consumer reports in health care. Do they make a difference in patient care?. JAMA. Nov. 19. 1997;278(19):1579-84.
112 Luce JM, Thiel GD, Holland MR, et al. Use of risk-adjusted outcome data for quality improvement by public hospitals. West J Med. May. 1996;164(5):410-4. [pmid: 8686297].
113 Magee H, Davis LJ, Coulter A. Public views on healthcare performance indicators and patient choice. J R Soc Med. Jul. 2003;96(7):338-42. [pmid: 12835446].
114 Mannion R, Davies H, Marshall M. Impact of star performance ratings in English acute hospital trusts. J Health Serv Res Policy. Jan. 2005;10(1):18-24. [pmid: 15667700].
115 Mannion R, Goddard M. Public disclosure of comparative clinical performance data: lessons from the Scottish experience. J Eval Clin Pract. May. 2003;9(2):277-86. [pmid: 12787191].
116 Marquis MS, Long SH. Prevalence of selected employer health insurance purchasing strategies in 1997. Health Aff (Millwood). Jul–Aug. 2001;20(4):220-30. [pmid: 11463079].
117 Marshall M, Noble J, Davies H, et al. Development of an information source for patients and the public about general practice services: an action research study. Health Expect. Sep. 2006;9(3):265-74. [pmid: 16911141].
118 Marshall MN, Hiscock J, Sibbald B. Attitudes to the public release of comparative information on the quality of general practice care: qualitative study. BMJ. Nov. 30. 2002;325(7375):1278. [pmid: 12458248].
119 Maytham G, Kessaris N. A change in opinion on surgeon’s performance indicators. Interact Cardiovasc Thorac Surg. 2011;12(4):586-9. [pmid: 21228042].
120 Mazor KM, Dodd KS. A qualitative study of consumers’ views on public reporting of health care-associated infections. Am J Med Qual. Sep–Oct. 2009;24(5):412-8. [pmid: 19525369].
121 Mazor KM, Dodd KS, Kunches L. Communicating hospital infection data to the public: a study of consumer responses and preferences. Am J Med Qual. Mar–Apr. 2009;24(2):108-15. [pmid: 19237552].
122 McCormack LA, Garfinkel SA, Hibbard JH, et al. Health plan decision making with new medicare information materials. Health Serv Res. Jul. 2001;36(3):531-54. [pmid: 11482588].
123 Mehrotra A, Bodenheimer T, Dudley RA. Employers’ efforts to measure and improve hospital quality: determinants of success. Health Aff (Millwood). Mar–Apr. 2003;22(2):60-71. [pmid: 12674408].
124 Mennemeyer ST, Morrisey MA, Howard LZ. Death and reputation: how consumers acted upon HCFA mortality information. Inquiry. Summer. 1997;34(2):117-28. [pmid: 9256817].
125 Merle V, Germain JM, Tavolacci MP, et al. Influence of infection control report cards on patients’ choice of hospital: pilot survey. J Hosp Infect. Mar. 2009;71(3):263-8. [pmid: 19147258].
126 Moscucci M, Eagle KA, Share D, et al. Public reporting and case selection for percutaneous coronary interventions: an analysis from two large multicenter percutaneous coronary intervention databases. J Am Coll Cardiol. Jun. 2005;45(11):1759-65. [pmid: 15936602].
127 Moser A, Korstjens I, van der Weijden T, et al. Themes affecting health-care consumers’ choice of a hospital for elective surgery when receiving web-based comparative consumer information. Patient Educ Couns. Mar. 2010;78(3):365-71. [pmid: 20006460].
128 Mukamel DB, Ladd H, Weimer DL, et al. Is there evidence of cream skimming among nursing homes following the publication of the Nursing Home Compare report card?. Gerontologist. Dec. 2009;49(6):793-802. [pmid: 19491363].
129 Mukamel DB, Mushlin AI. Quality of care information makes a difference: an analysis of market share and price changes after publication of the New York State Cardiac Surgery Mortality Reports. Med Care. Jul. 1998;36(7):945-54. [pmid: 9674613].
130 Mukamel DB, Mushlin AI, Weimer D, et al. Do quality report cards play a role in HMOs’ contracting practices? Evidence from New York State. Health Serv Res. Apr. 2000;35(1 Pt 2):319-32. [pmid: 10778818].
131 Mukamel DB, Spector WD, Zinn J, et al. Changes in clinical and hotel expenditures following publication of the nursing home compare report card. Med Care. Oct. 2010;48(10):869-74. [pmid: 20733531].
132 Mukamel DB, Spector WD, Zinn JS, et al. Nursing homes’ response to the nursing home compare report card. J Gerontol B Psychol Sci Soc Sci. Jul. 2007;62(4):S218-25. [pmid: 17673535].
133 Mukamel DB, Weimer DL, Spector WD, et al. Publication of quality report cards and trends in reported quality measures in nursing homes. Health Serv Res. Aug. 2008;43(4):1244-62. [pmid: 18248401].
134 Mukamel DB, Weimer DL, Zwanziger J, et al. Quality report cards, selection of cardiac surgeons, and racial disparities: a study of the publication of the New York State Cardiac Surgery Reports. Inquiry. Winter. 2004;41(4):435-46. [pmid: 15835601].
135 Mukamel DB, Weimer DL, Zwanziger J, et al. Quality of cardiac surgeons and managed care contracting practices. Health Serv Res. Oct. 2002;37(5):1129-44. [pmid: 12479489].
136 Narins CR, Dozier AM, Ling FS, et al. The influence of public reporting of outcome data on medical decision making by physicians. Arch Intern Med. Jan. 10. 2005;165(1):83-7. [pmid: 15642879].
137 O’Day B, Palsbo SE, Dhont K, et al. Health plan selection criteria by people with impaired mobility. Med Care. Sep. 2002;40(9):732-42. [pmid: 12218764].
138 Omoigui NA, Miller DP, Brown KJ, et al. Outmigration for coronary bypass surgery in an era of public dissemination of clinical outcomes. Circulation. Jan. 1996;93(1):27-33. [pmid: 8616936].
139 Palsbo SE, Kroll T. Meeting information needs to facilitate decision making: report cards for people with disabilities. Health Expect. Sep. 2007;10(3):278-85. [pmid: 17678516].
140 Park J, Konetzka RT, Werner RM. Performing Well on Nursing Home Report Cards: Does It Pay Off?. Health Serv Res. 2011;46(2):531-54. [pmid: 21029093].
141 Park J, Werner RM. Changes in the Relationship between Nursing Home Financial Performance and Quality of Care under Public Reporting. Health Econ. 2011;20(7):783-801. [pmid: 20578255].
142 Peters E, Dieckmann N, Dixon A, et al. Less is more in presenting quality information to consumers. Med Care Res Rev. Apr. 2007;64(2):169-90. [pmid: 17406019].
143 Peters E, Dieckmann NF, Vastfjall D, et al. Bringing meaning to numbers: the impact of evaluative categories on decisions. J Exp Psychol Appl. Sep. 2009;15(3):213-27. [pmid: 19751072].
144 Peterson ED, DeLong ER, Jollis JG, et al. The effects of New York’s bypass surgery provider profiling on access to care and patient outcomes in the elderly. J Am Coll Cardiol. Oct. 1998;32(4):993-9. [pmid: 9768723].
145 Pettijohn TL, Lawrence ME. The impact of outcomes data reporting on access to health care of high-risk patients to interventional cardiologists in the United States. J Invasive Cardiol. Mar. 1999;11(3):111-5. [pmid: 10745496].
146 Pham HH, Coughlan J, O’Malley AS. The impact of quality-reporting programs on hospital operations. Health Aff (Millwood). Sep–Oct. 2006;25(5):1412-22. [pmid: 16966741].
147 Pham HH, Frick KD, Diener-West M, et al. Is health plan employer data and information set performance associated with withdrawal from medicare managed care?. Med Care. Mar. 2002;40(3):212-26. [pmid: 11880794].
148 Pope DG. Reacting to rankings: Evidence from “America’s Best Hospitals”. J Health Econ. Dec. 2009;28(6):1154-65. [pmid: 19818518].
149 Putnam W, Bower KN, Cox J, et al. Quality indicators for cardiac care: national standards in a community context. J Health Serv Res Policy. Jan. 2006;11(1):5-12. [pmid: 16378527].
150 Rainwater JA. Evaluation of California’s Quality of Care Report Card. Sacramento, CA. University of California, Davis, Center for Health Services Research in Primary Care. 2005.
151 Rainwater JA, Romano PS. What data do California HMOs use to select hospitals for contracting?. Am J Manag Care. Aug. 2003;9(8):553-61. [pmid: 12921233].
152 Rainwater JA, Romano PS, Antonius DM. The California Hospital Outcomes Project: how useful is California’s report card for quality improvement?. Jt Comm J Qual Improv. Jan. 1998;24(1):31-9. [pmid: 9494872].
153 Ranganathan M, Hibbard J, Rodday AM, et al. Motivating public use of physician-level performance data: an experiment on the effects of message and mode. Med Care Res Rev. Feb. 2009;66(1):68-81. [pmid: 18923193].
154 Reeves R, Seccombe I. Do patient surveys work? The influence of a national survey programme on local quality-improvement initiatives. Qual Saf Health Care. Dec. 2008;17(6):437-41. [pmid: 19064659].
155 Richard SA, Rawal S, Martin DK. Patients’ views about cardiac report cards: a qualitative study. Can J Cardiol. Sep. 2005;21(11):943-7. [pmid: 16239978].
156 Romano PS, Marcin JP, Dai JJ, et al. Impact of public reporting of coronary artery bypass graft surgery performance data on market share, mortality, and patient selection. Med Care. 2011;49(12):1118-25. [pmid: 22002641].
157 Romano PS, Rainwater JA, Antonius D. Grading the graders: how hospitals in California and New York perceive and interpret their report cards. Med Care. Mar. 1999;37(3):295-305. [pmid: 10098573].
158 Romano PS, Zhou H. Do well-publicized risk-adjusted outcomes reports affect hospital volume?. Med Care. Apr. 2004;42(4):367-77. [pmid: 15076814].
159 Rosenthal GE, Hammar PJ, Way LE, et al. Using hospital performance data in quality improvement: the Cleveland Health Quality Choice experience. Jt Comm J Qual Improv. Jul. 1998;24(7):347-60. [pmid: 9689568].
160 Rosenthal GE, Quinn L, Harper DL. Declines in hospital mortality associated with a regional initiative to measure hospital performance. Am J Med Qual. Summer. 1997;12(2):103-12. [pmid: 9161057].
161 Rosenthal MB, Landon BE, Normand SL, et al. Employers’ use of value-based purchasing strategies. JAMA. Nov. 21. 2007;298(19):2281-8. [pmid: 18029832].
162 Sarfaty M, Myers RE. The effect of HEDIS measurement of colorectal cancer screening on insurance plans in Pennsylvania. Am J Manag Care. May. 2008;14(5):277-82. [pmid: 18471032].
163 Scanlo DP, Chernew M, McLaughlin C, et al. The impact of health plan report cards on managed care enrollment. J Health Econ. Jan. 2002;21(1):19-41. [pmid: 11845924].
164 Scanlon DP, Chernew M. HEDIS measures and managed care enrollment. Med Care Res Rev. 1999;56(Suppl 2):60-84. [pmid: 10327824].
165 Scanlon DP, Darby C, Rolph E, et al. The role of performance measures for improving quality in managed care organizations. Health Serv Res. Jul. 2001;36(3):619-41. [pmid: 11482592].
166 Schneider EC, Epstein AM. Influence of cardiac-surgery performance reports on referral practices and access to care. A survey of cardiovascular specialists. N Engl J Med. Jul. 1996;335(4):251-6. [pmid: 8657242].
167 Schneider EC, Epstein AM. Use of public performance reports: a survey of patients undergoing cardiac surgery. JAMA. May. 27. 1998;279(20):1638-42. [pmid: 9613914].
168 Schultz J, Thiede Call K, Feldman R, et al. Do employees use report cards to assess health care provider systems?. Health Serv Res. Jul. 2001;36(3):509-30. [pmid: 11482587].
169 Schwartz LM, Woloshin S, Birkmeyer JD. How do elderly patients decide where to go for major surgery? Telephone interview survey. BMJ. Oct. 8. 2005;331(7520):821. [pmid: 16192286].
170 Shabino C, Richardson DB. In pursuit of excellence: the checkpoint journey. WMJ. Dec. 2006;105(8):34-7. [pmid: 17256706].
171 Smith F, Gerteis M, Downey N, et al. The effects of disseminating performance data to health plans: results of qualitative research with the Medicare Managed Care plans. Health Serv Res. Jul. 2001;36(3):643-63. [pmid: 11482593].
172 Sofaer S, Crofton C, Goldstein E, et al. What do consumers want to know about the quality of care in hospitals?. Health Serv Res. Dec. 2005;40(6 Pt 2):2018-36. [pmid: 16316436].
173 Spranca M, Kanouse DE, Elliott M, et al. Do consumer reports of health plan quality affect health plan selection?. Health Serv Res. Dec. 2000;35(5 Pt 1):933-47. [pmid: 11130805].
174 Spranca MD, Elliott MN, Shaw R, et al. Disenrollment information and Medicare plan choice: is more information better?. Health Care Financ Rev. Spring. 2007;28(3):47-59. [pmid: 17645155].
175 Stein BD, Kogan JN, Essock S, et al. Views of mental health care consumers on public reporting of information on provider performance. Psychiatr Serv. May. 2009;60(5):689-92. [pmid: 19411360].
176 Stevenson DG. Is a public reporting approach appropriate for nursing home care?. J Health Polit Policy Law. Aug. 2006;31(4):773-810. [pmid: 16971545].
177 Tai-Seale M. Does consumer satisfaction information matter? Evidence on member retention in FEHBP plans. Med Care Res Rev. Jun. 2004;61(2):171-86. [pmid: 15155050].
178 Teleki SS, Kanouse DE, Elliott MN, et al. Understanding the reporting practices of CAHPS sponsors. Health Care Financ Rev. 2007;28(3):17-30. [pmid: 17645153].
179 Tu JV, Cameron C. Impact of an acute myocardial infarction report card in Ontario, Canada. Int J Qual Health Care. Apr. 2003;15(2):131-7. [pmid: 12705706].
180 Tu JV, Donovan LR, Lee DS, et al. Effectiveness of public report cards for improving the quality of cardiac care: the EFFECT study: a randomized trial. JAMA. Dec. 2. 2009;302(21):2330-7. [pmid: 19923205].
181 Uhrig JD, Harris-Kojetin L, Bann C, et al. Do content and format affect older consumers’ use of comparative information in a Medicare health plan choice? Results from a controlled experiment. Med Care Res Rev. Dec. 2006;63(6):701-18. [pmid: 17099122].
182 Uhrig JD, Short PF. Testing the effect of quality reports on the health plan choices of Medicare beneficiaries. Inquiry. Winter. 2002;39(4):355-71. [pmid: 12638711].
183 Van Nie NC, Hollands LJ, Hamers JP. Reporting quality of nursing home care by an internet report card. Patient Educ Couns. Mar. 2010;78(3):337-43. [pmid: 20189748].
184 Veroff DR, Gallagher PM, Wilson V, et al. Effective reports for health care quality data: lessons from a CAHPS demonstration in Washington State. Int J Qual Health Care. Dec. 1998;10(6):555-60. [pmid: 9928595].
185 Vladeck BC, Goodwin EJ, Myers LP, et al. Consumers and hospital use: the HCFA “death list”. Health Aff (Millwood). Spring. 1988;7(1):122-5. [pmid: 3360387].
186 Wang J, Hockenberry J, Chou SY, et al. Do bad report cards have consequences? Impacts of publicly reported provider quality information on the CABG market in Pennsylvania. J Health Econ. Mar. 2011;30(2):392-407. [pmid: 21195494].
187 Wedig GJ, Tai-Seale M. The effect of report cards on consumer choice in the health insurance market. J Health Econ. Nov. 2002;21(6):1031-48. [pmid: 12475124].
188 Werner R, Norton EC, Konetzka R, et al. Do consumers respond to publicly reported quality information? Evidence from nursing homes. J Health Econ. 2012;31(1):50-61. [pmid: 22307033].
189 Werner R, Stuart E, Polsky D. Public reporting drove quality gains at nursing homes. Health Aff (Millwood). Sep. 2010;29(9):1706-13. [pmid: 20820030].
190 Werner RM, Asch DA, Polsky D. Racial profiling: the unintended consequences of coronary artery bypass graft report cards. Circulation. Mar. 15. 2005;111(10):1257-63. [pmid: 15769766].
191 Werner RM, Bradlow ET. Public Reporting On Hospital Process Improvements Is Linked To Better Patient Outcomes. Health Aff (Millwood). Jul. 2010;29(7):1319-24. [pmid: 20606180].
192 Werner RM, Konetzka RT, Kruse GB. Impact of public reporting on unreported quality of care. Health Serv Res. Apr. 2009;44(2 Pt 1):379-98. [pmid: 19178586].
193 Werner RM, Konetzka RT, Stuart EA, et al. Impact of public reporting on quality of postacute care. Health Serv Res. Aug. 2009;44(4):1169-87. [pmid: 19490160].
194 Werner RM, Konetzka RT, Stuart EA, et al. Changes in patient sorting to nursing homes under public reporting: improved patient matching or provider gaming?. Health Serv Res. 2011;46(2):555-71. [pmid: 21105869].
195 Wübker A, Auerland D, Wübker A. Does better information about hospital quality affect patients’ choice?. Empirical findings from Germany. MPRA Paper No. 10479. Available at http://mpra.ub.uni-muenchen.de/10479/. Accessed 2/9/2012. 2008.
196 Zinn J, Spector W, Hsieh L, et al. Do trends in the reporting of quality measures on the nursing home compare web site differ by nursing home characteristics?. Gerontologist. Dec. 2005;45(6):720-30. [pmid: 16326653].
197 Zinn JS, Spector WD, Weimer DL, et al. Strategic orientation and nursing home response to public reporting of quality measures: an application of the miles and snow typology. Health Serv Res. Apr. 2008;43(2):598-615. [pmid: 18370969].
198 Zinn JS, Weimer DL, Spector W, et al. Factors influencing nursing home response to quality measure publication: A resource dependence perspective. Health Care Manage Rev. Jul–Sep. 2010;35(3):256-65. [pmid: 20551773].

## Excluded Studies

1 Symposium report: Toward better choices in health care. Inquiry. 1988;25:423-68. Exclusion reason: No outcome data.
2 HCFA mortality studies. QA review: quality assurance news and views. 1990;2(2). Exclusion reason: No outcome data.
3 Cost control for quality care : meeting the challenge of health system financing. Geneva. Internat. Social Security Assoc. 1992. Exclusion reason: Wrong topic.
4 HEDIS 2.0: a precursor to national report cards for health plans. Business and health. 1993;11(14). Exclusion reason: No outcome data.
5 HEDIS (Health Plan Employer Data and Information Set) indicators and quality report cards. Qual Lett Healthc Lead. Mar. 1994;6(2):24-7. Exclusion reason: No outcome data. [pmid: 10133045].
6 NCQA releases HEDIS 2.0 standards. Quality monitoring group prepares to test report card measures. QRC Advis. Jan. 1994;10(3):1-3. Exclusion reason: No outcome data. [pmid: 10131407].
7 Data project aids managed care plan evaluations. Employee Benefit Plan Review. 1994;48(8):14. Exclusion reason: No outcome data.
8 Consumers…most Americans want more information to help them pick their health care plans, hospitals and doctors. Hosp Health Netw. Nov. 5. 1995;69(21):14. Exclusion reason: No outcome data. [pmid: 7581605].
9 Measuring health plan performance: sample report formats. Qual Lett Healthc Lead. Feb. 1995;7(1):19-22. Exclusion reason: No outcome data. [pmid: 10151587].
10 Summary report from the Cleveland Health Quality Choice Program. Qual Manag Health Care. Spring. 1995;3(3):78-90. Exclusion reason: No outcome data. [pmid: 10143559].
11 Government to study health plan choices. AHA News. 1995;31(12):5. Exclusion reason: No outcome data.
12 Judgment day. Drug Topics. 1995;139(14):26. Exclusion reason: No outcome data.
13 Report cards promise more than they deliver. Mod Healthc. 1995;25(11):30. Exclusion reason: No outcome data.
14 West. Mod Healthc. 1995;25(14):65. Exclusion reason: No outcome data.
15 CareData Reports provides information on consumer satisfaction with managed care. Health Care Strateg Manage. Jan. 1996;14(1):14. Exclusion reason: Wrong topic. [pmid: 10154079].
16 Health plan performance gets overhauled. Best’s Review/Life-Health Insurance Edition. 1996;97(5):12. Exclusion reason: No outcome data.
17 HEDIS compliance software available. Drug Topics. 1996;140(23):8. Exclusion reason: Wrong topic.
18 Medicaid Hedis Info Now Available. Hosp Health Netw. 1996;70(4):12. Exclusion reason: No outcome data.
19 N.Y. bypass deaths dropping. Mod Healthc. 1996;26(49):24. Exclusion reason: No outcome data.
20 Public call brings more than 800 HEDIS measures. Physician Executive. 1996;22(5):3. Exclusion reason: Wrong topic.
21 Special report: America’s best-designed hospital. Griffin’s design, care make it a hot benchmark. Healthc Benchmarks. Apr. 1997;4(4):45-8. 53. 4. Exclusion reason: Wrong topic. [pmid: 10176234].
22 Use MD profiling to improve capitation performance. Capitation Manag Rep. Aug. 1997;4(8):121-8. Exclusion reason: No outcome data. [pmid: 10175788].
23 Doctors, not report cards, shape consumer choices. Physician Relat Update. Mar. 1997;6(3):35. Exclusion reason: No outcome data. [pmid: 10166663].
24 New software addresses quality reporting rules. Best’s Review/Life-Health Insurance Edition. 1997;97(10):61. Exclusion reason: No outcome data.
25 Making the grade: a status report on hospital report cards. Health Syst Rev. Sep–Oct. 1997;30(5):11-4. Exclusion reason: Background. [pmid: 10173709].
26 Physician report cards more prevalent among MCOs, but do they work?. Manag Care Strateg. Dec. 1998;6(12):137-9. Exclusion reason: No outcome data. [pmid: 10351376].
27 How does your organization stack up to these HEDIS performance benchmarks?. Capitation Rates Data. Jul. 1998;3(7):76-8. Exclusion reason: No outcome data. [pmid: 10345862].
28 Health plan finds answers with data warehouse that stores 4,500 data elements. Data Strateg Benchmarks. Sep. 1998;2(9):140-2. Exclusion reason: No outcome data. [pmid: 10345385].
29 Study finds purchasers aren’t using providers’ outcomes data, quality report cards. Data Strateg Benchmarks. Feb. 1998;2(2):30-2. Exclusion reason: No outcome data. [pmid: 10345362].
30 Publicly reported data impacts administrative procedures, contracting decisions. Data Strateg Benchmarks. Oct. 1998;2(10):158-9. Exclusion reason: No outcome data. [pmid: 10345357].
31 HEDIS measures can make practices almost perfect. Physician Relat Update. Mar. 1998;7(3):32-3. Exclusion reason: No outcome data. [pmid: 10181775].
32 Toronto Academic Health Science Council. Performance 98 report. Hosp Q. Winter. 1998;2(2):79-80. Exclusion reason: Wrong topic. [pmid: 10621186].
33 NCQA uses HEDIS to assess managed care quality against natioanl averages, fee-for-service. Employee Benefit Plan Review. 1998;52(8):16. Exclusion reason: No outcome data.
34 New HEDIS specs broaden performance measurement. Health Management Technology. 1998;19(12):8. Exclusion reason: No outcome data. [pmid: 10178860].
35 Competition and accountability are serious business for hospitals. Mod Healthc. 1998. Sect. 24. Exclusion reason: No outcome data.
36 Use of clinical preventive services by adults aged <65 years enrolled in health-maintenance organizations--United States, 1996. MMWR Morb Mortal Wkly Rep. Jul. 31. 1998;47(29):613-9. Exclusion reason: Methods. [pmid: 9699811].
37 Stakes rise for HEDIS with new accreditation rules. Physician Relat Update. May. 1998;7(5):55-8. Exclusion reason: Background. [pmid: 10181781].
38 Are report cards giving physicians a bum rap?. Capitation Manag Rep. Aug. 1999;6(8):118-21. Exclusion reason: No outcome data. [pmid: 10558133].
39 Medicaid plan, health centers reveal secrets to boosting HEDIS scores, quality of care. Public Sect Contract Rep. Jul. 1999;5(7):104-8. Exclusion reason: No outcome data. [pmid: 10539510].
40 Pacific Business Group on Health spotlights MD group quality. Med Netw Strategy Rep. May. 8. 1999;8(5):1-9. Exclusion reason: No outcome data. [pmid: 10387718].
41 Mental health assessment tool helps determine best practices. Data Strateg Benchmarks. Jan. 1999;3(1):9-12. 1. Exclusion reason: No outcome data. [pmid: 10387194].
42 Report links health plan quality and satisfaction. Healthc Benchmarks. Dec. 1999;6(12):141-2. Exclusion reason: No outcome data. [pmid: 10662426].
43 For the record. Mod Healthc. 1999;29(6):16. Exclusion reason: No outcome data.
44 HCFA posts HMO ratings on Web site. Mod Healthc. 1999;29(5):6. Exclusion reason: No outcome data.
45 Guidelines introduced to help providers with newest HEDIS measure: menopause counseling. Rep Med Guidel Outcomes Res. Oct. 3. 2000;11(20):9-10. 2. Exclusion reason: Wrong topic. [pmid: 11865897].
46 Syndicated profiles providing nationwide quality report cards. Data Strateg Benchmarks. Oct. 2000;4(10):151-4. Exclusion reason: No outcome data. [pmid: 11149357].
47 Quality Compass 2000 shows steady improvement in HEDIS performance data. Capitation Rates Data. Oct. 2000;5(10):112-5. Exclusion reason: Wrong topic. [pmid: 11147536].
48 Reasons for accreditation denial to be publicly disclosed. Jt Comm Perspect. Nov–Dec. 2000;20(6):5. Exclusion reason: No outcome data. [pmid: 11142237].
49 Managed care outlook. HEDIS performance. Routine reporting drives improvement. Manag Care. Oct. 2000;9(10):60. Exclusion reason: No outcome data. [pmid: 11186554].
50 Consumers tuning in to plans’ quality ratings. Hosp Peer Rev. Jan. 2000;25(1):9-10. Exclusion reason: No outcome data. [pmid: 11184085].
51 Top 100 in cardiac care perform 4.7% to 31% better than others. Clin Resour Manag. Jun. 2000;1(6):92-4. 81. Exclusion reason: No outcome data. [pmid: 11014797].
52 Public access to the National Practitioner Data Bank: hearings, March 1 and 16, 2000, what consumers should know about their doctors; assessing the operation of the National Practitioner Data Bank. 106th Cong 2d ed. United States. Oversight and Investigations. 2000:1-128. Exclusion reason: Wrong topic.
53 HCFA updates instructions on disclosure of patient, SNF information. Natl Rep Subacute Care. Jul. 12. 2000;8(14):1-2. Exclusion reason: Background. [pmid: 11183242].
54 Health plans bear down on quality, HEDIS scores improve dramatically. Manag Care. Oct. 2001;10(10):34-5. Exclusion reason: No outcome data. [pmid: 11688109].
55 Health plans making solid progress on HEDIS performance. Capitation Rates Data. Oct. 2001;6(10):109-12. Exclusion reason: No outcome data. [pmid: 11680095].
56 Information on the Internet found to be usually accurate but also incomplete. Qual Lett Healthc Lead. Jul. 2001;13(7):11-2. 1. Exclusion reason: Wrong topic. [pmid: 11494813].
57 Use this report card to profile physicians on pharmacy use. Clin Resour Manag. Jul. 2001;2(7):104-7. Exclusion reason: Wrong topic. [pmid: 11482247].
58 Health care choices: sharing the quality message. Issue Brief Cent Medicare Educ. 2001;2(1):1-12. Exclusion reason: No outcome data. [pmid: 11859891].
59 Health care consumers say they want to know more objective measures about quality. Qual Lett Healthc Lead. Apr. 2001;13(4):12-3. 1. Exclusion reason: Background. [pmid: 11330225].
60 2002 HEDIS data mark big changes for high-performing physicians. Capitation Rates Data. Oct. 2002;7(10):116-8. Exclusion reason: No outcome data. [pmid: 12412317].
61 Pay for performance promoted in California. Qual Lett Healthc Lead. Feb. 13. 2002;14(2):1. Exclusion reason: Wrong topic. [pmid: 11995616].
62 Consumers take a pass on quality ratings. Marketing Health Services. Winter2002. 2002;22(4):9. Exclusion reason: Background.
63 Report cards don’t make the grade with physicians or consumers. Healthc Benchmarks. Apr. 2002;9(4):37-9. Exclusion reason: Background. [pmid: 11963434].
64 Quality reports. CMS and JCAHO strive to help consumers make better healthcare decisions. Health Care Food Nutr Focus. Aug. 2003;20(8):9. Exclusion reason: No outcome data. [pmid: 12905922].
65 Web Watch. Quality Progress. 2003;36(9):21. Exclusion reason: No outcome data. [pmid: 12463336].
66 Hospitals to watch. Marketing Health Services. Spring2003. 2003;23(1):5. Exclusion reason: Background. [pmid: 12645429].
67 New HEDIS areas include population health, service. Healthcare Benchmarks Qual Improv. Sep. 2003;10(9):103-5. Exclusion reason: Background. [pmid: 12966685].
68 Connecticut hospital puts performance data on web, warts and all. Perform Improv Advis. Oct. 2004;8(10):116-7. 09. Exclusion reason: No outcome data. [pmid: 15595476].
69 NCQA adds four new measures to HEDIS 2005. Qual Lett Healthc Lead. Aug. 2004;16(8):12-3. Exclusion reason: No outcome data. [pmid: 15478720].
70 CT hospitals give feedback on HCAHPS. AHA News. 2004;40(12):2. Exclusion reason: No outcome data. [pmid: 13491846].
71 2003 HEDIS data suggest growing quality gap between HMOs, other payers. Capitation Rates Data. Oct. 2004;9(10):116-20. Exclusion reason: Background. [pmid: 15595566].
72 Enhanced set of quality measures now available at Medicare’s easier-to-use nursing home compare. Miss RN. Spring. 2004;66(1):10. Exclusion reason: Background. [pmid: 15071813].
73 Consumers increase website use to compare hospitals. Qual Lett Healthc Lead. Oct. 2005;17(10):14-5. Exclusion reason: No outcome data. [pmid: 16358935].
74 The effect of report cards on Medicare HMO enrollment. Natl Bur Econ Res Bull Aging Health. Summer. 2005;(12):3. Exclusion reason: No outcome data. [pmid: 16175679].
75 CMS’s hospital compare makes hospital quality available to the public. Miss RN. Summer. 2005;67(2):8. Exclusion reason: No outcome data. [pmid: 16047851].
76 NQF endorses HCAHPS patient perception survey. Healthcare Benchmarks Qual Improv. Jul. 2005;12(7):82-3. Exclusion reason: No outcome data. [pmid: 16021980].
77 Curbing their enthusiasm. Physicians show reluctance to reveal performance data: study. Mod Healthc. May. 16. 2005;35(20):32. Exclusion reason: No outcome data. [pmid: 15926373].
78 Directory helps patients make informed choices. Hospital compiled information on all providers. Hosp Case Manag. Feb. 2005;13(2):19-20. Exclusion reason: No outcome data. [pmid: 15709554].
79 Leapfrog Group Releases Hospital Quality and Safety Survey. Quality Progress. 2005;38(1):16. Exclusion reason: No outcome data. [pmid: 15633051].
80 Leapfrog Group releases latest hospital survey results. Healthcare Purchasing News. 2005;29(1):8. Exclusion reason: No outcome data. [pmid: 16243266].
81 Medicare and Medicaid programs; requirements for long term care facilities; nursing services; posting of nurse staffing information. Final rule. Fed Regist. Oct. 28. 2005;70(208):62065-73. Exclusion reason: Wrong topic. [pmid: 16259092].
82 New quality yardsticks for HEDIS. Medical Economics. 2005;82(17):16. Exclusion reason: Background. [pmid: 18180786].
83 St. Francis Health System overhauls heart attack care process. Perform Improv Advis. Apr. 2006;10(4):42-5. 37. Exclusion reason: Wrong topic. [pmid: 16686099].
84 The best hospitals are getting better while others continue to struggle. Perform Improv Advis. Feb. 2006;10(2):21-4. 13. Exclusion reason: No outcome data. [pmid: 16550938].
85 HCAHPS promises to tell hospitals a lot about how they can improve care. 2006;42:7. Exclusion reason: No outcome data.
86 Patient Perception of Reputation Is Key. Health Care Collector. The Monthly Newsletter for Health Care Collectors. 2006;19(9):5-6. Exclusion reason: No outcome data.
87 When saying “I’m sorry” just isn’t enough. Medical Economics. 2006;83(24):20. Exclusion reason: No outcome data.
88 Backus Hospital earns high ranking for QI, patient safety. Perform Improv Advis. Apr. 2006;10(4):45-7. 37. Exclusion reason: Background. [pmid: 16686100].
89 Consumers empowered by public information in healthcare. Remington Report. 2006;14(5):52. Exclusion reason: Background.
90 Top hospitals record a 71% lower mortality rate. Healthcare Benchmarks Qual Improv. Dec. 2007;14(12):141-3. Exclusion reason: No outcome data. [pmid: 18019791].
91 By the Numbers. hfm (Healthcare Financial Management). 2007;61(3):1-8. Exclusion reason: Wrong topic.
92 Leapfrog: 87% of hospitals fail to take all recommended steps to avoid four common infections. Hosp Health Netw. Oct. 66. 2007;81(10):8. Exclusion reason: No outcome data. [pmid: 18027442].
93 Patient safety = patient satisfaction. Trustee. 2007;60(5):4. Exclusion reason: No outcome data. [pmid: 17608087].
94 Study: Pay-for-Performance Not Leading to Improvement. Quality Progress. 2007;40(8):12. Exclusion reason: Wrong topic.
95 The AHA Makes Strides in Quality and Patient Safety. AHA News. 2007;43(4):2. Exclusion reason: Wrong topic.
96 Physician Quality Reporting Initiative. J Med Assoc Ga. 2007;96(2):17-9. Exclusion reason: Background. [pmid: 18019441].
97 Public reporting boosts patient satisfaction. Hosp Peer Rev. Dec. 2008;33(12):159-60. Exclusion reason: No outcome data. [pmid: 19070325].
98 Your hand hygiene data may soon go ‘public’. Hosp Peer Rev. Feb. 2008;33(2):24-6. Exclusion reason: No outcome data. [pmid: 18402284].
99 How to Make Clients Happy. Healthcare Executive. 2008;23(1):42-4. Exclusion reason: No outcome data. [pmid: 18724590].
100 Mortality Reporting. Trustee. 2008;61(1):4. Exclusion reason: No outcome data.
101 Patient satisfaction up sharply after launch of public reporting (cover story). AHA News. 2008;44(20):1. Exclusion reason: No outcome data.
102 Scope. Hosp Health Netw. 2008;82(11):51-2. Exclusion reason: No outcome data.
103 Second National Scorecard on U.S. Healthcare System Finds No Overall Improvement. hfm (Healthcare Financial Management). 2008;62(8):9. Exclusion reason: Wrong topic.
104 Press Ganey: public reporting gives huge boost to patient satisfaction. Healthcare Benchmarks Qual Improv. Dec. 2008;15(12):121-3. Exclusion reason: Background. [pmid: 19024286].
105 Scale measures quality of hospital discharge process. Healthcare Benchmarks Qual Improv. Jul. 2009;16(7):80-1. Exclusion reason: Wrong topic. [pmid: 19548611].
106 On the Regulatory Radar Screen. AHA News. 2009;45(1):8. Exclusion reason: No outcome data.
107 Data Exchange/lnteroperability. Health Management Technology. 2009;30(2):6. Exclusion reason: Background. [pmid: 19580040].
108 Use patient satisfaction data to zero in on areas for improvement. Hosp Case Manag. Nov. 2010;18(11):161-4. Exclusion reason: No outcome data. [pmid: 21053693].
109 Focus on publicly reported data enhances the case manager’s role. Hosp Case Manag. Aug. 2010;18(8):113-6. Exclusion reason: No outcome data. [pmid: 20672735].
110 MGMA addresses accuracy concerns with Medicare Physician Compare Web site. MGMA Connex. Mar. 2011;11(3):12. Exclusion reason: No outcome data. [pmid: 21473427].
111 Patient Access Benchmarks. Receivables Report for America’s Health Care Financial Managers. 2011;26(5):5-6. Exclusion reason: Wrong topic.
112 Role of State and Hospital Leadership in CMS Process Management: Effects on Art and Science of Care. Academy of Management Annual Meeting Proceedings. 2011:1-6. Exclusion reason: PR as outcome.
113 Abernethy AP, Bull J. Palliative Care Quality Monitoring (404) (Advanced). J Pain Symptom Manage. 2011;41(1):221. Exclusion reason: Wrong topic.
114 Adab P, Rouse AM, Mohammed MA, et al. Performance league tables: the NHS deserves better. BMJ. Jan. 12. 2002;324(7329):95-8. Exclusion reason: No outcome data. [pmid: 11786455].
115 Adams JL. The reliability of provider profiling: a tutorial. Santa Monica, CA. RAND. 2009. Exclusion reason: Methods.
116 Ahmad F, Hudak PL, Bercovitz K, et al. Are physicians ready for patients with Internet-based health information?. J Med Internet Res. 2006;8(3):e22. Exclusion reason: Wrong topic. [pmid: 17032638].
117 Ahmed F, Elbasha EE, Thompson BL, et al. Cost-benefit analysis of a new HEDIS performance measure for pneumococcal vaccination. Med Decis Making. Sep–Oct. 2002;22(5 Suppl):S58-66. Exclusion reason: Methods. [pmid: 12369232].
118 al Awa B, el Hati T, Jacquery A, et al. Comparison of patient safety and quality of care indicators between pre and post accreditation periods in King Abdulaziz University Hospital. Res J Med Sci Research Journal of Medical Sciences. 2011;5(1):61-6. Exclusion reason: Wrong topic.
119 al-Doghaither AH, Abdelrhman BM, Saeed AA, et al. Factors influencing patient choice of hospitals in Riyadh, Saudi Arabia. J R Soc Promot Health. Jun. 2003;123(2):105-9. Exclusion reason: Wrong topic. [pmid: 12852195].
120 Alexander JA, Hearld LR. What can we learn from quality improvement research? A critical review of research methods. Med Care Res Rev. Jun. 2009;66(3):235-71. Exclusion reason: Background. [pmid: 19176833].
121 Alexander JA, Hearld LR, Hasnain-Wynia R, et al. Consumer trust in sources of physician quality information. Med Care Res Rev. Aug. 2011;68(4):421-40. Exclusion reason: Wrong topic. [pmid: 21536600].
122 Ali AM. The personalisation of the British National Health Service: empowering patients or exacerbating inequality?. Int J Clin Pract. Oct. 2009;63(10):1416-8. Exclusion reason: Background. [pmid: 19674162].
123 Allen H. The Central Iowa project. J Ambu Care Mangmt. 1994;17(4):29-56. Exclusion reason: Methods.
124 Allen HM Jr, Rogers WH. Consumer surveys of health plan performance: a comparison of content and approach and a look to the future. Jt Comm J Qual Improv. Dec. 1996;22(12):775-94. Exclusion reason: Background. [pmid: 8986560].
125 Allen KG. United States. Government Accountability O. Nursing homes: despite increased oversight, challenges remain in ensuring high-quality care and resident safety. Washington, D.C. United States Government Accountability Office. 2005. Exclusion reason: Background.
126 Allen P, Hommel PR. What are ‘third way’ governments learning? Health care consumers and quality in England and Germany. Health Policy. Apr. 2006;76(2):202-12. Exclusion reason: Background. [pmid: 16024132].
127 Alphin J. Commentary on Are health plans making the grade?. [Original article by Harris N appears in BUS HEALTH 1994;12(6):22–8]. AONE’s Leadership Prospectives. Jan–Feb. 1995;3(1):22. Exclusion reason: No outcome data.
128 Alteras TT. Health plan report cards may influence insurers more than consumers: their effect on insurer behavior in Minnesota. Find Brief. Apr. 2000;3(3):1-2. Exclusion reason: No outcome data. [pmid: 12138921].
129 Amin AN, Deitelzweig SB. Optimizing the prevention of venous thromboembolism: recent quality initiatives and strategies to drive improvement. Jt Comm J Qual Patient Saf. Nov. 2009;35(11):558-64. Exclusion reason: Wrong topic. [pmid: 19947332].
130 Anderson B. HEDIS antidepressant medication management measures and performance-based measures: an opportunity for improvement in depression care. Am J Manag Care. Nov. 2007;13(4 Suppl):S98-102. Exclusion reason: No outcome data. [pmid: 18041869].
131 Anderson GM. Measurement of the outcome of learning: health care performance measurement and continuing medical education. J Contin Educ Health Prof. 1999;19(4):222-6. Exclusion reason: Wrong topic.
132 Andrews A, Valente A. Accelerating Best Care in Pennsylvania: the Hazleton General Hospital experience. Am J Med Qual. Jul–Aug. 2008;23(4):259-65. Exclusion reason: Wrong topic. [pmid: 18658098].
133 Andrews JE, Pearce KA, Ireson C, et al. Information-seeking behaviors of practitioners in a primary care practice-based research network (PBRN). J Med Libr Assoc. Apr. 2005;93(2):206-12. Exclusion reason: Wrong topic. [pmid: 15858623].
134 Andrews WC, Morrow TJ. HEDIS measure for the management of menopause. Am J Manag Care. Sep. 2000;6(14 Suppl):S742-5. Exclusion reason: Wrong topic. [pmid: 11184071].
135 Angelelli J, Grabowski DC, Mor V. Effect of educational level and minority status on nursing home choice after hospital discharge. Am J Public Health. Jul. 2006;96(7):1249-53. Exclusion reason: Wrong topic. [pmid: 16735621].
136 Antonacci AC, Lam S, Lavarias V, et al. A surgeon report card system developed using a standardized classification of adverse outcomes, error profile analysis and concurrent morbidity and mortality review: A three-year experience. J Surg Res. 2007;137(2):186-7. Exclusion reason: Wrong topic.
137 Applebaum R, Kunkel S, Wilson K. Transforming data into practical information: using consumer input to improve home-care services. Gerontologist. Feb. 2007;47(1):116-22. Exclusion reason: Wrong topic. [pmid: 17327547].
138 Appleby C. Report cards. Giving consumers the scoop on quality and cost. Hosp Health Netw. Dec. 20. 1995;69(24):84. Exclusion reason: No outcome data. [pmid: 8541911].
139 Appleby C. HEDIS (Health Plan Employer Data and Information Set): managed care’s emerging gold standard. Manag Care. Feb. 1995;4(2):19-24. Exclusion reason: No outcome data. [pmid: 10142046].
140 Arias KM. Mandatory reporting and pay for performance: health care infections in the limelight. AORN J. Apr. 2008;87(4):750-8. Exclusion reason: No outcome data. [pmid: 18395020].
141 Arora NK. Importance of patient-centered care in enhancing patient well-being: a cancer survivor’s perspective. Qual Life Res. Feb. 2009;18(1):1-4. Exclusion reason: Background. [pmid: 19005778].
142 Asplund J. Private-public partners revamp health plan survey for 1999. AHA News. 1998;34(36):4. Exclusion reason: No outcome data. [pmid: 1100050].
143 Aston G. HMOs with Medicare contracts to begin HEDIS. AHA News. 1996;32(37):3. Exclusion reason: No outcome data.
144 Aston G. Survey to measure how well HMOs care for patients. AHA News. 1996;32(29):3. Exclusion reason: No outcome data.
145 Atherly A, Dowd BE, Feldman R. The effect of benefits, premiums, and health risk on health plan choice in the Medicare program. Health Serv Res. Aug. 2004;39(4 Pt 1):847-64. Exclusion reason: Wrong topic. [pmid: 15230931].
146 Austin K. AHA seeking feedback on CMS’ patient care survey. AHA News. 2003;39(25):15. Exclusion reason: No outcome data. [pmid: 11795713].
147 Averill RF. Public dissemination of provider performance comparisons in the United States. Hosp Q. Spring. 1998;1(3):39-41. Exclusion reason: No outcome data. [pmid: 10345578].
148 Averill RF, Goldfield NI, Vertrees JC, et al. Achieving cost control, care coordination, and quality improvement through incremental payment system reform. J Ambul Care Manage. Jan–Mar. 2010;33(1):2-23. Exclusion reason: Background. [pmid: 20026992].
149 Aviles A. Transparency in practice. Why we chose to give public all of our quality data. Mod Healthc. Dec. 10. 2007;37(49):24. Exclusion reason: No outcome data. [pmid: 18203362].
150 Aydin CE, Bolton LB, Donaldson N, et al. Creating and analyzing a statewide nursing quality measurement database. J Nurs Scholarsh. 2004;36(4):371-8. Exclusion reason: Wrong topic. [pmid: 15636419].
151 Aylin P. Hospital and clinician performance data: What it can and cannot tell us Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press, US. 2007:226-42. Exclusion reason: Background.
152 Bach PB, Pham HH, Schrag D, et al. Primary care physicians who treat blacks and whites. N Engl J Med. 2004;351(6):575-84. Exclusion reason: Wrong topic. [pmid: 15295050].
153 Baier RR, Butterfield K, Harris Y, et al. Aiming for star performance: the relationship between setting targets and improved nursing home quality of care. J Am Med Dir Assoc. Oct. 2008;9(8):594-8. Exclusion reason: PR as outcome. [pmid: 19083294].
154 Bailey JE, Gibson D. Public reporting needed to improve the health of Tennesseans. Tenn Med. Nov. 2005;98(11):539-40. 45. Exclusion reason: No outcome data. [pmid: 16375088].
155 Baker LC, Hopkins D, Dixon R, et al. Do health plans influence quality of care?. Int J Qual Health Care. Feb. 2004;16(1):19-30. Exclusion reason: Background. [pmid: 15020557].
156 Baker LC, Hopkins DS. The contribution of health plans and provider organizations to variations in measured plan quality. Int J Qual Health Care. Jun. 2010;22(3):210-8. Exclusion reason: Methods. [pmid: 20299493].
157 Baker N. Medicare PROs and the assessment of quality: should physician-specific quality data be released to consumers?. J Health Hosp Law. Apr. 1992;25(4):97-109. 17. Exclusion reason: No outcome data. [pmid: 10123435].
158 Baker NA, Otten RD. Principles for the release of physician-specific health care data: balancing the interests of patients and physicians. Med Staff Couns. Summer. 1993;7(3):27-34. Exclusion reason: No outcome data. [pmid: 10126798].
159 Baldwin G. Report cards miss the mark. Health Data Manag. Jan. 2000;8(1):60-3. Exclusion reason: Background. [pmid: 11183083].
160 Ballard DJ, Ogola G, Fleming NS, et al. Impact of a standardized heart failure order set on mortality, readmission, and quality and costs of care. Int J Qual Health Care. Dec. 2010;22(6):437-44. Exclusion reason: PR as outcome. [pmid: 20935009].
161 Balmer C. The information requirements of people with cancer: where to go after the “patient information leaflet”?. Cancer Nurs. Jan–Feb. 2005;28(1):36-44. quiz 5–6. Exclusion reason: Wrong topic. [pmid: 15681980].
162 Barber SL. Public and private prenatal care providers in urban Mexico: how does their quality compare?. Int J Qual Health Care. Aug. 2006;18(4):306-13. Exclusion reason: Wrong topic. [pmid: 16675474].
163 Bardach NS, Chien AT, Dudley RA. Small numbers limit the use of the inpatient pediatric quality indicators for hospital comparison. Acad Pediatr. Jul–Aug. 2010;10(4):266-73. Exclusion reason: Background. [pmid: 20599180].
164 Barigozzi F, Levaggi R. Emotions in physician agency. Health Policy. Oct. 2008;88(1):1-14. Exclusion reason: Background. [pmid: 18439704].
165 Barkauskas VH, Pohl JM, Benkert R, et al. Measuring quality in nurse-managed centers using HEDIS measures. J Healthc Qual. Jan–Feb. 2005;27(1):4-14. Exclusion reason: Wrong topic. [pmid: 16416887].
166 Barnighausen T, Bloom DE. Financial incentives for return of service in underserved areas: a systematic review. BMC Health Serv Res. 2009;9:86. Exclusion reason: Wrong topic. [pmid: 19480656].
167 Barr JK, Boni CE, Kochurka KA, et al. Public reporting of hospital patient satisfaction: the Rhode Island experience. Health Care Financ Rev. Summer. 2002;23(4):51-70. Exclusion reason: Methods. [pmid: 12500470].
168 Barr JK. Physicians as Intermediaries for HCAHPS Public Reports. American Public Health Association. 2006. 800 I Street, NW Washington, DC 20001-3710. Exclusion reason: Unable to obtain.
169 Bartlett J, Kaufmann C, Manderscheid R, et al. Making the grade: update on report card initiatives for 1997. Behav Healthc Tomorrow. Apr. 1997;6(2):55-62. Exclusion reason: No outcome data. [pmid: 10166631].
170 Baumgarten A. Performance measurement: a good idea in theory. Minn Med. Jan. 1998;81(1):6-7. Exclusion reason: No outcome data. [pmid: 9465577].
171 Beatty PW, Neri MT, Bell K, et al. Use of outcomes information in acute inpatient rehabilitation. Am J Phys Med Rehabil. Jun. 2004;83(6):468-78. Exclusion reason: PR as outcome. [pmid: 15166693].
172 Beck CA, Richard H, Tu JV, et al. Administrative Data Feedback for Effective Cardiac Treatment: AFFECT, a cluster randomized trial. JAMA. Jul. 20. 2005;294(3):309-17. Exclusion reason: Wrong topic. [pmid: 16030275].
173 Becker C. Consumers are king. From IT projects to quality initiatives to improved transparency, in ‘07 it’s all about making the healthcare experience better, safer. Mod Healthc. Jan. 1. 2007;37(1):24-8. Exclusion reason: No outcome data. [pmid: 17228543].
174 Beckman HB, Mahoney T, Greene RA, et al. Current approaches to improving the value of care: a physician’s perspective. New York, NY. Commonwealth Fund. 2007. Exclusion reason: No outcome data.
175 Belicza E, Takacs E. The objective assessment of the quality of hospital care: dream or reality?. Orv Hetil. Oct. 28. 2007;148(43):2033-41. Exclusion reason: No outcome data. [pmid: 17947196].
176 Bell D, Brandt EN Jr. Accreditation by the National Committee on Quality Assurance (NCQA): a description. J Okla State Med Assoc. May. 1999;92(5):234-7. Exclusion reason: Background. [pmid: 10432784].
177 Bell NN. HEDIS (Health Employer Data and Information Set): are we finally comparing apples to apples?. Med Interface. Apr. 1994;7(4):74-6. 81. 2. Exclusion reason: Background. [pmid: 10133361].
178 Benkert R, George N, Tanner C, et al. Satisfaction with a school-based teen health center: a report card on care. Pediatr Nurs. Mar–Apr. 2007;33(2):103-9. Exclusion reason: Wrong topic. [pmid: 17542231].
179 Benko LB. Poor performance. Insurance group’s ratings system angers providers. Mod Healthc. Apr. 4. 2005;35(14):10-1. Exclusion reason: No outcome data. [pmid: 15825948].
180 Berenbeim DM. Workshops: recommendations and plans of action for meeting the HEDIS 2000 management of menopause measure. Am J Manag Care. Sep. 2000;6(14 Suppl):S761-4. Exclusion reason: Background. [pmid: 11184073].
181 Berendsen AJ, de Jong GM, Schuling J, et al. Patient’s need for choice and information across the interface between primary and secondary care: a survey. Patient Educ Couns. Apr. 2010;79(1):100-5. Exclusion reason: Wrong topic. [pmid: 19713065].
182 Berenson RA, Cassel CK. Consumer-driven health care may not be what patients need--caveat emptor. JAMA. Jan. 21. 2009;301(3):321-3. Exclusion reason: Background. [pmid: 19155460].
183 Berg M, Meijerink Y, Gras M, et al. Feasibility first: developing public performance indicators on patient safety and clinical effectiveness for Dutch hospitals. Health Policy. Dec. 2005;75(1):59-73. Exclusion reason: Methods. [pmid: 16298229].
184 Berger E. Consumers and hospital report cards: first efforts at definition. Hosp Q. Spring. 1999;2(3):40-6. Exclusion reason: Wrong topic. [pmid: 10538705].
185 Bergman R. Making the grade. Report cards will be used to measure the performance of health plans: how might they work?. Hosp Health Netw. Jan. 5. 1994;68(1):34-6. Exclusion reason: No outcome data. [pmid: 8269004].
186 Berlowitz DR, Rosen AK, Wang F, et al. Purchasing or providing nursing home care: can quality of care data provide guidance. J Am Geriatr Soc. Apr. 2005;53(4):603-8. Exclusion reason: Wrong topic. [pmid: 15817005].
187 Bernard SL. Physicians’ views on hospital quality reporting and consumer use of quality data: Findings from a national survey of physicians. American Public Health Association. 2006. 4–8. Nov. New Boston Convention and Exhibition Center. Boston, Massachusetts. Exclusion reason: Unable to obtain.
188 Berry K. Legislative forum: Maryland HEDIS report card project. J Healthc Qual. Sep–Oct. 1995;17(5):32. Exclusion reason: No outcome data. [pmid: 10144986].
189 Bevan G. Is choice working for patients in the English NHS?. BMJ. 2008;337:a935. Exclusion reason: No outcome data. [pmid: 18689434].
190 Beveridge RN. Creating value-focused healthcare delivery systems: Part three--Core competencies. J Oncol Manag. Nov–Dec. 1997;6(6):16-23. Exclusion reason: Wrong topic. [pmid: 10174597].
191 Bilimoria KY, Bentrem DJ, Stewart AK, et al. Lymph node evaluation as a colon cancer quality measure: a national hospital report card. J Natl Cancer Inst. Sep. 17. 2008;100(18):1310-7. Exclusion reason: PR as outcome. [pmid: 18780863].
192 Bilimoria KY, Cohen ME, Merkow RP, et al. Comparison of outlier identification methods in hospital surgical quality improvement programs. J Gastrointest Surg. Oct. 2010;14(10):1600-7. Exclusion reason: Methods. [pmid: 20824379].
193 Bindman AB, Wholey DR, Christianson JB. Physicians’ reports of their experience with health plan care management practices. Am J Manag Care. Jun. 2003;9(Spec No 2):SP100-10. Exclusion reason: Wrong topic. [pmid: 12822719].
194 Birch S. DRGs U.K. style: a comparison of U.K. and U.S. policies for hospital cost containment and their implications for health status. Health Policy. Oct. 1988;10(2):143-54. Exclusion reason: Wrong topic. [pmid: 10312718].
195 Bird CE, Fremont A, Wickstrom S, et al. Improving women’s quality of care for cardiovascular disease and diabetes: the feasibility and desirability of stratified reporting of objective performance measures. Womens Health Issues. Jul–Aug. 2003;13(4):150-7. Exclusion reason: Methods. [pmid: 13678806].
196 Birkmeyer NJ, Birkmeyer JD. Strategies for improving surgical quality--should payers reward excellence or effort?. N Engl J Med. Feb. 23. 2006;354(8):864-70. Exclusion reason: No outcome data. [pmid: 16495401].
197 Birkmeyer NJ, Share D, Campbell DA Jr, et al. Partnering with payers to improve surgical quality: the Michigan plan. Surgery. Nov. 2005;138(5):815-20. Exclusion reason: Wrong topic. [pmid: 16291379].
198 Biro LA, Moreland ME, Cowgill DE. Achieving excellence in veterans healthcare--a balanced scorecard approach. J Healthc Qual. May–Jun. 2003;25(3):33-9. Exclusion reason: Wrong topic. [pmid: 12774646].
199 Birtcher KK, Pan W, Labresh KA, et al. Performance achievement award program for Get With The Guidelines--Coronary Artery Disease is associated with global and sustained improvement in cardiac care for patients hospitalized with an acute myocardial infarction. Crit Pathw Cardiol. Sep. 2010;9(3):103-12. Exclusion reason: Wrong topic. [pmid: 20802262].
200 Bisaha J. View finder. With Hospital Consumer Assessment of Health Care Provider and Systems data, hospitals can understand care from the patient’s perspective. Mark Health Serv. Fall. 2007;27(3):21-5. Exclusion reason: No outcome data. [pmid: 17896638].
201 Bittle LJ, Bloomrosen M. QA, RM and UM functions require coordinated information management. J Qual Assur. Feb–Mar. 1990;12(1):14-9. 42. Exclusion reason: Wrong topic. [pmid: 10106367].
202 Black AD, Car J, Pagliari C, et al. The impact of eHealth on the quality and safety of health care: a systematic overview. PLoS Med. 2011;8(1). Exclusion reason: Background. [pmid: 21267058].
203 Blackwell B, Eilers K, Robinson D Jr. The consumer’s role in assessing quality Handbook of quality management in behavioral health. Dordrecht, Netherlands. Kluwer Academic Publishers; Netherlands. 2000:375-86. Exclusion reason: Background.
204 Boerner CM. Aging Population Means More Focus on Nursing Home Compliance Programs. J Health Care Compliance. 2008;10(5):33-4. Exclusion reason: Wrong topic.
205 Bolsin S, Freestone L. Report cards and performance monitoring Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:91-105. Exclusion reason: Background.
206 Bombard C. HCAHPS is all about patient satisfaction. Nursing Spectrum -- DC, Maryland &. Virginia Edition. 2009;19(9):18-23. Exclusion reason: No outcome data.
207 Bonow RO, Masoudi FA, Rumsfeld JS, et al. ACC/AHA classification of care metrics: performance measures and quality metrics: a report of the American College of Cardiology/American Heart Association Task Force on Performance Measures. J Am Coll Cardiol. Dec. 9. 2008;52(24):2113-7. Exclusion reason: Wrong topic. [pmid: 19056002].
208 Bonvissuto K. Competing plans now measured by efficient use of resources. Managed Healthcare Executive. 2011;21(2):30-1. Exclusion reason: No outcome data.
209 Boratgis G, Broderick S, Callahan M, et al. Disseminating QI interventions. Jt Comm J Qual Patient Saf. Dec. 2007;33(12 Suppl):48-65. Exclusion reason: Background. [pmid: 18277639].
210 Borenstein J, Badamgarav E, Henning JM, et al. The association between quality improvement activities performed by managed care organizations and quality of care. Am J Med. Sep. 1. 2004;117(5):297-304. Exclusion reason: PR as outcome. [pmid: 15336578].
211 Borfitz D. Are you ready for the new grading system?. Med Econ. Aug. 21. 1995;72(16):151-2. 7. 8. 60 passim. Exclusion reason: No outcome data. [pmid: 10151326].
212 Borland M, Smith C, Nankivil N. A community quality initiative for health care reform. Manag Care Q. Winter. 1994;2(1):6-16. Exclusion reason: Background. [pmid: 10132794].
213 Boscarino JA, Adams RE. Public perceptions of quality care and provider profiling in New York: implications for improving quality care and public health. J Public Health Manag Pract. May–Jun. 2004;10(3):241-50. Exclusion reason: Wrong topic. [pmid: 15253520].
214 Boulding W, Glickman SW, Manary MP, et al. Relationship between patient satisfaction with inpatient care and hospital readmission within 30 days. Am J Manag Care. Jan. 2011;17(1):41-8. Exclusion reason: Wrong topic. [pmid: 21348567].
215 Bradley EH, Rizzo JA. Public information and private search: evaluating the Patient Self-Determination Act. J Health Polit Policy Law. Apr. 1999;24(2):239-73. Exclusion reason: Wrong topic. [pmid: 10321357].
216 Brakeman L. Online database serves Medicare managed care. Managed Healthcare. 1998;8(6):55. Exclusion reason: Background.
217 Brann P, Walter G, Coombs T. Benchmarking child and adolescent mental health organizations. Australas Psychiatry. Apr. 2011;19(2):125-32. Exclusion reason: Wrong topic. [pmid: 21348781].
218 Bratzler DW. The Surgical Infection Prevention and Surgical Care Improvement Projects: promises and pitfalls. Am Surg. Nov. 2006;72(11):1010-6. discussion 21–30, 133–48. Exclusion reason: Wrong topic. [pmid: 17120942].
219 Bratzler DW. Development of national performance measures on the prevention and treatment of venous thromboembolism. J Thromb Thrombolysis. Feb. 2010;29(2):148-54. Exclusion reason: Wrong topic. [pmid: 19915995].
220 Bratzler DW, Hunt DR. The surgical infection prevention and surgical care improvement projects: national initiatives to improve outcomes for patients having surgery. Clin Infect Dis. Aug. 1. 2006;43(3):322-30. Exclusion reason: Wrong topic. [pmid: 16804848].
221 Bratzler DW, Nsa W, Houck PM. Performance measures for pneumonia: are they valuable, and are process measures adequate?. Curr Opin Infect Dis. Apr. 2007;20(2):182-9. Exclusion reason: Wrong topic. [pmid: 17496578].
222 Brennan TA, Horwitz RI, Duffy FD, et al. The role of physician specialty board certification status in the quality movement. JAMA. Sep. 1. 2004;292(9):1038-43. Exclusion reason: Wrong topic. [pmid: 15339894].
223 Brien SE, Lorenzetti DL, Lewis S, et al. Overview of a formal scoping review on health system report cards. Implement Sci. 2010;5:2. Exclusion reason: Background. [pmid: 20205791].
224 Briggs B. HMOs are drilling for HEDIS data. Health Data Manag. Nov. 2000;8(11):54-6. 60. 3. Exclusion reason: No outcome data. [pmid: 11188261].
225 Brindis R, Krumholz HM. President’s page: national quality initiatives put ACC’s mission into action. J Am Coll Cardiol. Oct. 5. 2010;56(15):1260-2. Exclusion reason: Wrong topic. [pmid: 20883935].
226 Brindle CT. Outliers to the Braden Scale: identifying high-risk ICU patients and the results of prophylactic dressing use. World Council of Enterostomal Therapists Journal. Jan–Mar. 2010;30(1):11-8. Exclusion reason: Wrong topic.
227 Brockenbrough G. More patients and organizations are looking at physician quality ratings. Ocular Surgery News. 2008;26(21):106. Exclusion reason: No outcome data.
228 Broder MS, Ory C, Yermilov I, et al. Does improving quality of care save money? Analysis of health care effectiveness data and information set (hedis) measures. Value in Health. 2009;12(3):A88. Exclusion reason: Wrong topic.
229 Broder MS, Payne-Simon L, Brook RH. Measures of surgical quality: what will patients know by 2005?. J Eval Clin Pract. Jun. 2005;11(3):209-17. Exclusion reason: Background. [pmid: 15869551].
230 Brody BA. HCFA data release--government abuse or patient right?. Hosp Physician. Jun. 1986;22(6):36-7. 40. Exclusion reason: No outcome data. [pmid: 10277538].
231 Brook EL, Rosman DL, Holman CD. Public good through data linkage: measuring research outputs from the Western Australian Data Linkage System. Aust N Z J Public Health. Feb. 2008;32(1):19-23. Exclusion reason: Wrong topic. [pmid: 18290908].
232 Brown DS. Public reporting works…shining a light on cardiac surgery results. AHA News. 2008;44(20):5. Exclusion reason: No outcome data.
233 Brown GJ. Public Access to Nursing Home Survey and Certification Results. . Dept of Health & Human Services: Office of Inspector General (OIG). 1999. Mar. Report : OEI-06-98-00280. Exclusion reason: Wrong topic.
234 Brown JA, Nederend SE, Hays RD, et al. Special issues in assessing care of Medicaid recipients. Med Care. Mar. 1999;37(3 Suppl):MS79-88. Exclusion reason: Methods. [pmid: 10098562].
235 Browne K, Roseman D, Shaller D, et al. Analysis & commentary. Measuring patient experience as a strategy for improving primary care. Health Aff (Millwood). May. 2010;29(5):921-5. Exclusion reason: No outcome data. [pmid: 20439881].
236 Brunnekreef JJ, Schreurs BW. Total hip arthroplasty: what information do we offer patients on websites of hospitals?. BMC Health Serv Res. 2011;11:83. Exclusion reason: Wrong topic. [pmid: 21504581].
237 Buechner JS, Dexter MK. Public reporting of cardiac procedure outcomes. American Public Health Association. 1999. 7–11. Nov. Chicago, IL. Exclusion reason: No outcome data.
238 Bukunt S, Hunter C, Perkins S, et al. El Camino Hospital: using health information technology to promote patient safety. Jt Comm J Qual Patient Saf. Oct. 2005;31(10):561-5. Exclusion reason: Wrong topic. [pmid: 16294668].
239 Bundorf MK. Employee demand for health insurance and employer health plan choices. J Health Econ. Jan. 2002;21(1):65-88. Exclusion reason: Wrong topic. [pmid: 11845926].
240 Buppert C. Ten practical pointers for tracking HEDIS data. Manag Care. Sep. 5. 1997;6(9):90-8. Exclusion reason: No outcome data. [pmid: 10173831].
241 Buppert C. HEDIS for the primary care provider: getting an “A” on the managed care report card. Nurse Pract. Jan. 1999;24(1):84-6. 8. 9. 92. 4. passim. Exclusion reason: Background. [pmid: 9950000].
242 Burger I, Schill K, Goodman S. Disclosure of individual surgeon’s performance rates during informed consent: ethical and epistemological considerations. Ann Surg. Apr. 2007;245(4):507-13. Exclusion reason: Wrong topic. [pmid: 17414595].
243 Burke J. Bridging the consumer information gap. The State of Health Care in America. 1997:44-7. Exclusion reason: No outcome data. [pmid: 10168086].
244 Burstein GR, Snyder MH, Conley D, et al. Chlamydia screening in a Health Plan before and after a national performance measure introduction. Obstet Gynecol. Aug. 2005;106(2):327-34. Exclusion reason: Wrong topic. [pmid: 16055583].
245 Busse R, Nimptsch U, Mansky T. Measuring, monitoring, and managing quality in Germany’s hospitals. Health Aff (Millwood). Mar–Apr. 2009;28(2):w294-304. Exclusion reason: Methods. [pmid: 19174391].
246 Cabral KP. How to meet national quality initiatives: best practices. J Thromb Thrombolysis. Feb. 2010;29(2):155-8. Exclusion reason: Wrong topic. [pmid: 19908125].
247 Caldwell B. Employers use performance data to steer employees to better-performing plans. Employee Benefit Plan Review. 1998;52(8):14. Exclusion reason: No outcome data.
248 Calnan M, Rowe R. Trust, accountability and choice. Health, Risk & Society. 2008. 06. 01. 2008;10(3):201-6. Exclusion reason: No outcome data.
249 Campbell J, Einspahr K. Building partnerships in accountability: Consumer satisfaction. Improving Mental Health Care: Commitment to Quality. Arlington, VA, US. American Psychiatric Publishing, Inc. 2001:101-13. Exclusion reason: Wrong topic.
250 Campbell RJ, Nolfi DA. Teaching elderly adults to use the Internet to access health care information: before-after study. J Med Internet Res. 2005;7(2):e19. Exclusion reason: Wrong topic. [pmid: 15998610].
251 Campbell SM, Roland MO, Buetow SA. Defining quality of care. Social Science & Medicine. 2000;51(11):1611-25. Exclusion reason: Background. [pmid: 11072882].
252 Capo KM, Rutledge DR. Applying managed care performance measures in community pharmacy-based outcomes research. J Am Pharm Assoc (Wash). May–Jun. 1999;39(3):388-94. quiz 423–4. Exclusion reason: Wrong topic. [pmid: 10363467].
253 Capponi L, Waldron J, Mackle K. Building and deploying a patient registry to measure and improve patient care. J. Inf. Technol. Healthc. Journal on Information Technology in Healthcare. 2008;6(1):55-62. Exclusion reason: Wrong topic.
254 Carey RG. Measuring quality: report cards get low grades. QRC Advis. Oct. 1995;11(12):4-5. Exclusion reason: No outcome data. [pmid: 10151510].
255 Carlisle RT. Internet report cards on quality: what exists and the evidence on impact. W V Med J. Jul–Oct. 2007;103(4):17-21. Exclusion reason: No outcome data. [pmid: 18159839].
256 Carman JM. Patient perceptions of service quality. Combining the dimensions. J Manag Med. 2000;14(5–6):339-56. Exclusion reason: Wrong topic. [pmid: 11200300].
257 Carman KL. Ensuring Positive Physician Patient Communication about Hospital Quality Information. American Public Health Association. 2006 4–8 Nov. Boston, Massachusetts (USA). 134th Annual Meeting. Exclusion reason: Unable to obtain.
258 Carman KL, Short PF, Farley DO, et al. Epilogue: Early lessons from CAHPS Demonstrations and Evaluations. Consumer Assessment of Health Plans Study. Med Care. Mar. 1999;37(3 Suppl):MS97-105. Exclusion reason: Methods. [pmid: 10098564].
259 Carpenter D. Attention investors. The Q-revolution is spreading. Trustee. Jun. 2006;59(6):22-6. 1. Exclusion reason: Background. [pmid: 16802669].
260 Carpinello S, Felton CJ, Pease EA, et al. Designing a system for managing the performance of mental health managed care: an example from New York State’s prepaid mental health plan. J Behav Health Serv Res. Aug. 1998;25(3):269-78. Exclusion reason: Background. [pmid: 9685746].
261 Carter MW, Porell FW. Nursing home performance on select publicly reported quality indicators and resident risk of hospitalization: grappling with policy implications. J Aging Soc Policy. 2006;18(1):17-39. Exclusion reason: Methods. [pmid: 16635979].
262 Casey DE Jr. Performance measurement 2.0: time to raise the bar. Am J Med Qual. Jul–Aug. 2010;25(4):246-8. Exclusion reason: No outcome data. [pmid: 20606208].
263 Casey M, Klingner J. HMOs serving rural areas: experiences with HMO accreditation and HEDIS reporting. Manag Care Q. Spring. 2000;8(2):48-59. Exclusion reason: Wrong topic. [pmid: 11010391].
264 Casparie AF, Sluijs EM, Wagner C, et al. Quality systems in Dutch health care institutions. Health Policy. Dec. 1997;42(3):255-67. Exclusion reason: Wrong topic. [pmid: 10176304].
265 Cassell D. JCAHO Web tool offers clues to best in health care. Drug Topics. 2004;148(16):HSE9-HSE. Exclusion reason: No outcome data.
266 Castle NG, Anderson RA. Caregiver staffing in nursing homes and their influence on quality of care: using dynamic panel estimation methods. Med Care. Jun. 2011;49(6):545-52. Exclusion reason: Wrong topic. [pmid: 21577182].
267 Castle NG, Engberg J. An examination of special focus facility nursing homes. Gerontologist. Jun. 2010;50(3):400-7. Exclusion reason: Methods. [pmid: 20154306].
268 Castle NG, Ferguson JC. What is nursing home quality and how is it measured?. Gerontologist. Aug. 2010;50(4):426-42. Exclusion reason: No outcome data. [pmid: 20631035].
269 Castle NG, Lowe TJ. Report Cards and Nursing Homes. Gerontologist 2005. February. 1. 2005;45(1):48-67. Exclusion reason: No outcome data.
270 Castles AG, Milstein A, Damberg CL. Using employer purchasing power to improve the quality of perinatal care. Pediatrics. Jan. 1999;103(1 Suppl E):248-54. Exclusion reason: No outcome data. [pmid: 9917468].
271 Cawood J, Morrow T. Management of menopause: a new HEDIS measure and an opportunity for health plans. Manag Care Interface. Aug. 2000;13(8):65-9. Exclusion reason: Wrong topic. [pmid: 11185178].
272 Center for Healthcare Industry Performance S. The 2000 performance review: a guide to U.S. hospitals. [Salt Lake City, Utah]. Ingenix. 2000. Exclusion reason: No outcome data.
273 Centre for R, Dissemination. Using quality indicators to improve hospital care: a review of the literature (Structured abstract). Exclusion reason: Wrong topic.
274 Centre for R, Dissemination. A systematic review and meta-analysis of studies comparing readmission rates and mortality rates in patients with heart failure (Structured abstract). Database of Abstracts of Reviews of Effects. 2012;1:1. Exclusion reason: Wrong topic.
275 Centre for R, Dissemination. Practice parameter: early detection of dementia Mild cognitive impairment (an evidence-based review): report of the Quality Standards Subcommittee of the American Academy of Neurology (Structured abstract). Database of Abstracts of Reviews of Effects. 2012;1:1. Exclusion reason: Wrong topic.
276 Centre for R, Dissemination. A meta-analysis on data from 575 patients with multiple myeloma randomly assigned to either high-dose therapy or conventional therapy (Provisional abstract). Database of Abstracts of Reviews of Effects. 2012;1:1. Exclusion reason: Wrong topic.
277 Centre for R, Dissemination. Measuring and reporting quality of life outcomes in clinical trials in cystic fibrosis: a critical review (Structured abstract). Database of Abstracts of Reviews of Effects. 2012;1:1. Exclusion reason: Wrong topic.
278 Centre for R, Dissemination. The impact of measuring patient-reported outcomes in clinical practice: a systematic review of the literature (Structured abstract). Database of Abstracts of Reviews of Effects. 2012;1:1. Exclusion reason: Wrong topic.
279 Centre for R, Dissemination. The effectiveness of the use of patient-based measures of health in routine practice in improving the process and outcomes of patient care: a literature review (Structured abstract). Database of Abstracts of Reviews of Effects. 2012;1:1. Exclusion reason: Wrong topic.
280 Centre for R, Dissemination. Effectiveness of self-management interventions on mortality, hospital readmissions, chronic heart failure hospitalization rate and quality of life in patients with chronic heart failure: a systematic review (Structured abstract). Database of Abstracts of Reviews of Effects. 2012;1:1. Exclusion reason: Wrong topic.
281 Centre for R, Dissemination. A critical appraisal of the performance, reporting, and interpretation of studies comparing carotid plaque imaging with histology (Provisional abstract). Database of Abstracts of Reviews of Effects. 2012;1:1. Exclusion reason: Wrong topic.
282 Centre for R, Dissemination. Blood cultures for community-acquired pneumonia: are they worthy of two quality measures: a systematic review (Structured abstract). Database of Abstracts of Reviews of Effects. 2012;1:1. Exclusion reason: Wrong topic.
283 Centre for R, Dissemination. Benefits of enriched intervention compared with standard care for patients with recent-onset psychosis: a metaanalytic approach (Provisional abstract). Database of Abstracts of Reviews of Effects. 2012;1:1. Exclusion reason: Wrong topic.
284 Centre for R, Dissemination. Knowledge retention from pre-operative patient information (Structured abstract). Database of Abstracts of Reviews of Effects. 2012;1:1. Exclusion reason: Wrong topic.
285 Centre for R, Dissemination. Systematic review: the evidence that publishing patient care performance data improves quality of care (Structured abstract). Database of Abstracts of Reviews of Effects. 2012;1:1. Exclusion reason: Background.
286 Cerne F. New performance measures will yield comparative data on HMOs. Hosp Health Netw. Jul. 5. 1993;67(13):48. Exclusion reason: No outcome data. [pmid: 8513374].
287 Chandra A. Potential Influences of the Web on Health Care Patients and Professionals. Health Care on the Internet. 2001;5:59-68. Exclusion reason: Wrong topic.
288 Chang D-S, Yang FC. A New Benchmarking Method to Advance the Two-Model DEA Approach: Evidence from a Nursing Home Application. INFOR: Information Systems and Operational Research. 2010;48(2):83-94. Exclusion reason: Wrong topic.
289 Chang JT, Hays RD, Shekelle PG, et al. Patients’ global ratings of their health care are not associated with the technical quality of their care. Ann Intern Med. May. 2. 2006;144(9):665-72. Exclusion reason: Background. [pmid: 16670136].
290 Chanter C, Ashmore S, Mandair S. Improving the patient experience in general practice with the General Practice Assessment Questionnaire (GPAQ). Quality in Primary Care. 2005;13(4):225-32. Exclusion reason: Methods.
291 Where is our team ranked on the League Table? - A retrospective analysis of PET in Hunter New England Area Health Service. Society of Nuclear Medicine. 2009 Apr 23–27. Sydney Convention and Exhibition Centre, Sydney Australia. 39th Annual Scientific Meeting. Exclusion reason: Wrong topic.
292 Chase D, Heinen L. Performance reporting of health care delivery systems: will it make the grade?. J Ambul Care Manage. Oct. 1994;17(4):15-28. Exclusion reason: No outcome data. [pmid: 10137967].
293 Chassin MR, Hannan EL, DeBuono BA. Benefits and hazards of reporting medical outcomes publicly. N Engl J Med. Feb. 8. 1996;334(6):394-8. Exclusion reason: No outcome data. [pmid: 8538714].
294 Chen J, Radford MJ, Wang Y, et al. Performance of the ‘100 top hospitals’: what does the report card report?. Health Aff (Millwood). Jul–Aug. 1999;18(4):53-68. Exclusion reason: Methods. [pmid: 10425843].
295 Chen Y. Why are health care report cards so bad (good)?. J Health Econ. May. 2011;30(3):575-90. Exclusion reason: Background. [pmid: 21420749].
296 Cheng EM, Cunningham WE, Towfighi A, et al. Randomized, controlled trial of an intervention to enable stroke survivors throughout the Los Angeles County safety net to “stay with the guidelines”. Circ Cardiovasc Qual Outcomes. Mar. 2011;4(2):229-34. Exclusion reason: Wrong topic. [pmid: 21406671].
297 Cheng SH, Ho YC, Chung KP. Hospital quality information for patients in Taiwan: can they understand it?. Int J Qual Health Care. Apr. 2002;14(2):155-60. Exclusion reason: Wrong topic. [pmid: 11954685].
298 Cheraghi-Sohi S, Hole AR, Mead N, et al. What patients want from primary care consultations: a discrete choice experiment to identify patients’ priorities. Ann Fam Med. Mar–Apr. 2008;6(2):107-15. Exclusion reason: Wrong topic. [pmid: 18332402].
299 Chernew M, Gowrisankaran G, Scanlon DP. Learning and the value of information: the case of hospital report cards. J Econom. Exclusion reason: Unable to obtain.
300 Chernew M, Gowrisankaran G, Scanlon PD. Learning and the value of information: Evidence from health plan report cards. J Econom. 2008;144(1):156-74. Exclusion reason: Methods.
301 Chesanow N. Managed care 1999. Your report card is about to go public. Med Econ. Apr. 12. 1999;76(7):220-2. 4. 6. 35. Exclusion reason: No outcome data. [pmid: 10351793].
302 Chien AT, Chin MH, Davis AM, et al. Pay for performance, public reporting, and racial disparities in health care: how are programs being designed?. Med Care Res Rev. Oct. 28. 2007;64(5 Suppl):3S-304S. Exclusion reason: Background. [pmid: 17881629].
303 Chien TW, Wang WC, Wang HY, et al. Online assessment of patients’ views on hospital performances using Rasch model’s KIDMAP diagram. BMC Health Serv Res. 2009;9:135. Exclusion reason: Wrong topic. [pmid: 19646267].
304 Chouaid C, Hejblum G, Guidet B, et al. The evaluation of health care outcomes and hospital performance indicators. Rev Mal Respir. Sep. S87. 2006;23(4 Suppl):13-98. quiz 13S158, 13S9. Exclusion reason: No outcome data. [pmid: 16604019].
305 Christensen EW, Arnould RJ. The impact of asymmetric information and ownership on nursing home access. Int J Health Care Finance Econ. Sep. 2005;5(3):273-97. Exclusion reason: Background. [pmid: 16082519].
306 Christensen MC, Remler D. Information and communications technology in U.S. health care: why is adoption so slow and is slower better?. J Health Polit Policy Law. Dec. 2009;34(6):1011-34. Exclusion reason: Wrong topic. [pmid: 20018989].
307 Christianson JB, Volmar KM, Alexander J, et al. A report card on provider report cards: current status of the health care transparency movement. J Gen Intern Med. Nov. 2010;25(11):1235-41. Exclusion reason: Background. [pmid: 20625849].
308 Chu HL, Wang CC, Dai YT. A study of a nursing department performance measurement system: using the Balanced Scorecard and the Analytic Hierarchy Process. Nurs Econ. Nov–Dec. 2009;27(6):401-7. Exclusion reason: Wrong topic. [pmid: 20050491].
309 Chuang S, Inder K. An effectiveness analysis of healthcare systems using a systems theoretic approach. BMC Health Serv Res. 2009;9:195. Exclusion reason: Background. [pmid: 19852837].
310 Chung KC, Shauver MJ. Measuring quality in health care and its implications for pay-for-performance initiatives. Hand Clin. Feb. 2009;25(1):71-81. vii. Exclusion reason: Background. [pmid: 19232918].
311 Cimino JJ. Use, usability, usefulness, and impact of an infobutton manager. AMIA Annu Symp Proc. 2006:151-5. Exclusion reason: Wrong topic. [pmid: 17238321].
312 Clancy C. The Performance of Performance Measurement Health Serv Res. 2007;42(5):1797-801. Exclusion reason: No outcome data.
313 Clancy C. H-CAHPS survey reflects patient experiences. Managed Healthcare Executive. 2008;18(7):34. Exclusion reason: No outcome data.
314 Clark RE. The development of The Society of Thoracic Surgeons voluntary national database system: genesis, issues, growth, and status. Best Pract Benchmarking Healthc. Mar–Apr. 1996;1(2):62-9. Exclusion reason: Wrong topic. [pmid: 9192577].
315 Clarke S. Surgeons’ report cards, heuristics, biases and informed consent Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:167-79. Exclusion reason: Background.
316 Clarke S, Oakley J. Informed consent and clinician accountability: The ethics of report cards on surgeon performance. Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007;xii:304. Exclusion reason: Background.
317 Cleves MA, Golden WE. Assessment of HCFA’s 1992 Medicare hospital information report of mortality following admission for hip arthroplasty. Health Serv Res. Apr. 1996;31(1):39-48. Exclusion reason: Methods. [pmid: 8617608].
318 Cogdill KW. Web resources for information about providers and facilities. Health Care on the Internet. 2000;4(4):69-75. Exclusion reason: Background.
319 Coile C. Medical report cards and hospital quality. Natl Bur Econ Res Bull Aging Health. Summer. 2004;(8):2-3. Exclusion reason: No outcome data. [pmid: 15344290].
320 Coile RC Jr. Competing in a report-card environment. Russ Coiles Health Trends. Oct. 4. 2002;14(12):1-9. Exclusion reason: Background. [pmid: 12387203].
321 Coile RC Jr, Menkin HL. Becoming customer-driven in a “report card” marketplace. Russ Coiles Health Trends. Dec. 4. 1998;11(2):1-9. Exclusion reason: No outcome data. [pmid: 10345224].
322 Cole DL. Managed care and information needs for consumers. Med Interface. Feb. 1997;10(2):54-5. Exclusion reason: No outcome data. [pmid: 10164790].
323 Collier EJ, Harrington C. Discharge planning, nursing home placement, and the Internet. Nurs Outlook. Mar–Apr. 2005;53(2):95-103. Exclusion reason: Wrong topic. [pmid: 15858528].
324 Collins SR. Consumer-driven health care. Why it won’t solve what ails the United States health system. J Leg Med. Jan–Mar. 2007;28(1):53-77. Exclusion reason: Wrong topic. [pmid: 17365413].
325 Collopy BT. Clinical indicators in accreditation: an effective stimulus to improve patient care. Int J Qual Health Care. Jun. 2000;12(3):211-6. Exclusion reason: Wrong topic. [pmid: 10894192].
326 Coltin KL, Beck A. The HEDIS antidepressant measure. Behav Healthc Tomorrow. Jun. 1999;8(3):40-1. 7. Exclusion reason: PR as outcome. [pmid: 10537652].
327 Comarow A. America’s best hospitals. Making the diagnosis: how we select the best. Keeping patients alive is a critical measure. US News World Rep. Jul. 19. 7. 81. 1999;127(3):75-2. passim. Exclusion reason: Background. [pmid: 10539368].
328 Comins M, Pathak E, Strom J. Hospital Compare and Rural Urban Disparities: Public Reporting and Quality of Care for Acute Myocardial Infarction Patients in the United States, 2007. Research in Cardiovascular Disease and Stroke. 2009 Apr 22–24. Wardman Park Marriott Hotel, Washington, DC, Washington. Exclusion reason: Unable to obtain.
329 Commonwealth Fund. Commission on a High Performance Health S. Why not the best?: Results from the national scorecard on U.S. health system performance, 2008. New York, NY. Commonwealth Fund. 2008. Exclusion reason: Wrong topic.
330 Cone-Swartz L, Lindberg L. Using patient satisfaction data to enhance performance. Remington Report. 2008:5-8. Exclusion reason: No outcome data.
331 Conn J. Getting satisfaction. (cover story). Mod Healthc. 2005;35(50):6-13. Exclusion reason: No outcome data. [pmid: 19273867].
332 Conn J. Getting satisfaction. The CMS survey publicly revealing patient satisfaction with hospitals is one step closer to becoming a reality. Mod Healthc. Dec. 12. 2005;35(50):6-7. 13. 1. Exclusion reason: Background. [pmid: 17899645].
333 Connelly D. News feature - The Safer Patients Initiative: Using new methods to tackle old problems. Pharmaceutical journal. 2007;279(7462):95. Exclusion reason: Wrong topic.
334 Connelly D. News feature - How do we measure patient outcomes?. Pharmaceutical journal. 2010;284(7594):283. Exclusion reason: Wrong topic.
335 Conrad K, Reilly KA. Choosing a home infusion provider. Caring. May. 1990;9(5):12-6. Exclusion reason: No outcome data. [pmid: 10105437].
336 Contencin P, Falcoff H, Doumenc M. Review of performance assessment and improvement in ambulatory medical care. Health Policy. Jun. 2006;77(1):64-75. Exclusion reason: Wrong topic. [pmid: 16139389].
337 Cooper W. A Call for Accountability. Pharmaceutical Executive. 2000;20(8):126. Exclusion reason: No outcome data. [pmid: 3476846].
338 Cornett BS. Health care quality and safety issues. Semin Speech Lang. May. 2006;27(2):80-8. Exclusion reason: Background. [pmid: 16673256].
339 Cornett BS. Transparency in Health Care: Through a Glass, Dimly. J Health Care Compliance. 2007;9(5):47-8. Exclusion reason: No outcome data.
340 Corrigan JM, Janet M. Corrigan, Ph.D. Interview by Marie E. Sinioris. Qual Manag Health Care. Summer. 1994;2(4):82-9. Exclusion reason: Background. [pmid: 10137611].
341 Cotton P. HCFA treating death data gently. Med World News. Oct. 10. 1988;29(19):35. Exclusion reason: No outcome data. [pmid: 10302908].
342 Coughlin TA, Long SK, Triplett T, et al. Florida’s medicaid reform: informed consumer choice?. Health Aff (Millwood). Nov–Dec. 2008;27(6):w523-32. Exclusion reason: Wrong topic. [pmid: 18854349].
343 Coulter A. Do patients want a choice and does it work?. BMJ. 2010;341:c4989. Exclusion reason: No outcome data. [pmid: 20947576].
344 Couper MP, Singer E, Levin CA, et al. Use of the Internet and ratings of information sources for medical decisions: results from the decisions survey. Med Decis Making. Sep–Oct. 10. 2010;30(5 Suppl):6S-14S. Exclusion reason: Wrong topic. [pmid: 20881159].
345 Coye MJ. No Toyotas in health care: why medical care has not evolved to meet patients’ needs. Health Aff (Millwood). Nov–Dec. 2001;20(6):44-56. Exclusion reason: Background. [pmid: 11816688].
346 Crofton C, Darby C, Farquhar M, et al. The CAHPS Hospital Survey: development, testing, and use. Jt Comm J Qual Patient Saf. Nov. 2005;31(11):655-9. 01. Exclusion reason: Background. [pmid: 16335067].
347 Crofton C, Lubalin JS, Darby C. Consumer Assessment of Health Plans Study (CAHPS). Foreword Med Care. Mar. 1999;37(3 Suppl):MS1-9. Exclusion reason: Background. [pmid: 10098554].
348 Cronenwett JL, Likosky DS, Russell MT, et al. A regional registry for quality assurance and improvement: The Vascular Study Group of Northern New England (VSGNNE). J Vasc Surg. Dec. 2007;46(6):1093-101. discussion 101–2. Exclusion reason: Wrong topic. [pmid: 17950568].
349 Cronin C. Business coalitions on health: their activities and impact. Jt Comm J Qual Improv. Jul. 1994;20(7):376-80. Exclusion reason: Background. [pmid: 7951767].
350 Cronin C. State health insurance exchange websites a review, discussion and recommendations for providing consumers information about quality and performance. Washington, D.C. AARP. 2011. Exclusion reason: No outcome data.
351 Cronin CA. Information: what do consumers want to know?. Med Interface. Apr. 1995;8(4):70-2. 4. 5. 86. Exclusion reason: No outcome data. [pmid: 10141768].
352 Crutchfield TN, Eveland VB, Eveland AP. Assessing Medicaid patients’ perceptions of the OB/GYN-patient relationship. Health Mark Q. 2002;19(4):21-37. Exclusion reason: Wrong topic. [pmid: 12557987].
353 Cuddeback J. Florida’s inpatient report card provides information to purchasers and consumers. QRC Advis. Mar. 1996;12(5):1-5. Exclusion reason: No outcome data. [pmid: 10154477].
354 Culler SD, Simon AW, Brown PP, et al. Sex differences in hospital risk-adjusted mortality rates for Medicare beneficiaries undergoing CABG surgery. Arch Intern Med. Nov. 24. 2008;168(21):2317-22. discussion 23–5. Exclusion reason: Wrong topic. [pmid: 19029494].
355 Cunningham R. Perspectives. Midwest buyers seek provider-specific performance data. Faulkner Grays Med Health. Mar. 24. 1997;51(12). suppl 1–4. Exclusion reason: No outcome data. [pmid: 10165376].
356 Cunningham R, Williams S. Perspectives. Informed consumer choice still a distant and difficult goal. Faulkner Grays Med Health. Sep. 8. 1997;51(35). suppl 1–4. Exclusion reason: No outcome data. [pmid: 10169926].
357 Cunningham-Myrie C, Reid M, Forrester TE. A comparative study of the quality and availability of health information used to facilitate cost burden analysis of diabetes and hypertension in the Caribbean. West Indian Med J. Sep. 2008;57(4):383-92. Exclusion reason: Wrong topic. [pmid: 19566021].
358 Daly JM, Jogerst GJ. Association of knowledge of adult protective services legislation with rates of reporting of abuse in Iowa nursing homes. J Am Med Dir Assoc. Mar–Apr. 2005;6(2):113-20. Exclusion reason: Wrong topic. [pmid: 15871886].
359 Dalzell MD. NCQA puts pressure on plans that don’t report HEDIS scores. Manag Care. Aug. 1999;8(8):39-40. Exclusion reason: No outcome data. [pmid: 10557925].
360 Dalzell MD. Physician, HEDIS (Health Employer Data and Information Set) thyself. Manag Care. Mar. 54. 1999;8(3):7. Exclusion reason: No outcome data. [pmid: 11729401].
361 Dalzell MD. Health care report cards: are you paying attention?. Manag Care. Feb. 1999;8(2):27-8. 30. 2. 4. Exclusion reason: No outcome data. [pmid: 10346106].
362 Damberg CL, Shortell SM, Raube K, et al. Relationship between quality improvement processes and clinical performance. Am J Manag Care. Aug. 2010;16(8):601-6. Exclusion reason: Wrong topic. [pmid: 20712393].
363 Damiano PC, Willard JC, Tyler MC, et al. CAHPS in practice: the Iowa demonstration. J Ambul Care Manage. Apr. 2002;25(2):32-42. Exclusion reason: No outcome data. [pmid: 11995194].
364 Daniels AS, Shaul JA, Greenberg P, et al. The Experience of Care and Health Outcomes Survey (ECHO): A Consumer Survey to Collect Ratings of Behavioral Health Care Treatment, Outcomes and Plans The use of psychological testing for treatment planning and outcomes assessment. Instruments for adults. 3rd ed. Mahwah, NJ. Lawrence Erlbaum Associates Publishers; US. 2004;3:839-66. Exclusion reason: Background.
365 Daniels AS, Stukenberg KW. Assessing quality of care The integrated behavioral health continuum: Theory and practice. Arlington, VA. American Psychiatric Publishing, Inc; US. 2001:257-68. Exclusion reason: Wrong topic.
366 Dans PE. Caveat doctor: how to analyze claims-based report cards. Jt Comm J Qual Improv. Jan. 1998;24(1):21-30. Exclusion reason: No outcome data. [pmid: 9494871].
367 Darby C, Crofton C, Clancy CM. Consumer Assessment of Health Providers and Systems (CAHPS): evolving to meet stakeholder needs. Am J Med Qual. Mar–Apr. 2006;21(2):144-7. Exclusion reason: Background. [pmid: 16533906].
368 Davidson BN. Designing health insurance information for the Medicare beneficiary: a policy synthesis. Health Serv Res. Dec. 1988;23(5):685-720. Exclusion reason: Background. [pmid: 3060450].
369 Davies E, Shaller D, Edgman-Levitan S, et al. Evaluating the use of a modified CAHPS survey to support improvements in patient-centred care: lessons from a quality improvement collaborative. Health Expect. Jun. 2008;11(2):160-76. Exclusion reason: Wrong topic. [pmid: 18494960].
370 Davies HT. Public release of performance data and quality improvement: internal responses to external data by US health care providers. Qual Health Care. Jun. 2001;10(2):104-10. Exclusion reason: Background. [pmid: 11389319].
371 Davies HT, Marshall MN. Public disclosure of performance data: does the public get what the public wants?. Lancet. May. 15. 1999;353(9165):1639-40. Exclusion reason: No outcome data. [pmid: 10335781].
372 Davies HT, Washington AE, Bindman AB. Health care report cards: implications for vulnerable patient groups and the organizations providing them care. J Health Polit Policy Law. Jun. 2002;27(3):379-99. Exclusion reason: Background. [pmid: 12092674].
373 Davies TJ, Bunn WB 3rd, Fromer L, et al. A focus on the asthma HEDIS measure and its implications for clinical practice. Manag Care Interface. Feb. 2006;19(2):29-36. Exclusion reason: No outcome data. [pmid: 16529078].
374 Davies TJ, Bunn WB 3rd, Fromer L, et al. A focus on the asthma HEDIS measure and its implications for clinical practice. Manag Care Interface. Feb. 2006;19(2):29-36. Exclusion reason: Background. [pmid: 16529078].
375 Davis K, Doty MM, Shea K, et al. Health information technology and physician perceptions of quality of care and satisfaction. Health Policy. May. 2009;90(2–3):239-46. Exclusion reason: Wrong topic. [pmid: 19038472].
376 Davis K, Schoen C. Assuring quality, information, and choice in managed care. Inquiry. Summer. 1998;35(2):104-14. Exclusion reason: Wrong topic. [pmid: 9719779].
377 Davis MM, Hibbard JH, Milstein A. Consumer tolerance for inaccuracy in physician performance ratings: one size fits none. Issue Brief Cent Stud Health Syst Change. Mar. 2007;(110):1-5. Exclusion reason: Wrong topic. [pmid: 17407857].
378 Daze C. Patients can get data on doctors just by picking up the phone. Manag Care. Jun. 1994;3(6):53. Exclusion reason: No outcome data. [pmid: 10139695].
379 de Vries H, Elliott MN, Hepner KA, et al. Equivalence of mail and telephone responses to the CAHPS Hospital Survey. Health Serv Res. Dec. 2005;40(6 Pt 2):2120-39. Exclusion reason: Methods. [pmid: 16316441].
380 Deas TM Jr. Health care value-based purchasing. Gastrointest Endosc Clin N Am. Oct. 2006;16(4):643-56. Exclusion reason: No outcome data. [pmid: 17098612].
381 Decker B, MacInnes R. Assessing the importance of report cards rating patient satisfaction. Health Syst Lead. Dec. 1997;4(11):16-8. Exclusion reason: No outcome data. [pmid: 10175513].
382 Deering MJ. Developing the health information infrastructure in the United States. Stud Health Technol Inform. 2002;80:121-8. Exclusion reason: Wrong topic. [pmid: 12026121].
383 Defino T. Medicaid HEDIS from paper to practice. Healthplan. May–Jun. 1996;37(3):25-8. 30. Exclusion reason: No outcome data. [pmid: 10162265].
384 Del Fante P, Allan D, Babidge E. Getting the most out of your practice--the Practice Health Atlas and business modelling opportunities. Aust Fam Physician. Jan–Feb. 2006;35(1–2):34-8. Exclusion reason: Wrong topic. [pmid: 16489384].
385 Delbanco S. Employers flex their muscles as health care purchasers. Surg Clin North Am. Aug. 2007;87(4):883-7. vii. Exclusion reason: Background. [pmid: 17888786].
386 DeLiberty RN. Developing a public mental health report card: The Hoosier Assurance Plan Provider Profile Report Card. Manag Care Q. Winter. 1998;6(1):1-7. Exclusion reason: Methods. [pmid: 10177283].
387 Delnoij DM. Measuring patient experiences in Europe: what can we learn from the experiences in the USA and England?. Eur J Public Health. Aug. 2009;19(4):354-6. Exclusion reason: No outcome data. [pmid: 19620220].
388 Delnoij DM, Rademakers JJ, Groenewegen PP. The Dutch consumer quality index: an example of stakeholder involvement in indicator development. BMC Health Serv Res. 2010;10:88. Exclusion reason: Background. [pmid: 20370925].
389 Delnoij DM, ten Asbroek G, Arah OA, et al. Made in the USA: the import of American Consumer Assessment of Health Plan Surveys (CAHPS) into the Dutch social insurance system. Eur J Public Health. Dec. 2006;16(6):652-9. Exclusion reason: Methods. [pmid: 16524940].
390 DeMott K. Massachusetts’ HMO Blue bows out of group report card project; claims star rating system unscientific. Qual Lett Healthc Lead. Nov. 1996;8(9):19. Exclusion reason: Background. [pmid: 10163987].
391 Derose KP, Kanouse DE, Weidmer B, et al. Developing a Spanish-language consumer report for CAHPS health plan surveys. Jt Comm J Qual Patient Saf. Nov. 2007;33(11):681-8. Exclusion reason: Methods. [pmid: 18074716].
392 Deutsch A, MacDonel C, Papadimitriou C, Magasi S, Heinemann A. Public Reporting of Quality Information by Inpatient Rehabilitation Hospitals and Units. Rehabilitation Research without Borders. 2008 Oct 15–19. Delta Chelsea Hotel, Toronto, Ontario (Canada). Exclusion reason: Unable to obtain.
393 Devers KJ, Pham HH, Liu G. What is driving hospitals’ patient-safety efforts?. Health Aff (Millwood). Mar–Apr. 2004;23(2):103-15. Exclusion reason: No outcome data. [pmid: 15046135].
394 Dewan NA, Carpenter D. Performance measurement in healthcare delivery systems. American Psychiatric Press review of psychiatry. Washington, DC. American Psychiatric Association; US. 1997;16:V-81-V-102. Exclusion reason: Background.
395 DeWitt E, Morgan PMK, et al. Pediatric Rheumatology Improvement Network for Clinical Excellence and Safety - PRINCES [abstract]. Arthritis Rheum. October. 16–21. 2009;60(S10):1888. Exclusion reason: Background.
396 DeWolf L, Giloth B. Strategies for outcomes measurement: how seven systems do it. Healthc Forum J. Jul–Aug. 1998;41(4):32-4. Exclusion reason: Wrong topic. [pmid: 10185469].
397 Di Tanna GL, Cisbani L, Grilli R. Public reporting on individual hospitals’ quality: the risk of misinformation. Epidemiol Prev. May–Jun. 2006;30(3):199-204. Exclusion reason: Methods. [pmid: 17051944].
398 Diamond F. Believe it: HEDIS scores matter to employers. Manag Care. Mar. 34. 2003;12(3):7. Exclusion reason: No outcome data. [pmid: 12685374].
399 Dianis NL, Cummings C. An interdisciplinary approach to process performance improvement. J Nurs Care Qual. Apr. 1998;12(4):49-59. Exclusion reason: Wrong topic. [pmid: 9529798].
400 DiCenzo J, Fronstin P. Lessons from the evolution of 401(k) retirement plans for increased consumerism in health care: an application of behavioral research. EBRI Issue Brief. Aug. 3. 2008;320:1-26. Exclusion reason: Background. [pmid: 18724525].
401 Dickerson S, Reinhart AM, Feeley TH, et al. Patient Internet use for health information at three urban primary care clinics. J Am Med Inform Assoc. Nov–Dec. 2004;11(6):499-504. Exclusion reason: Wrong topic. [pmid: 15298993].
402 Dickinson T, Riley J, Zabetakis PM. External validation of compliance to perfusion quality indicators. Perfusion. 2004;19(5):295-9. Exclusion reason: Methods. [pmid: 15506034].
403 Dielenseger P, Dilhuydy JM, Brusco S, et al. Sor Savoir Patient Cancer and fatigue. Information dedicated to cancer patients and relatives. Bull Cancer. Dec. 2006;93(12):1213-27. Exclusion reason: Wrong topic. [pmid: 17191350].
404 Dikolli SS. Discussion Nonfinancial Performance Measures and Physician Compensation. J of Management Accounting Research. 2010;22:57. Exclusion reason: Wrong topic.
405 Dimick JB, Osborne NH, Hall BL, et al. Risk adjustment for comparing hospital quality with surgery: how many variables are needed?. J Am Coll Surg. Apr. 2010;210(4):503-8. Exclusion reason: Methods. [pmid: 20347744].
406 Diokno AC, Killinger KA, Ibrahim IA, et al. Establishing a Prostatectomy Outcomes Database for Clinical Practice Improvement, Research, and Education: A Community Hospital Experience. JCOM -WAYNE PA-. 2007;14(10):541-6. Exclusion reason: Wrong topic.
407 Dobler K, Mohr VD. Clinical performance measurement in surgery and orthopedics -- new aspects in 2004. Zentralbl Chir. Jun. 2004;129(3):165-71. Exclusion reason: No outcome data. [pmid: 15237319].
408 Dolan G, Iredale R, Williams R, et al. Consumer use of the internet for health information: a survey of primary care patients. Int J Consum Stud. 2004;28(2):147-53. Exclusion reason: Wrong topic.
409 Donohue JM, Marcum Z, Zhang Y, et al. Medicare Part D’s impact on high risk medication use among older adults. ACRT-SCTS Scholar Abstracts Clinical and Translational Science. 2010;3(2):S25. Exclusion reason: PR as outcome.
410 Doran T, Fullwood C. Pay for performance: is it the best way to improve control of hypertension?. Curr Hypertens Rep. Nov. 2007;9(5):360-7. Exclusion reason: Wrong topic. [pmid: 18177581].
411 D’Oronzio JC. “Unexpected” death and other report cards on access and ethics. Camb Q Healthc Ethics. Fall. 1995;4(4):549-52. Exclusion reason: No outcome data. [pmid: 8563966].
412 Doty MM, Koren MJ, Sturla EL, et al. Culture change in nursing homes : how far have we come? : findings from the Commonwealth Fund 2007 national survey of nursing homes. [New York, N.Y.?]. Commonwealth Fund. 2008. Exclusion reason: Wrong topic.
413 Downing A, Rudge G, Cheng Y, et al. Do the UK government’s new Quality and Outcomes Framework (QOF) scores adequately measure primary care performance? A cross-sectional survey of routine healthcare data. BMC Health Serv Res. 2007;7:166. Exclusion reason: Wrong topic. [pmid: 17941984].
414 Draper DA. Physician Performance Measurement: A Key to Higher Quality and Lower Cost Growth or a Lost Opportunity?. Jones & Bartlett Publishers. 2009. Exclusion reason: No outcome data.
415 Drozda JP Jr, Hagan EP, Mirro MJ, et al. ACCF 2008 health policy statement on principles for public reporting of physician performance data: A Report of the American College of Cardiology Foundation Writing Committee to develop principles for public reporting of physician performance data. J Am Coll Cardiol. May. 20. 2008;51(20):1993-2001. Exclusion reason: Background. [pmid: 18482675].
416 Druss BG. A review of HEDIS measures and performance for mental disorders. Manag Care. Jun. 2004;13(6 Suppl Depression):48-51. Exclusion reason: Background. [pmid: 15293771].
417 Druss BG, Miller CL, Rosenheck RA, et al. Mental health care quality under managed care in the United States: a view from the Health Employer Data and Information Set (HEDIS). Am J Psychiatry. May. 2002;159(5):860-2. Exclusion reason: Methods. [pmid: 11986144].
418 Du Moulin MF, van Haastregt JC, Hamers JP. Monitoring quality of care in nursing homes and making information available for the general public: state of the art. Patient Educ Couns. Mar. 2010;78(3):288-96. Exclusion reason: Background. [pmid: 20171037].
419 Duckett SJ, Collins J, Kamp M, et al. An improvement focus in public reporting: the Queensland approach. Med J Aust. Dec. 1–15. 2008;189(11–12):616-7. Exclusion reason: No outcome data. [pmid: 19061447].
420 Duckett SJ, Coory M, Sketcher-Baker K. Identifying variations in quality of care in Queensland hospitals. Med J Aust. Nov. 19. 2007;187(10):571-5. Exclusion reason: Wrong topic. [pmid: 18021046].
421 DuPree E, Martin L, Anderson R, et al. Improving patient satisfaction with pain management using Six Sigma tools. Jt Comm J Qual Patient Saf. Jul. 2009;35(7):343-50. Exclusion reason: PR as outcome. [pmid: 19634801].
422 Duran-Arenas L, Cruz Rivero C, Fernandez Canton S, et al. The development of a quality information system: a case study of Mexico. Health Policy Plan. Dec. 1998;13(4):446-58. Exclusion reason: Wrong topic. [pmid: 10346036].
423 Duszak R Jr, Saunders WM. Medicare’s physician quality reporting initiative: incentives, physician work, and perceived impact on patient care. J Am Coll Radiol. Jun. 2010;7(6):419-24. Exclusion reason: Wrong topic. [pmid: 20522394].
424 Dutta-Bergman M. Trusted online sources of health information: differences in demographics, health beliefs, and health-information orientation. J Med Internet Res. Jul–Sep. 2003;5(3):e21. Exclusion reason: Wrong topic. [pmid: 14517112].
425 Dziuban SW Jr, McIlduff JB, Miller SJ, et al. How a New York cardiac surgery program uses outcomes data. Ann Thorac Surg. Dec. 1994;58(6):1871-6. Exclusion Reason: No Outcome data. [pmid: 7979785].
426 Eagle KA, Koelling TM, Montoye CK. Primer: implementation of guideline-based programs for coronary care. Nat Clin Pract Cardiovasc Med. Mar. 2006;3(3):163-71. Exclusion reason: Wrong topic. [pmid: 16505862].
427 Eastaugh SR. Hospital quality scorecards, patient severity, and the emerging value shopper. Hosp Health Serv Adm. Nov–Dec. 1986;31(6):85-102. Exclusion reason: Background. [pmid: 10279765].
428 Eckert J. A clear & present measure. Take ownership of patient satisfaction. MGMA Connex. Sep. 2009;9(8):52-5. Exclusion reason: No outcome data. [pmid: 19785363].
429 Eddy DM. What defines a good doctor is about to change. Interview by Ken Terry. Med Econ. Apr. 28. 1997;74(9):67-70. Exclusion reason: Background. [pmid: 10166723].
430 Edgman-Levitan S, Cleary PD. What information do consumers want and need?. Health Aff (Millwood). Winter. 1996;15(4):42-56. Exclusion reason: No outcome data. [pmid: 8991253].
431 Edlin ML. Define your health plan’s value with quality reporting. Health Manag Technol. Jul. 1996;17(8):17-9. Exclusion reason: No outcome data. [pmid: 10159293].
432 Edmond MB, Bearman GM. Mandatory public reporting in the USA: an example to follow?. J Hosp Infect. Jun. 2007;65(Suppl 2):182-8. Exclusion reason: Background. [pmid: 17540267].
433 Edwards C, Staniszewska S. Accessing the users’ perspective. Health & Social Care in the Community. 2000;8(6):417-24. Exclusion reason: Wrong topic. [pmid: 11560712].
434 Edwards DJ. QI efforts work -- And more QMs appear. Nursing Homes: Long Term Care Management. 2004;53(4):22-3. Exclusion reason: Wrong topic.
435 Edwards FH. How one medical specialty society’s use of measures and reporting dramatically improved patient care. J Fam Pract. 2008;57(10):S6-9. Exclusion reason: Wrong topic.
436 Edwards N. Using markets to reform health care. BMJ. Dec. 17. 2005;331(7530):1464-6. Exclusion reason: No outcome data. [pmid: 16356985].
437 Einarson A, Park A, Koren G. How physicians perceive and utilize information from a teratogen information service: the Motherisk Program. BMC Med Educ. Apr. 5. 2004;4:6. Exclusion reason: Wrong topic. [pmid: 15066201].
438 Elizabeth Wilcox M, Herridge MS. Clinical year in review III: mechanical ventilation, acute respiratory distress syndrome, nonpulmonary intensive care unit, and quality performance assessment metrics in your practice. Proc Am Thorac Soc. Sep. 2011;8(5):404-10. Exclusion reason: Wrong topic. [pmid: 21926390].
439 Elliott MN, Beckett MK, Kanouse DE, et al. Problem-oriented reporting of CAHPS consumer evaluations of health care. Med Care Res Rev. Oct. 2007;64(5):600-14. Exclusion reason: Background. [pmid: 17717379].
440 Elston DM. The physician quality reporting initiative. Clin Lab Med. Jun. 2008;28(2):351-7. viii. Exclusion reason: Background. [pmid: 18436076].
441 Elwyn G, Buetow S, Hibbard J, et al. Measuring quality through performance Respecting the subjective: quality measurement from the patient’s perspective. BMJ. Nov. 17. 2007;335(7628):1021-2. Exclusion reason: No outcome data. [pmid: 18007003].
442 Emmert M, Maryschok M, Eisenreich S, et al. Websites to assess quality of care--appropriate to identify good physicians?. Gesundheitswesen. Apr. 2009;71(4):e18-27. Exclusion reason: No outcome data. [pmid: 19221986].
443 Emmert M, Schoffski O. Public reporting of the Californian “pay for performance” conducted by the Integrated Healthcare Association (IHA). Gesundheitswesen. Aug–Sep. 2007;69(8–9):438-47. Exclusion reason: No outcome data. [pmid: 17926260].
444 Endahl LA, Utzon J. [Will publication of quality indicators in the health service improve the quality? International experiences and Danish perspectives]. Ugeskr Laeger. Sep. 16. 2002;164(38):4380-4. Exclusion reason: No outcome data. [pmid: 12362726].
445 Epstein AJ. Do cardiac surgery report cards reduce mortality? Assessing the evidence. Med Care Res Rev. Aug. 2006;63(4):403-26. Exclusion reason: Background. [pmid: 16847071].
446 Epstein AJ, Rosenquist JN. Tell me something new: report cards and the referring physician. Am J Med. Feb. 2010;123(2):99-100. Exclusion reason: No outcome data. [pmid: 20103013].
447 Epstein AM. The role of quality measurement in a competitive marketplace. Baxter Health Policy Rev. 1996;2:207-34. Exclusion reason: Background. [pmid: 11066261].
448 Epstein AM. Rolling down the runway: the challenges ahead for quality report cards. JAMA. Jun. 3. 1998;279(21):1691-6. Exclusion reason: Background. [pmid: 9624015].
449 Epstein AM. Public release of performance data: a progress report from the front. JAMA. Apr. 12. 2000;283(14):1884-6. Exclusion reason: No outcome data. [pmid: 10770153].
450 Erbeck GW, Pozzebon L. San Diego County team excellence performance measurement system. J Environ Health. Jan–Feb. 2006;68(6):65-8. Exclusion reason: Wrong topic. [pmid: 16483085].
451 Erickson LC, Torchiana DF, Schneider EC, et al. The relationship between managed care insurance and use of lower-mortality hospitals for CABG surgery. JAMA. Apr. 19. 2000;283(15):1976-82. Exclusion reason: Wrong topic. [pmid: 10789665].
452 Eselius LL. Assessing the quality of behavioral health care and health plans using consumer reports and ratings. 2004. Exclusion reason: Methods.
453 Esmail N, Hazel M. A lack of transparency in BC’s hospitals. Fraser Forum. 2008 Apr 13–16. Exclusion reason: Background.
454 Esmail N, Hazel M. Hospital Report Card Alberta 2009 Fraser Institute. June. 18. 2009. http://www.fraserinstitute.org/commerce.web/product_files/HospitalReportCard_AB2009.pdf. Exclusion reason: No outcome data.
455 Esmail N, Hazel M. Hospital Report Card: British Columbia 2009 Fraser Institute. May. 22. 2009. http://www.fraserinstitute.org/commerce.web/product_files/Complete-Publication.pdf. Exclusion reason: No outcome data.
456 Esmail N, Hazel M. Hospital Report Card: Ontario 2009 Fraser Institute. Mar. 2009. http://www.fraserinstitute.org/commerce.web/product_files/HospitalReportCard_Ontario2009.pdf. Exclusion reason: No outcome data.
457 Evans M. Shopping for a hospital. Ads direct consumers to compare quality measures. Mod Healthc. May. 26. 2008;38(21):8-9. Exclusion reason: No outcome data. [pmid: 18714444].
458 Eyers T. Training, innovation and surgeons’ report cards Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:266-78. Exclusion reason: No outcome data.
459 Eysenbach G, Jadad AR. Evidence-based patient choice and consumer health informatics in the Internet age. J Med Internet Res. Apr–Jun. 2001;3(2):E19. Exclusion reason: Background. [pmid: 11720961].
460 Faber M, Bosch M, Wollersheim H, et al. Public reporting in health care: how do consumers use quality-of-care information? A systematic review. Med Care. Jan. 2009;47(1):1-8. Exclusion reason: Background. [pmid: 19106724].
461 Farber H, Schatz M. Health Plan Employer Data and Information Set (HEDIS(R)) Criteria to Determine the Quality of Asthma Care in Children: What Are the Limitations?. Dis Manag Health Out. 2008;15(5):279-87. Exclusion reason: Methods.
462 Farley DO, McGlynn EA, Klein D. Assessing quality in managed care: health plan reporting of HEDIS performance measures. Policy Brief Commonw Fund. Sep. 1998;(298):1-6. Exclusion reason: Methods. [pmid: 11729847].
463 Faulkner M, Davies S, The CARE. (Combined Assessment of Residential Environments) profiles: a new approach to improving quality in care homes. Qual Ageing. 2006;7(3):15-25. Exclusion reason: Methods.
464 Faunce T, Mure K, Cox C, et al. When silence threatens safety: lessons from the first Canberra Hospital neurosurgical inquiry. J Law Med. Aug. 2004;12(1):112-8. Exclusion reason: Wrong topic. [pmid: 15359555].
465 Faust R. Indicators for the sensible judgement of care-sensitivity quality in nursing home compare -- chances of RAI MDS-based quality indicators for quality measurement of nursing in Germany [German]. PR-Internet fur die Pflege. 2004;6(4):222-30. Exclusion reason: Methods.
466 Fazzi R, Mazza G. The National Quality Improvement/Hospitalization Reduction Study, Part I. An industry-wide response. Caring. Oct. 2005;24(10):70-6. Exclusion reason: Wrong topic. [pmid: 16358536].
467 Feeley TW, Fly HS, Albright H, et al. A method for defining value in healthcare using cancer care as a model. J Healthc Manag. Nov–Dec. 2010;55(6):399-411. discussion -2. Exclusion reason: Background. [pmid: 21166323].
468 Feifer C, Ornstein SM, Jenkins RG, et al. The logic behind a multimethod intervention to improve adherence to clinical practice guidelines in a nationwide network of primary care practices. Eval Health Prof. Mar. 2006;29(1):65-88. Exclusion reason: Wrong topic. [pmid: 16510880].
469 Feldman R, Christianson J, Schultz J. Do consumers use information to choose a health-care provider system?. Milbank Q. 2000;78(1):47-77. ii. Exclusion reason: Wrong topic. [pmid: 10834081].
470 Feldstein AC, Glasgow RE. A practical, robust implementation and sustainability model (PRISM) for integrating research findings into practice. Jt Comm J Qual Patient Saf. Apr. 2008;34(4):228-43. Exclusion reason: Background. [pmid: 18468362].
471 Felt-Lisk S, Barrett A, Nyman R. Public reporting of quality information on Medicaid health plans. Health Care Financ Rev. Spring. 2007;28(3):5-16. Exclusion reason: Background. [pmid: 17645152].
472 Fenter TC, Lewis SJ. Pay-for-performance initiatives. Supplement to Journal of Managed Care Pharmacy. Aug. 2008;14(6 SUPPL C):S12-S5. Exclusion reason: Wrong topic.
473 Ferguson TB Jr. Reporting for provider performance: should we punish the bad, or try to make them all good?. Am Heart J. Sep. 2006;152(3):410-3. Exclusion reason: No outcome data. [pmid: 16923404].
474 Fermazin M, Canady M, Bauer K, et al. Nursing home compare: web site offers critical information to consumers, professionals. Lippincotts Case Manag. Jul–Aug. 2003;8(4):175-83. Exclusion reason: Background. [pmid: 12897631].
475 Fermazin M, Canady MO, Milmine PR, et al. Home health compare: Web site offers critical information to consumers, professionals. Lippincotts Case Manag. Mar–Apr. 2004;9(2):89-95. Exclusion reason: Background. [pmid: 15192503].
476 Ferreira-Gonzalez I, Marsal JR, Mitjavila F, et al. Patient registries of acute coronary syndrome: assessing or biasing the clinical real world data?. Circ Cardiovasc Qual Outcomes. Nov. 2009;2(6):540-7. Exclusion reason: Wrong topic. [pmid: 20031891].
477 Findlay S, Lansky D. Numbers to crunch. Better public data needed to help patients compare and choose physicians. Mod Healthc. Feb. 14. 2011;41(7):26. Exclusion reason: Background. [pmid: 21449118].
478 Fishman L. Report cards hold HMOs accountable. N J Med. Feb. 1998;95(2):37-9. Exclusion reason: Methods. [pmid: 9505506].
479 Coronary artery by-pass graft surgery report card in New Jersey. American Public Health Association. 1998 Nov 15–19. American Public Health Association, 1015 15th Street, N.W., Washington, DC 20005-2605. World Meeting Number 984 0224. Exclusion reason: Unable to obtain.
480 Fletcher M. Hand hygiene and infection in hospitals: what do the public know; what should the public know?. J Hosp Infect. Dec. 2009;73(4):397-9. Exclusion reason: No outcome data. [pmid: 19783070].
481 Fong T. Giving choice a chance. CMS extends its mandated quality data campaign to include home care. Mod Healthc. Nov. 10. 2003;33(45):17. Exclusion reason: No outcome data. [pmid: 14666546].
482 Forrester L, Collet JC, Mitchell R, et al. How reliable are national surveillance data? Findings from an audit of Canadian methicillin-resistant Staphylococcus aureus surveillance data. Am J Infect Control. 2011. Jun. 24. Exclusion reason: Wrong topic. [pmid: 21705109].
483 Fotaki M, Roland M, Boyd A, et al. What benefits will choice bring to patients? Literature review and assessment of implications. J Health Serv Res Policy. Jul. 2008;13(3):178-84. Exclusion reason: Background. [pmid: 18573768].
484 Fottler MD, Slovensky DJ, Rogers SJ. HCFA release of hospital specific death rates: where are we and where are we going?. J Am Med Rec Assoc. Sep. 1988;59(9):25-9. Exclusion reason: No outcome data. [pmid: 10288893].
485 Fountain JE. Digital government and public health. Prev Chronic Dis. Oct. 2004;1(4):A2. Exclusion reason: Wrong topic. [pmid: 15675046].
486 Fox KA, Eagle KA, Gore JM, et al. The Global Registry of Acute Coronary Events, 1999 to 2009--GRACE. Heart. Jul. 2010;96(14):1095-101. Exclusion reason: Wrong topic. [pmid: 20511625].
487 Fox MH. Who speaks for the health consumer?. J Health Care Poor Underserved. Aug. 2008;19(3):671-6. Exclusion reason: Background. [pmid: 18677063].
488 Frank RG, Lave JR. Economics. Feldman S, editor. Managed Behavioral Health Services: Perspectives and Practice. Springfield, IL, US. Charles C. Thomas Publishing. 2003:146-65. Exclusion reason: Wrong topic.
489 Franks A. How goes the night, watchman? An overview of the first annual clinical governance reports (1999/2000) from acute trusts in an English NHS region. J Manag Med. 2001;15(3):220-6. Exclusion reason: Wrong topic. [pmid: 11547581].
490 Freckelton I. Doctors’ report cards: A legal perspective Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:279-93. Exclusion reason: Background.
491 Fredrickson DD, Jones TL, Molgaard CA, et al. Optimal design features for surveying low-income populations. J Health Care Poor Underserved. Nov. 2005;16(4):677-90. Exclusion reason: Wrong topic. [pmid: 16311492].
492 Freedman JD, Gottlieb AB, Lizzul PF. Physician performance measurement: tiered networks and dermatology (an opportunity and a challenge). J Am Acad Dermatol. Jun. 2011;64(6):1164-9. Exclusion reason: No outcome data. [pmid: 21571173].
493 Freixinet JL, Varela G, Molins L, et al. Benchmarking in thoracic surgery. Eur J Cardiothorac Surg 2011. July. 1. 2011;40(1):124-9. Exclusion reason: Wrong topic.
494 French J. 2003 E.I. Hood Award. The Use of Patient Satisfaction Data to Drive Quality Improvement. Canadian Journal of Medical Radiation Technology. 2004;35(2):14-24. Exclusion reason: Wrong topic.
495 Friedberg MW, Coltin KL, Safran DG, et al. Associations between structural capabilities of primary care practices and performance on selected quality measures. Ann Intern Med. Oct. 6. 2009;151(7):456-63. Exclusion reason: PR as outcome. [pmid: 19805769].
496 Frolich A, Talavera JA, Broadhead P, et al. A behavioral model of clinician responses to incentives to improve quality. Health Policy. Jan. 2007;80(1):179-93. Exclusion reason: Background. [pmid: 16624440].
497 Fuhlbrigge A, Carey VJ, Adams RJ, et al. Evaluation of asthma prescription measures and health system performance based on emergency department utilization. Med Care. May. 2004;42(5):465-71. Exclusion reason: Methods. [pmid: 15083107].
498 Fung CH, Lim YW, Mattke S, et al. Systematic review: the evidence that publishing patient care performance data improves quality of care. Ann Intern Med. Jan. 15. 2008;148(2):111-23. Exclusion reason: No outcome data. [pmid: 18195336].
499 Gagliardi AR, Lemieux-Charles L, Brown AD, et al. Barriers to patient involvement in health service planning and evaluation: an exploratory study. Patient Educ Couns. Feb. 2008;70(2):234-41. Exclusion reason: Wrong topic. [pmid: 18023129].
500 Galandiuk S, Rao MK, Heine MF, et al. Mutual reporting of process and outcomes enhances quality outcomes for colon and rectal resections. Surgery. Oct. 2004;136(4):833-41. Exclusion reason: Wrong topic. [pmid: 15467669].
501 Galdabini G. Carve-out behavioral MCOs look to performance standards, accreditation to counter charges of poor quality. Qual Lett Healthc Lead. Nov. 1997;9(10):17-8. Exclusion reason: Wrong topic. [pmid: 10175480].
502 Gallagher MP, Krumholz HM. Public reporting of hospital outcomes: a challenging road ahead. Med J Aust. Jun. 20. 2011;194(12):658-60. Exclusion reason: Background. [pmid: 21692729].
503 Gallagher TH, Levinson W. Disclosing harmful medical errors to patients: a time for professional action. Arch Intern Med. Sep. 12. 2005;165(16):1819-24. Exclusion reason: Wrong topic. [pmid: 16157824].
504 Gallagher TH, Waterman AD, Garbutt JM, et al. US and Canadian physicians’ attitudes and experiences regarding disclosing errors to patients. Arch Intern Med. Aug. 14–28. 2006;166(15):1605-11. Exclusion reason: Wrong topic. [pmid: 16908793].
505 Galloro V. Surveying the landscape. State of Oklahoma using ‘score card’ to quantify nursing home quality. Mod Healthc. Jan. 15. 2001;31(3):48. Exclusion reason: No outcome data. [pmid: 11418948].
506 Galvin RS. Are performance measures relevant?. Health Aff (Millwood). Jul–Aug. 1998;17(4):29-31. Exclusion reason: No outcome data. [pmid: 9691544].
507 Gandhi TK, Francis EC, Puopolo AL, et al. Inconsistent report cards: assessing the comparability of various measures of the quality of ambulatory care. Med Care. Feb. 2002;40(2):155-65. Exclusion reason: Methods. [pmid: 11802088].
508 Garcia-Lacalle J. A bed too far. The implementation of freedom of choice policy in the NHS. Health Policy. Jul. 2008;87(1):31-40. Exclusion reason: Methods. [pmid: 18078681].
509 Gardin TH. How well will HEDIS 3.0 address the Medicaid population?. Med Interface. Jul. 1996;9(7):78-81. 5. Exclusion reason: Methods. [pmid: 10159280].
510 Gardner E. Missouri to deliver report card. Mod Healthc. Jul. 5. 1993;23(27):36. Exclusion reason: No outcome data. [pmid: 10126815].
511 Gardner J. Pilot NCQA report card rates managed-care plans. Mod Healthc. Feb. 27. 1995;25(9):12. Exclusion reason: No outcome data. [pmid: 10140266].
512 Gardner J. Web now watchdog on nursing homes. Mod Healthc. 1998;28(43):17. Exclusion reason: No outcome data. [pmid: 1247462].
513 Garpenby P. Implementing quality of programmes in three Swedish county councils: the views of politicians, managers and doctors. Health Policy. Mar. 1997;39(3):195-206. Exclusion reason: Wrong topic. [pmid: 10165461].
514 Gawande AA, Bates DW. The use of information technology in improving medical performance. Part I. Information systems for medical transactions. MedGenMed. Feb. 7. 2000;2(1):E14. Exclusion reason: Background. [pmid: 11104460].
515 Gebhart F. Will transparency in hospital pricing affect you?. Drug Topics. Oct. 26. 2006:HSE22. Exclusion reason: Wrong topic.
516 Gelfand EW, Colice GL, Fromer L, et al. Use of the health plan employer data and information set for measuring and improving the quality of asthma care. Ann Allergy Asthma Immunol. Sep. 2006;97(3):298-305. Exclusion reason: No outcome data. [pmid: 17042134].
517 Geraedts M, Amhof R. Gender differences in the demand for quality-related information on health care providers. Bundesgesundheitsblatt Gesundheitsforschung Gesundheitsschutz. Jan. 2008;51(1):53-60. Exclusion reason: Not English. [pmid: 18185969].
518 Geraedts M, Auras S, Hermeling P, et al. Public reporting--forms and effects. Dtsch Med Wochenschr. Oct. 2009;134(Suppl 6):S232-3. Exclusion reason: No outcome data. [pmid: 19834852].
519 Ghaferi AA, Osborne NH, Dimick JB. Does voluntary reporting bias hospital quality rankings?. J Surg Res. Jun. 15. 2010;161(2):190-4. Exclusion reason: Methods. [pmid: 19932907].
520 Gharacholou SM, Hellkamp AS, Hernandez AF, et al. Use and predictors of heart failure disease management referral in patients hospitalized with heart failure: insights from the get with the guidelines program. J Card Fail. May. 2011;17(5):431-9. Exclusion reason: Wrong topic. [pmid: 21549302].
521 Gillette B. Pay-for-performance measurement helps set the bar for quality, efficient care. Managed Healthcare Executive. 2005;15(12):26-30. Exclusion reason: No outcome data.
522 Ginsburg PB, Kemper NM. Health Care Quality Transparency: If You Build It, Will Patients Come?. HSC - Center for Studying: Health System Change. Jul. 2009;(4):1-4. Exclusion reason: No outcome data.
523 Giordano LA, Elliott MN, Goldstein E, et al. Development, implementation, and public reporting of the HCAHPS survey. Med Care Res Rev. Feb. 2010;67(1):27-37. Exclusion reason: Background. [pmid: 19638641].
524 Glance LG, Neuman M, Martinez EA, et al. Performance measurement at a “tipping point”. Anesth Analg. Apr. 2011;112(4):958-66. Exclusion reason: No outcome data. [pmid: 21385976].
525 Glazer J, McGuire T, Normand SL. Mitigating the Problem of Unmeasured Outcomes in Quality Reports. B E J Econom Anal Policy. Jan. 2008;8(2):7. Exclusion reason: Background. [pmid: 20490360].
526 Glazer J, McGuire TG. Optimal quality reporting in markets for health plans. J Health Econ. Mar. 2006;25(2):295-310. Exclusion reason: No outcome data. [pmid: 16352359].
527 Glazer J, McGuire TG, Cao Z, et al. Using global ratings of health plans to improve the quality of health care. J Health Econ. Sep. 2008;27(5):1182-95. Exclusion reason: Background. [pmid: 18571751].
528 Glazer J, McGuire TG, Newhouse JP. Using performance measures to motivate ‘report-averse’ and ‘report-loving’ agents. J Health Econ. Dec. 1. 2007;26(6):1170-89. Exclusion reason: Background. [pmid: 17996319].
529 Glenn B. The rating game. Patients & insurers are rating the quality of your care. Do you know what they’re saying?. Med Econ. Dec. 5. 2008;85(23):18-22. Exclusion reason: No outcome data. [pmid: 19209532].
530 Glickman SW, Boulding W, Roos JM, et al. Alternative pay-for-performance scoring methods: implications for quality improvement and patient outcomes. Med Care. Oct. 2009;47(10):1062-8. Exclusion reason: Methods. [pmid: 19648833].
531 Glondys BA. HIM resources--practice tools: mortality review. J AHIM A. Jul. 1992;63(7):33-8. Exclusion reason: Wrong topic. [pmid: 10119095].
532 Gold M. Medicare’s private plans: a report card on Medicare Advantage. Health Aff (Millwood). Jan–Feb. 2009;28(1):w41-54. Exclusion reason: Wrong topic. [pmid: 19029152].
533 Goldberg R. Understanding the quality landscape in medicine and psychiatry. American Journal of Geriatric Psychiatry. AAGP Annual Meeting Abstracts. 2010;18(3 (Supplement)):S12. Exclusion reason: No outcome data.
534 Goldman LE, Dudley RA. United States rural hospital quality in the Hospital Compare database-accounting for hospital characteristics. Health Policy. Jul. 2008;87(1):112-27. Exclusion reason: PR as outcome. [pmid: 18374447].
535 Goldman RD, Macpherson A. Internet health information use and e-mail access by parents attending a paediatric emergency department. Emerg Med J. May. 2006;23(5):345-8. Exclusion reason: Wrong topic. [pmid: 16627833].
536 Goldman RS. Payment for performance: in sickness and in health. For better or for worse?. Blood Purif. 2006;24(1):28-32. Exclusion reason: Background. [pmid: 16361837].
537 Goldstein E. CMS’s consumer information efforts. Health Care Financ Rev. Fall. 2001;23(1):1-4. Exclusion reason: No outcome data. [pmid: 12500358].
538 Goldstein E, Elliott MN, Lehrman WG, et al. Racial/ethnic differences in patients’ perceptions of inpatient care using the HCAHPS survey. Med Care Res Rev. Feb. 2010;67(1):74-92. Exclusion reason: PR as outcome. [pmid: 19652150].
539 Goldstein SM, Schweikhart SB. Empirical support for the Baldrige Award framework in U.S. hospitals. Health Care Manage Rev. Winter. 2002;27(1):62-75. Exclusion reason: Background. [pmid: 11765896].
540 Gooding SK. The relative importance of information sources in consumers’ choice of hospitals. J Ambul Care Mark. 1995;6(1):99-108. Exclusion reason: Wrong topic. [pmid: 10170374].
541 Goodman M, Brown J, Deitz P. Managing managed care II : a handbook for mental health professionals. Washington, DC. American Psychiatric Press. 1996. Exclusion reason: Wrong topic.
542 Goodroe JH. Using comparative data to improve healthcare value. Healthc Financ Manage. Jun. 2010;64(6):63-6. Exclusion reason: No outcome data. [pmid: 20533679].
543 Gormley WT Jr, Boccuti C. HCFA and the states: politics and intergovernmental leverage. J Health Polit Policy Law. Jun. 2001;26(3):557-80. Exclusion reason: Background. [pmid: 11430252].
544 Gormley WT, Weimer DL. Organizational report cards. Harvard University Press. 1999. Exclusion reason: No outcome data.
545 Gorrindo T, Groves JE. Web searching for information about physicians. JAMA. Jul. 9. 2008;300(2):213-5. Exclusion reason: Wrong topic. [pmid: 18612120].
546 Gorton C, Tabak YP, Hollenbeak CS, Jones JL, Derby KG, Johannes RS. Associations Between Public Reporting of Health Outcomes and In-Hospital Mortality. 2005 Jun 26–28. Hynes Convention Center, Boston, Massachusetts. Exclusion reason: Unable to obtain.
547 Goss JR, Maynard C, Aldea GS, et al. Effects of a statewide physician-led quality-improvement program on the quality of cardiac care. Am Heart J. May. 2006;151(5):1033-42. Exclusion reason: Wrong topic. [pmid: 16644333].
548 Grabowski DC. Consumer complaints and nursing home quality. Med Care. Feb. 2005;43(2):99-101. Exclusion reason: Background. [pmid: 15655422].
549 Grabowski DC. Nursing home report cards. Med Care. Oct. 2010;48(10):859-61. Exclusion reason: Background. [pmid: 20859136].
550 Graham J. Perspectives. Physician performance measurement initiatives gain ground. Med Health. Oct. 12. 1998;52(40). suppl 1–4. Exclusion reason: No outcome data. [pmid: 10186053].
551 Graham JD. Is reporting of quality scores worth refining?. Ann Intern Med. Jun. 3. 2008;148(11):883. Exclusion reason: Background. [pmid: 18519937].
552 Grammatico-Guillon L, Thiolet JM, Bernillon P, et al. Relationship between the prevalence of methicillin-resistant Staphylococcus aureus infection and indicators of nosocomial infection control measures: a population-based study in French hospitals. Infect Control Hosp Epidemiol. Sep. 2009;30(9):861-9. Exclusion reason: Wrong topic. [pmid: 19637957].
553 Grant A, Moshyk A, Diab H, et al. Integrating feedback from a clinical data warehouse into practice organisation. Int J Med Inform. Mar–Apr. 2006;75(3–4):232-9. Exclusion reason: Wrong topic. [pmid: 16153886].
554 Grant D. Information and sorting in the market for obstetrical services. Health Econ. Jul. 2005;14(7):703-19. Exclusion reason: Methods. [pmid: 15700300].
555 Gravelle H, Sivey P. Imperfect information in a quality-competitive hospital market. J Health Econ. Jul. 2010;29(4):524-35. Exclusion reason: Background. [pmid: 20573413].
556 Gray J. Recognising and dealing with poor performance amongst general medical practitioners: local arrangements in two English health districts. Qual Prim Care. 2005;13(1):29-36. Exclusion reason: Wrong topic.
557 Green J. Group proposes program to rate Medicaid managed care. AHA News. 1995;31(29):4. Exclusion reason: No outcome data.
558 Green J, Wintfeld N. Report cards on cardiac surgeons. Assessing New York State’s approach. N Engl J Med. May. 4. 1995;332(18):1229-32. Exclusion reason: Background. [pmid: 7700321].
559 Greenberg A, Angus H, Sullivan T, et al. Development of a set of strategy-based system-level cancer care performance indicators in Ontario, Canada. Int J Qual Health Care. Apr. 2005;17(2):107-14. Exclusion reason: Methods. [pmid: 15665069].
560 Greenberg L, D’Andrea G, Lorence D. Setting the public agenda for online health search: a white paper and action agenda. J Med Internet Res. Jun. 8. 2004;6(2):e18. Exclusion reason: Background. [pmid: 15249267].
561 Greenberg W. Information on quality will fuel competition. Healthspan. Jan. 1986;3(1):6-9. Exclusion reason: Background. [pmid: 10317695].
562 Greene FL, Gilkerson S, Tedder P, et al. The role of the hospital registry in achieving outcome benchmarks in cancer care. J Surg Oncol. Jun. 15. 2009;99(8):497-9. Exclusion reason: Wrong topic. [pmid: 19466739].
563 Greene J. Florida 2nd state to issue ‘report cards’. Mod Healthc. Mar. 4. 1996;26(10):80. Exclusion reason: No outcome data. [pmid: 10156349].
564 Greene J. Quality watch. Hosp Health Netw. 1997;71(18):16. Exclusion reason: Wrong topic. [pmid: 9435477].
565 Greene J. Holey hedis. (cover story). Hosp Health Netw. 1998;72(8):29. Exclusion reason: Background.
566 Greene J, Peters E. Medicaid consumers and informed decisionmaking. Health Care Financ Rev. Spring. 2009;30(3):25-40. Exclusion reason: Wrong topic. [pmid: 19544933].
567 Greene J, Peters E, Mertz CK, et al. Comprehension and choice of a consumer-directed health plan: an experimental study. Am J Manag Care. Jun. 2008;14(6):369-76. Exclusion reason: Wrong topic. [pmid: 18554075].
568 Greggains B. IT-enabled primary care: what quality gains might the NHS IT programme offer to patients?. Qual Prim Care. 2007;15(4):229-33. Exclusion reason: No outcome data.
569 Grimaldi PL. Monitoring managed care’s quality. Nurs Manage. Oct. 1996;27(10 Suppl):18-20. Exclusion reason: No outcome data. [pmid: 9287733].
570 Grimaldi PL. HEDIS 3.0 advances health plan accountability. Healthc Financ Manage. May. 1997;51(5):48. 50. 2. Exclusion reason: No outcome data. [pmid: 10167295].
571 Grimaldi PL. HEDIS is bigger and better. Nurs Manage. Jan. 21. 1997;28(1):17-2. Exclusion reason: No outcome data. [pmid: 9004678].
572 Grimaldi PL. Are managed care members satisfied?. Nursing management. 1997;28(6):12-5. Exclusion reason: No outcome data. [pmid: 9325902].
573 Grimaldi PL. HMOs must submit Medicare HEDIS. Nurs Manage. Mar. 1997;28(3):54-5. Exclusion reason: Background. [pmid: 9287766].
574 Grimaldi PL. HEDIS 3.0 updated for 1998. Nurs Manage. Apr. 1998;29(4):24-6. Exclusion reason: Background. [pmid: 9697489].
575 Grimaldi PL. New managed-care glossary. Nurs Manage. Nov. 1999;30(11):16-20. Exclusion reason: Background. [pmid: 10765264].
576 Grimshaw JM, Shirran L, Thomas R, et al. Changing provider behavior: an overview of systematic reviews of interventions. Med Care. Aug. 2001;39(8 Suppl 2):II2-45. Exclusion reason: Wrong topic. [pmid: 11583120].
577 Groce JB 3rd. Translating evidence-based guidelines into performance measures for venous thromboembolism and acute coronary syndrome. Am J Health Syst Pharm. Jun. 1. 2007;64(11 Suppl 7):S25-9. Exclusion reason: Wrong topic. [pmid: 17519443].
578 Groce JB. Improving the quality of care for venous thromboembolism and acute coronary syndrome: Using evidence-based guidelines and performance measures: Introduction. Am J Health Syst Pharm 2007. June. 1. 2007;64(11 Supplement 7):S2-4. Exclusion reason: Wrong topic.
579 Groenewoud AS. It’s your Choice! A Study of Search and Selection Processes, and the Use of Performance Indicators in Different Patient Groups. Erasmus University Rotterdam. 2008. http://hdl.handle.net/1765/21941. Exclusion reason: Methods.
580 Groenewoud AS, van Exel NJ, Berg M, et al. Building quality report cards for geriatric care in The Netherlands: using concept mapping to identify the appropriate “building blocks” from the consumer’s perspective. Gerontologist. Feb. 2008;48(1):79-92. Exclusion reason: Background. [pmid: 18381835].
581 Gruber T, Rudnitsky B. Can we be certain of PRO accuracy and accountability? Inaccurate “report cards” generated by medicare claims data as a marker for laboratory testing in diabetic patients. Am J Med Qual. Sep–Oct. 2002;17(5):171-4. Exclusion reason: Methods. [pmid: 12412943].
582 Haas-Wilson D. Quality signals and patient referrals in the market for social workers’ services. Adm Policy Ment Health Administration and Policy in Mental Health. 1990;18(1):55-64. Exclusion reason: Wrong topic.
583 Habel MA, Hogben M. Public health guidance dissemination via the Internet: expedited partner therapy. Sex Transm Dis. Jan. 2009;36(1):22-4. Exclusion reason: Wrong topic. [pmid: 19008774].
584 Haeske-Seeberg H, Piwernetz K. Benchmarking of public hospitals using the example of “4QD-Qualitatskliniken.de”. Z Evid Fortbild Qual Gesundhwes. 2011;105(5):401-3. Exclusion reason: No outcome data. [pmid: 21767801].
585 Hagland M. Provider profiling. Healthplan. Nov–Dec. 1998;39(6):32-7. Exclusion reason: No outcome data. [pmid: 10351345].
586 Halasyamani LK, Davis MM. Conflicting measures of hospital quality: ratings from “Hospital Compare” versus “Best Hospitals”. J Hosp Med. May. 2007;2(3):128-34. Exclusion reason: Background. [pmid: 17549759].
587 Halkias D, Harkiolakis N, Thurman P, et al. Internet use for health-related purposes among Greek consumers. Telemed J E Health. Apr. 2008;14(3):255-60. Exclusion reason: Wrong topic. [pmid: 18570549].
588 Hall LL, Mandersheid R, Kramer TL, et al. Report cards accelerate quality and accountability. Behav Healthc Tomorrow. Jun. 1996;5(3):57-62. Exclusion reason: Background. [pmid: 10158044].
589 Hall P, Morris M. Improving heart failure in home care with chronic disease management and telemonitoring. Home Healthc Nurse. Nov–Dec. 2010;28(10):606-17. quiz 18–9. Exclusion reason: No outcome data. [pmid: 21057230].
590 Hallam K. Physicians caught in the Web. Thanks to Internet, doc disciplinary data now just a mouse click away. Mod Healthc. Sep. 4. 2000;30(37):30-2. Exclusion reason: Background. [pmid: 11186522].
591 Halpern J. The measurement of quality of care in the Veterans Health Administration. Med Care. Mar. 1996;34(3 Suppl):MS55-68. Exclusion reason: Background. [pmid: 8598688].
592 Halpin HA, Milstein A, Shortell SM, et al. Mandatory public reporting of hospital-acquired infection rates: a report from California. Health Aff (Millwood). Apr. 2011;30(4):723-9. Exclusion reason: Background. [pmid: 21471494].
593 Halpin LS, Barnett SD, Henry LL, et al. Public health reporting: the United States perspective. Semin Cardiothorac Vasc Anesth. Sep. 2008;12(3):191-202. Exclusion reason: Background. [pmid: 18805854].
594 Hamblin R. Publishing ‘quality’ measures: how it works and when it does not?. Int J Qual Health Care. Aug. 2007;19(4):183-6. Exclusion reason: No outcome data. [pmid: 17569682].
595 Hamilton RA. The public’s demand for data. Mich Hosp. Jan. 1987;23(1):17-8. Exclusion reason: No outcome data. [pmid: 10280459].
596 Hammar PJ. The Cleveland Health Quality Choice Program: an evaluation of quality. Top Health Inf Manage. Aug. 1992;13(1):59-64. Exclusion reason: Background. [pmid: 10122872].
597 Hammond CB. HEDIS 2000: strategies for successful menopause management. Am J Manag Care. Sep. 2000;6(14 Suppl):S738-41. Exclusion reason: No outcome data. [pmid: 11184070].
598 Hanchak NA. Managed care, accountability, and the physician. Med Clin North Am. Mar. 1996;80(2):245-61. Exclusion reason: Background. [pmid: 8614172].
599 Hanchak NA, Harmon-Weiss SR, McDermott PD, et al. Medicare managed care and the need for quality measurement. Manag Care Q. Winter. 1996;4(1):1-12. Exclusion reason: Methods. [pmid: 10154062].
600 Handslip P, Swindells M, Allan C, et al. Information-clinical analysis. The data today. Real-time monitoring can alert trusts to clinical performance problems--before the star-ratings do it for them. Health Serv J. Sep. 2. 2004;114(5921). suppl 6–8. Exclusion reason: No outcome data. [pmid: 15461227].
601 Hannan EL, Chassin MR. Publicly Reporting Quality Information. JAMA. Jun. 2005;293(24):2999-3000. Exclusion reason: Background. [pmid: 15972560].
602 Hannan EL, Cozzens KS, Samadashvili Z, et al. Regulatory efforts to assess and improve the quality of pediatric cardiac surgery in New York State. Prog Pediatr Cardiol. 2011;32(2):111-9. Exclusion reason: No outcome data.
603 Hannan EL, Kilburn H Jr, O’Donnell JF, et al. Adult open heart surgery in New York State. An analysis of risk factors and hospital mortality rates. JAMA. Dec. 5. 1990;264(21):2768-74. Exclusion reason: Wrong topic. [pmid: 2232064].
604 Hannan EL, Siu AL, Kumar D, et al. The decline in coronary artery bypass graft surgery mortality in New York State. The role of surgeon volume. JAMA. Jan. 18. 1995;273(3):209-13. Exclusion reason: Wrong topic. [pmid: 7807659].
605 Hannan EL, Siu AL, Kumar D, et al. Assessment of coronary artery bypass graft surgery performance in New York. Is there a bias against taking high-risk patients?. Med Care. Jan. 1997;35(1):49-56. Exclusion reason: Methods. [pmid: 8998202].
606 Hanson K, Yip WC, Hsiao W. The impact of quality on the demand for outpatient services in Cyprus. Health Econ. Dec. 2004;13(12):1167-80. Exclusion reason: Wrong topic. [pmid: 15386672].
607 Hardee JT, Kasper IK. A Clinical Communication Strategy to Enhance Effectiveness and CAHPS Scores: The ALERT Model. Perm J. Summer. 2008;12(3):70-4. Exclusion reason: No outcome data. [pmid: 21331215].
608 Hardingham L. Informed decision-making and hospital report cards. AARN News Lett. May. 22. 1998;54(5):31. Exclusion reason: No outcome data. [pmid: 10594989].
609 Harman JS, Scholle SH, Ng JH, et al. Association of Health Plans’ Healthcare Effectiveness Data and Information Set (HEDIS) performance with outcomes of enrollees with diabetes. Med Care. Mar. 2010;48(3):217-23. Exclusion reason: Wrong topic. [pmid: 20125042].
610 Harolds JA, Merrill JK. The physician quality reporting initiative: what is it, will it increase health care quality, and should wide participation be encouraged?. Clin Nucl Med. Feb. 2011;36(2):118-20. Exclusion reason: Background. [pmid: 21220973].
611 Harper DL. The Cleveland Project: reporting on quality. Healthc Exec. May–Jun. 1998;13(3):68-9. Exclusion reason: Background. [pmid: 10178568].
612 Harrington C, Collier E, O’Meara J, et al. Federal and state nursing facility websites: just what the consumer needs?. Am J Med Qual. Jan–Feb. 2003;18(1):21-37. Exclusion reason: Background. [pmid: 12583642].
613 Harrington C, Mullan J, Woodruff LC, et al. Stakeholders’ opinions regarding important measures of nursing home quality for consumers. Am J Med Qual. May–Jun. 1999;14(3):124-32. Exclusion reason: Background. [pmid: 10446675].
614 Harrington C, O’Meara J, Collier E, et al. Nursing indicators of quality in nursing homes. A Web-based approach. J Gerontol Nurs. Oct. 2003;29(10):5-11. Exclusion reason: No outcome data. [pmid: 14558230].
615 Harrington C, Woolhandler S, Mullan J, et al. Does Investor-Ownership of Nursing Homes Compromise the Quality of Care?. Political and Economic Determinants of Population Health and Well-Being: Controversies and Developments. Amityville, NY, US. Baywood Publishing Co. 2004:245-55. Exclusion reason: Wrong topic.
616 Harris AH, Bowe T, Finney JW, et al. HEDIS initiation and engagement quality measures of substance use disorder care: impact of setting and health care specialty. Popul Health Manag. Aug. 2009;12(4):191-6. Exclusion reason: Methods. [pmid: 19663621].
617 Harris AH, Humphreys K, Bowe T, et al. Does meeting the HEDIS substance abuse treatment engagement criterion predict patient outcomes?. J Behav Health Serv Res. Jan. 2010;37(1):25-39. Exclusion reason: Wrong topic. [pmid: 18770044].
618 Harris AH, Reeder RN, Ellerbe LS, et al. Validation of the treatment identification strategy of the HEDIS addiction quality measures: concordance with medical record review. BMC Health Serv Res. 2011;11:73. Exclusion reason: Methods. [pmid: 21481264].
619 Harris JR, Caldwell B, Cahill K. Measuring the public’s health in an era of accountability: lessons from HEDIS. Health Plan Employer Data and Information Set. Am J Prev Med. Apr. 1998;14(3 Suppl):9-13. Exclusion reason: No outcome data. [pmid: 9566931].
620 Harris KM. The effect of unobserved plan attributes on the health plan choices of Twin Cities Medicare beneficiaries. University of Minnesota. 1996. Exclusion reason: Unable to obtain.
621 Harris N. Report cards, Part 2: How hospitals measure up. Bus Health. Aug. 1994;12(8):20-2. 4. Exclusion reason: No outcome data. [pmid: 10136770].
622 Harris N. How hospitals measure up: focusing on ways to evaluate performance, hospitals are following the lead of managed care by issuing report cards. Business & Health. 1994. 08. 1994:20+. Exclusion reason: Wrong topic. [pmid: 10136770].
623 Harris Y, Clauser SB. Achieving improvement through nursing home quality measurement. Health Care Financ Rev. Summer. 2002;23(4):5-18. Exclusion reason: Background. [pmid: 12500467].
624 Harris-Kojetin LD, Uhrig JD, Williams P, et al. The “choose with care system” - development of education materials to support informed Medicare health plan choices. J Health Commun. Mar. 2007;12(2):133-56. Exclusion reason: Background. [pmid: 17365356].
625 Hartig JR, Allison J. Physician performance improvement: an overview of methodologies. Clin Exp Rheumatol. Nov–Dec. 2007;25(6 Suppl 47):50-4. Exclusion reason: Background. [pmid: 18021507].
626 Hatahet MA, Bowhan J, Clough EA. Wisconsin Collaborative for Healthcare Quality (WCHQ): lessons learned. WMJ. 2004;103(3):45-8. Exclusion reason: Background. [pmid: 15217113].
627 Haustein T, Gastmeier P, Holmes A, et al. Use of benchmarking and public reporting for infection control in four high-income countries. Lancet Infect Dis. Jun. 2011;11(6):471-81. Exclusion reason: Background. [pmid: 21616457].
628 Hayashida K, Imanaka Y, Fukuda H. Measuring hospital-wide activity volume for patient safety and infection control: a multi-centre study in Japan. BMC Health Serv Res. 2007;7:140. Exclusion reason: Background. [pmid: 17764578].
629 Hays RD, Chong K, Brown J, et al. Patient reports and ratings of individual physicians: an evaluation of the DoctorGuide and Consumer Assessment of Health Plans Study provider-level surveys. Am J Med Qual. Sep–Oct. 2003;18(5):190-6. Exclusion reason: Methods. [pmid: 14604271].
630 Hayward RA. Access to clinically-detailed patient information: a fundamental element for improving the efficiency and quality of healthcare. Med Care. Mar. 2008;46(3):229-31. Exclusion reason: Wrong topic. [pmid: 18388837].
631 Head S. Keeping patients informed - is government policy working?. Clinical Risk. 2006;12(1):28-9. Exclusion reason: Wrong topic.
632 Headley DE. Perceived service quality : its measurement and relationship to consumer behavior in a medical care setting. 1989. Exclusion reason: Wrong topic.
633 Heidenreich PA, Lewis WR, LaBresh KA, et al. Hospital performance recognition with the Get With The Guidelines Program and mortality for acute myocardial infarction and heart failure. Am Heart J. Oct. 2009;158(4):546-53. Exclusion reason: Methods. [pmid: 19781413].
634 Heikkinen K, Suomi R, Jaaskelainen M, et al. The creation and evaluation of an ambulatory orthopedic surgical patient education web site to support empowerment. Comput Inform Nurs. Sep–Oct. 2010;28(5):282-90. Exclusion reason: Wrong topic. [pmid: 20736726].
635 Henderson A, Henderson S. Provision of a surgeon’s performance data for people considering elective surgery. Cochrane Database Syst Rev. 2010;(11):CD006327. Exclusion reason: Background. [pmid: 21069688].
636 Henderson JT, Hudson Scholle S, Weisman CS, et al. The role of physician gender in the evaluation of the National Centers of Excellence in Women’s Health: test of an alternate hypothesis. Womens Health Issues. Jul–Aug. 2004;14(4):130-9. Exclusion reason: Wrong topic. [pmid: 15324872].
637 Hess C, Schwartz S, Rosenthal J, et al. States’ roles in shaping high performance health systems. New York, NY. Commonwealth Fund. 2008. Exclusion reason: Background.
638 Heuer AJ. Hospital accreditation and patient satisfaction: testing the relationship. J Healthc Qual. Jan–Feb. 2004;26(1):46-51. Exclusion reason: Methods. [pmid: 14763320].
639 Hibbard JH. Use of outcome data by purchasers and consumers: new strategies and new dilemmas. Int J Qual Health Care. Dec. 1998;10(6):503-8. Exclusion reason: No outcome data. [pmid: 9928589].
640 Hibbard JH. Moving toward a more patient-centered health care delivery system. Health Aff (Millwood). Suppl Variation. 2004:VAR133-5. Exclusion reason: Background. [pmid: 15471780].
641 Hibbard JH. What can we say about the impact of public reporting? Inconsistent execution yields variable results. Ann Intern Med. Jan. 15. 2008;148(2):160-1. Exclusion reason: Background. [pmid: 18195340].
642 Hibbard JH, Peters E. Supporting informed consumer health care decisions: data presentation approaches that facilitate the use of information in choice. Annu Rev Public Health. 2003;24:413-33. Exclusion reason: Background. [pmid: 12428034].
643 Hibbard JH, Slovic P, Jewett JJ. Informing consumer decisions in health care: implications from decision-making research. Milbank Q. 1997;75(3):395-414. Exclusion reason: Background. [pmid: 9290635].
644 Hibbard JH, Stockard J, Tusler M. It isn’t just about choice: the potential of a public performance report to affect the public image of hospitals. Med Care Res Rev. Jun. 2005;62(3):358-71. Exclusion reason: Background. [pmid: 15894709].
645 Hibbard JH, Weeks EC. Does the dissemination of comparative data on physician fees affect consumer use of services?. Med Care. Dec. 1989;27(12):1167-74. Exclusion reason: Wrong topic. [pmid: 2512462].
646 Hill JW, Spoeri RK. How does HEDIS affect quality improvement strategies in an HMO?. Manag Care Interface. Nov. 1997;10(11):60-5. Exclusion reason: Background. [pmid: 10174756].
647 Hill SA, Zimmerman MK, Fox M. Rational Choice in Medicaid Managed Care: A Critique. J Poverty. 2002;6:37-60. Exclusion reason: Wrong topic.
648 Hill SC, Wooldridge J. Informed participation in TennCare by people with disabilities. J Health Care Poor Underserved. Nov. 2006;17(4):851-75. Exclusion reason: Wrong topic. [pmid: 17242535].
649 Hillman AL. Disclosing information and treating patients as customers. A review of selected issues. HMO Pract. Mar–Apr. 1991;5(2):37-41. Exclusion reason: No outcome data. [pmid: 10112689].
650 Hiltunen KA. HEDIS 1999 effectiveness of care measures: implementation issues. J Healthc Qual. Sep–Oct. 1999;21(5):32-5. 54. 5. Exclusion reason: Background. [pmid: 10620883].
651 Hinchey JA, et al. In-hospital stroke mortality and quality of care: The Cleveland health quality choice model. 1997 Apr 12–19. 12107 Insurance Way, Hagerstown, MD 21740. Lippincott-Raven Publishers. World Meeting Number 972 0103. Exclusion reason: Wrong topic.
652 Hirth RA, Banaszak-Holl JC, Fries BE, et al. Does quality influence consumer choice of nursing homes? Evidence from nursing home to nursing home transfers. Inquiry. Winter. 2003;40(4):343-61. Exclusion reason: Background. [pmid: 15055834].
653 Hochadel M, Schneider S, Gottwik M, et al. Evaluation of hospitals regarding outcomes and baseline risk -- an application to percutaneous coronary intervention. Clin Res Cardiol. Jul. 2007;96(7):502-7. Exclusion reason: Methods. [pmid: 17534567].
654 Hochhauser M. Can consumers understand managed care report cards?. Manag Care Interface. Nov. 1998;11(11):91-5. Exclusion reason: No outcome data. [pmid: 10187422].
655 Hochhauser M. Why patients have little patience for report cards. Manag Care. Mar. 1998;7(3):31-2. 4. Exclusion reason: Background. [pmid: 10177958].
656 Hochhauser M. Health maintenance organization report cards: communication strategies versus consumer abilities. Manag Care Q. Summer. 1999;7(3):75-82. Exclusion reason: No outcome data. [pmid: 10620962].
657 Hochhauser M. Grading the graders. How to make HMO report cards more useful to consumers. Healthplan. Mar–Apr. 2000;41(2):51-5. Exclusion reason: Background. [pmid: 10977689].
658 Hochhauser M. Lousy report card? Most consumers don’t pay attention. Manag Care Q. Summer. 2003;11(3):28-9. Exclusion reason: No outcome data. [pmid: 14983649].
659 Hochhauser M. Will consumers pay more or less for above-average health care?. Manag Care Interface. Aug. 2006;19(8):23-5. Exclusion reason: No outcome data. [pmid: 16933523].
660 Hodgson ES, Simpson L, Lannon CM. Principles for the development and use of quality measures. Pediatrics. Feb. 2008;121(2):411-8. Exclusion reason: Wrong topic. [pmid: 18245433].
661 Hofer TP, Hayward RA, Greenfield S, et al. The unreliability of individual physician “report cards” for assessing the costs and quality of care of a chronic disease. JAMA. Jun. 9. 1999;281(22):2098-105. Exclusion reason: Methods. [pmid: 10367820].
662 Hoffman J. Awash in information, patients face a lonely, uncertain road. NY Times (Print). Aug. 14. 2005:A1. A18. A9. Exclusion reason: No outcome data. [pmid: 16134278].
663 Holmboe ES, Wang Y, Meehan TP, et al. Association between maintenance of certification examination scores and quality of care for medicare beneficiaries. Arch Intern Med. Jul. 14. 2008;168(13):1396-403. Exclusion reason: Wrong topic. [pmid: 18625919].
664 Honbo L, Loke M. An assessment of Hawaii QUEST medical plans performance using Medicaid HEDIS measures, 1996–1997. Hawaii Med J. Oct. 4. 1998;57(10):662-70. 72. 3. Exclusion reason: PR as outcome. [pmid: 9844302].
665 Hong T. Internet health information in the patient-provider dialogue. Cyberpsychol Behav. Oct. 2008;11(5):587-9. Exclusion reason: Wrong topic. [pmid: 18771392].
666 Hope S, Williams AE, Lunn D. Information provision to cancer patients: a practical example of identifying the need for changes in practice from the Dorset Cancer Centre. Eur J Cancer Care (Engl). Dec. 2000;9(4):238-42. Exclusion reason: Wrong topic. [pmid: 11829372].
667 Horn SD. Performance measures and clinical outcomes. JAMA. 2006;296(22):2731-2. Exclusion reason: No outcome data. [pmid: 17164460].
668 Hoskins EJ, Abdul al-Hamid Noor F, Ghasib SH. Implementing TQM in a military hospital in Saudi Arabia. Jt Comm J Qual Improv. Aug. 1994;20(8):454-64. Exclusion reason: Wrong topic. [pmid: 8000483].
669 Houston TK, Ehrenberger HE. The potential of consumer health informatics. Semin Oncol Nurs. Feb. 2001;17(1):41-7. Exclusion reason: Wrong topic. [pmid: 11236364].
670 Howard DH. Hospital Quality and Selective Contracting: Evidence from. Kidney Transplantation Forum Health Econ Policy. 2008;11(2):2. Exclusion reason: Wrong topic. [pmid: 19079762].
671 Howard LM. Multidisciplinary Quality Assessment: the Case of a Child Development Team, Part 3. The British journal of occupational therapy. 1994;57(11):437. Exclusion reason: Wrong topic.
672 Howell MD. A 37-year-old man trying to choose a high-quality hospital: review of hospital quality indicators. JAMA. Dec. 2. 2009;302(21):2353-60. Exclusion reason: No outcome data. [pmid: 19887653].
673 Howgill M, Blaza J, Cunningham L, et al. The ratings game. How important are hospital rankings to consumers? Interview by Joyce Jensen. Mark Health Serv. Spring. 2004;24(1):40-5. Exclusion reason: Background. [pmid: 15008008].
674 Hudson JC, Watts E. Hispanic preferences for health care providers and health care information. Health Mark Q. 1996;14(1):67-83. Exclusion reason: Background. [pmid: 10163026].
675 Hudson T. Service means business Low rates once ensured lots of patients. Not anymore. Hosp Health Netw. Mar. 5. 1998;72(5):30-2. Exclusion reason: No outcome data. [pmid: 9520802].
676 Huff C. Good is never enough for P4P. Hosp Health Netw. Jun. 2008;82(6):26-30. 2. Exclusion reason: Background. [pmid: 18666732].
677 Huffman J, Miller M, Simmons C, et al. Measuring quality in hospitals: is there a difference between for-profits and not-for-profits?. Qual Manag Health Care. Summer. 1999;7(4):51-9. Exclusion reason: Background. [pmid: 10557399].
678 Hughes D. Innovation + incentives + HEDIS = high immunization rates. Manag Care. Sep. 1997;6(9):99-106. Exclusion reason: Wrong topic. [pmid: 10173832].
679 Hughes RG, Lee DE. Public information on private practice: the availability of physician inpatient data. Hosp Health Serv Adm. Spring. 1990;35(1):55-69. Exclusion reason: No outcome data. [pmid: 10103692].
680 Humphreys H, Cunney R. Performance indicators and the public reporting of healthcare-associated infection rates. Clin Microbiol Infect. Oct. 2008;14(10):892-4. Exclusion reason: No outcome data. [pmid: 18828850].
681 Hungate RW. Purchaser quality measures: progressing from wants to needs. Jt Comm J Qual Improv. Jul. 1994;20(7):381-7. Exclusion reason: Background. [pmid: 7951768].
682 Hunt S. Data management in home care: Using data to drive acute care hospitalizations. Home Health Care Manage Pract Home Health Care Management and Practice. 2008;20(2):175-9. Exclusion reason: Wrong topic.
683 Huser V, Rocha RA. Graphical modeling of HEDIS quality measures and prototyping of related decision support rules to accelerate improvement. AMIA Annu Symp Proc. 2007;986. Exclusion reason: Wrong topic. [pmid: 18694086].
684 Inlander CB. Consumers can put health care data to good use. Bus Health. May. 1987;4(7):26-7. Exclusion reason: No outcome data. [pmid: 10281580].
685 Ireson CI, Ford MA, Hower JM, et al. Outcome report cards: a necessity in the health care market. Arch Surg. Jan. 2002;137(1):46-51. Exclusion reason: Background. [pmid: 11772214].
686 Isaac T, Zaslavsky AM, Cleary PD, et al. The relationship between patients’ perception of care and measures of hospital quality and safety. Health Serv Res. Aug. 2010;45(4):1024-40. Exclusion reason: Methods. [pmid: 20528990].
687 Isaacs SL. Consumer’s information needs: results of a national survey. Health Aff (Millwood). Winter. 1996;15(4):31-41. Exclusion reason: Wrong topic. [pmid: 8991252].
688 Ito H, Sugawara H. Relationship between accreditation scores and the public disclosure of accreditation reports: a cross sectional study. Qual Saf Health Care. Apr. 2005;14(2):87-92. Exclusion reason: PR as outcome. [pmid: 15805452].
689 Izakovic M. New trends in the management of inpatients in U.S. hospitals--quality measurements and evidence-based medicine in practice. Bratisl Lek Listy. 2007;108(3):117-21. Exclusion reason: Wrong topic. [pmid: 17682536].
690 Newest JA. HEDIS tool paves way for sharing of health care data. AHA News. 1997;33(12):4. Exclusion reason: Wrong topic.
691 Jabaaij L, Visscher S, Verheij R, et al. Verbeter uw verslaglegging, gebruik de EPD-scan-h. To improve your reporting, use the EPD-scan-h. Huisarts Wet. Huisarts en Wetenschap. 2009;52(5):240-6. Exclusion reason: Wrong topic.
692 Jackson EA, Axelsen KJ. Medicare Part D formulary coverage since program inception: are beneficiaries choosing wisely?. Am J Manag Care. Nov. 2008;14(11 Suppl):SP29-35. Exclusion reason: Wrong topic. [pmid: 18991478].
693 Jacobson B, Mindell J, McKee M. Hospital mortality league tables. BMJ. Apr. 12. 2003;326(7393):777-8. Exclusion reason: No outcome data. [pmid: 12689953].
694 Jaklevic MC. Hospitals tout data with report cards. Mod Healthc. May. 8. 1995;25(19):68. Exclusion reason: No outcome data. [pmid: 10142266].
695 Jaklevic MC. Mich. association reports on hospital performance. Mod Healthc. May. 27. 1996;26(22):23. Exclusion reason: No outcome data. [pmid: 10157508].
696 Jaklevic MC. Marketers gear up for quality ratings. Mod Healthc. Apr. 1. 1996;26(14):49. Exclusion reason: No outcome data. [pmid: 10157113].
697 Jaklevic MC. Hospital report-card model in peril. Mod Healthc. Jan. 18. 1999;29(3):14-5. Exclusion reason: No outcome data. [pmid: 10345441].
698 Jaklevic MC. Well-kept secret. Despite a lack of clearly defined standards, hospitals are under increasing pressure to publicly report charity-care figures. Mod Healthc. Jun. 21. 2004;34(25):6-7. 16. 1. Exclusion reason: Wrong topic. [pmid: 15239521].
699 James N, Daniels H, Rahman R, et al. A study of information seeking by cancer patients and their carers. Clin Oncol (R Coll Radiol). Jun. 2007;19(5):356-62. Exclusion reason: Wrong topic. [pmid: 17399963].
700 Jayawardhana J, Welton JM, Lindrooth R. Adoption of national quality forum safe practices by Magnet(R) hospitals. J Nurs Adm. Sep. 2011;41(9):350-6. Exclusion reason: Wrong topic. [pmid: 21881440].
701 Jenkinson C, Coulter A, Bruster S, et al. Factors relating to patients’ reports about hospital care for coronary heart disease in England. J Health Serv Res Policy. Apr. 2003;8(2):83-6. Exclusion reason: No outcome data. [pmid: 12820669].
702 Jensen CK, Marino PB, Clough JD. A consumer guide for marketing medical services: one institution’s experience. QRB Qual Rev Bull. May. 1992;18(5):164-71. Exclusion reason: PR as outcome. [pmid: 1614697].
703 Jensen J. Most physicians believe patients obtain healthcare information from mass media. Mod Healthc. Sep. 11. 110. 1987;17(19):4. Exclusion reason: Wrong topic. [pmid: 10283590].
704 Jensen J. The Ratings Game. Spring. 2004. 2004;24:40-5. Exclusion reason: No outcome data.
705 Jha AK, Orav EJ, Epstein AM. Public reporting of discharge planning and rates of readmissions. N Engl J Med. Dec. 31. 2009;361(27):2637-45. Exclusion reason: Methods. [pmid: 20042755].
706 Jha AK, Orav EJ, Ridgway AB, et al. Does the Leapfrog program help identify high-quality hospitals?. Jt Comm J Qual Patient Saf. Jun. 2008;34(6):318-25. Exclusion reason: Wrong topic. [pmid: 18595377].
707 Jha AK, Orav EJ, Zheng J, et al. Patients’ perception of hospital care in the United States. N Engl J Med. Oct. 30. 2008;359(18):1921-31. Exclusion reason: Methods. [pmid: 18971493].
708 Jin GZ. Competition and disclosure incentives: an empirical study of HMOs. Rand J Econ. Spring. 2005;36(1):93-112. Exclusion reason: PR as outcome. [pmid: 15900649].
709 Johnson AJ, Easterling D, Williams LS, et al. Insight from patients for radiologists: improving our reporting systems. J Am Coll Radiol. Nov. 2009;6(11):786-94. Exclusion reason: Wrong topic. [pmid: 19878886].
710 Johnson C, Horton S. Owning up to errors: Put an end to the blame game Why would a hospital routinely disclose errors to patients and their families? The answer may surprise you. Nursing -Jenktown Then Horsham Then Springhouse- International Edition-. 2001;31:54-5. Exclusion reason: Wrong topic.
711 Johnsson J. CEOs: mortality data no help to consumers. Hospitals. Oct. 5. 1990;64(19):61. Exclusion reason: No outcome data. [pmid: 2401495].
712 Jones KR, Fink R, Vojir C, et al. Translation research in long-term care: improving pain management in nursing homes. Worldviews Evid Based Nurs. 2004;1(Suppl 1):S13-20. Exclusion reason: Wrong topic. [pmid: 17129330].
713 Jones N 3rd, Jones SL, Miller NA. The Medicare Health Outcomes Survey program: overview, context, and near-term prospects. Health Qual Life Outcomes. Jul. 12. 2004;2:33. Exclusion reason: Background. [pmid: 15248895].
714 Jones RB, Anasetti C, Appel P, et al. ASBMT committee report: white paper on measurement of quality outcomes. Biol Blood Marrow Transplant. May. 2006;12(5):594-7. Exclusion reason: Wrong topic. [pmid: 16635795].
715 Joynt K, Chandra A, Jha A. Mandatory national public reporting did not reduce mortality for acute myocardial infarction and heart failure. J Am Coll Cardiol. 2011;57(14):E1218. Exclusion reason: Unable to obtain.
716 Jung K. Incentives for Voluntary Disclosure of Quality Information in HMO Markets. Journal of Risk and Insurance. 2010;77(1):183-210. Exclusion reason: Wrong topic.
717 Jung K, Feldman R, Scanlon D. Where would you go for your next hospitalization?. J Health Econ. Jul. 2011;30(4):832-41. Exclusion reason: Wrong topic. [pmid: 21665300].
718 Kakkar A, Jacobson BC. Internet-Based Education and “Physician Compare” Websites May Discriminate Against Older and Disadvantaged Patient Populations. Gastroenterology. 2011;140(5):S-722. Exclusion reason: Wrong topic.
719 Kane RJ. Information is the key to patient empowerment. Ann Health Law. 2002;11:25-44. table of contents. Exclusion reason: Wrong topic. [pmid: 12430381].
720 Kang NM, Kim S, Hong S, et al. The evaluation criteria of internet health information. Stud Health Technol Inform. 2006;122:886. Exclusion reason: Wrong topic. [pmid: 17102445].
721 Kanwal F, Kramer JR, Buchanan P, et al. The quality of care provided to patients with cirrhosis and ascites (abstracts). Hepatology. 2011;54(S1):408A. Exclusion reason: Wrong topic.
722 Kaplan JG. The report card’s role in health care decision making: Part I. Manag Care Interface. Dec. 1997;10(12):61-5. Exclusion reason: Background. [pmid: 10176748].
723 Kaplan JG. Report cards: Part II--Providers rating MCOs. Manag Care Interface. Jan. 1998;11(1):60-4. Exclusion reason: No outcome data. [pmid: 10178973].
724 Kaufman CS. Validating quality breast care: three new validation programs for 2007. Am J Surg. Oct. 2007;194(4):515-7. Exclusion reason: Wrong topic. [pmid: 17826069].
725 Kaufman CS, Shockney L, Rabinowitz B, et al. National Quality Measures for Breast Centers (NQMBC): a robust quality tool: breast center quality measures. Ann Surg Oncol. Feb. 2010;17(2):377-85. Exclusion reason: Wrong topic. [pmid: 19834768].
726 Kazis LE, Selim A, Rogers W, et al. Dissemination of methods and results from the veterans health study: final comments and implications for future monitoring strategies within and outside the veterans healthcare system. J Ambul Care Manage. Oct–Dec. 2006;29(4):310-9. Exclusion reason: Methods. [pmid: 16985389].
727 Kelley J. Heart care for minority patients seen improving under ‘Expecting Success’. AHA News. 2007;43(10):6. Exclusion reason: Wrong topic.
728 Kelly A, Thompson JP, Tuttle D, et al. Public reporting of quality data for stroke: is it measuring quality?. Stroke. Dec. 2008;39(12):3367-71. Exclusion reason: Methods. [pmid: 18772446].
729 Kemper DW, Mettler M. The age wave: knowledgeable and demanding and very, very large. Manag Care Q. Summer. 2002;10(3):52-4. Exclusion reason: No outcome data. [pmid: 12476665].
730 Kenkel P. The new HEDIS boon or burden?. Health Syst Rev. Nov–Dec. 1996;29(6):17-9. Exclusion reason: No outcome data. [pmid: 10167140].
731 Kenkel PJ. Cleveland initiative hands out report cards. Mod Healthc. May. 3. 1993;23(18):11. Exclusion reason: No outcome data. [pmid: 10125845].
732 Kenkel PJ. Health plans face pressure to find ‘report care’ criteria that will make the grade. Mod Healthc. Jan. 10. 1994;24(2):41-2. Exclusion reason: No outcome data. [pmid: 10130898].
733 Kenkel PJ. New England HMOs, employers proceed with ‘report card’. Mod Healthc. Apr. 11. 1994;24(15):18. Exclusion reason: No outcome data. [pmid: 10132901].
734 Kennedy DM, Caselli RJ, Berry LL. A roadmap for improving healthcare service quality. J Healthc Manag. Nov–Dec. 2011;56(6):385-400. discussion -2. Exclusion reason: No outcome data. [pmid: 22201201].
735 Kennedy K, Mirmirani S, Spivack R. Continuous quality improvement in health maintenance organizations: an application of the HEDIS model. Int J Health Care Qual Assur. 1996;9(4):4-9. Exclusion reason: Wrong topic. [pmid: 10159577].
736 Kennedy P, Pronovost P. Shepherding change: how the market, healthcare providers, and public policy can deliver quality care for the 21st century. Crit Care Med. Mar. 2006;34(3 Suppl):S1-6. Exclusion reason: Wrong topic. [pmid: 16477197].
737 Keogh B, Spiegelhalter D, Bailey A, et al. The legacy of Bristol: public disclosure of individual surgeons’ results. BMJ. Aug. 21. 2004;329(7463):450-4. Exclusion reason: Background. [pmid: 15321906].
738 Keogh BE. Logistic, additive or historical: is EuroSCORE an appropriate model for comparing individual surgeons’ performance?. Heart. Dec. 2006;92(12):1715-6. Exclusion reason: Methods. [pmid: 17005714].
739 Keogh BE, Bridgewater B. Toward public disclosure of surgical results: experience of cardiac surgery in the United Kingdom. Thorac Surg Clin. Aug. 2007;17(3):403-11. vii. Exclusion reason: Background. [pmid: 18072362].
740 Kernich CA, Creighton FA. Academia and the medical group practice interface: the 2003 Institute of Medicine quality report and medication management. J Med Pract Manage. Jul–Aug. 2006;22(1):45-8. Exclusion reason: Background. [pmid: 16986641].
741 Kernisan LP, Lee SJ, Boscardin WJ, et al. Association between hospital-reported Leapfrog Safe Practices Scores and inpatient mortality. JAMA. Apr. 1. 2009;301(13):1341-8. Exclusion reason: Methods. [pmid: 19336709].
742 Kerr EA, McGlynn EA, Adams J, et al. Profiling the quality of care in twelve communities: results from the CQI study. Health Aff (Millwood). May–Jun. 2004;23(3):247-56. Exclusion reason: Wrong topic. [pmid: 15160823].
743 Kertesz L. Kaiser releases HEDIS information. Mod Healthc. Jul. 11. 1994;24(28):6. Exclusion reason: No outcome data. [pmid: 10135043].
744 Kertesz L. Calif. report card uses uniform data. Mod Healthc. Jun. 17. 1996;26(25):102. Exclusion reason: No outcome data. [pmid: 10157994].
745 Kertesz L. Report card given an ‘F’. Groups dispute study critical of managed behavioral care. Mod Healthc. Oct. 13. 1997;27(41):64. Exclusion reason: No outcome data. [pmid: 10173651].
746 Kesselheim AS, Ferris TG, Studdert DM. Will physician-level measures of clinical performance be used in medical malpractice litigation?. JAMA. Apr. 19. 2006;295(15):1831-4. Exclusion reason: Wrong topic. [pmid: 16622145].
747 Ketelaar N, Faber M, Flottorp S, et al. The effectiveness of the public release of performance data in changing consumer, healthcare professional or organisational behaviour. Cochrane Database of Systematic Reviews. 2009;(1). Exclusion reason: No outcome data.
748 Ketelaar NA, Faber MJ, Flottorp S, et al. Public release of performance data in changing the behaviour of healthcare consumers, professionals or organisations. Cochrane Database Syst Rev. 2011;11:CD004538. Exclusion reason: Background. [pmid: 22071813].
749 Keyhani S, Siu AL. The Underuse of Overuse Research Health Serv Res. 2008;43(6):1923-30. Exclusion reason: Wrong topic.
750 Khanduja K, Scales DC, Adhikari NK. Pay for performance in the intensive care unit--opportunity or threat?. Crit Care Med. Mar. 2009;37(3):852-8. Exclusion reason: Wrong topic. [pmid: 19237887].
751 Khanna V, Silverman H, Schwartz J. Disclosure of operating practices by managed-care organizations to consumers of healthcare: obligations of informed consent. J Clin Ethics. Fall. 1998;9(3):291-6. Exclusion reason: No outcome data. [pmid: 10029829].
752 Khare RK, Courtney DM, Kang R, et al. The relationship between the emergent primary percutaneous coronary intervention quality measure and inpatient myocardial infarction mortality. Acad Emerg Med. Aug. 2010;17(8):793-800. Exclusion reason: Wrong topic. [pmid: 20670315].
753 Kirchheimer B. The patient’s perspective. Hospitals must report patient-satisfaction data or face a financial hit; for many it’s just business as usual, for others it poses some challenges. Mod Healthc. Jul. 23. 2007;37(29):26-8. Exclusion reason: No outcome data. [pmid: 17844794].
754 Kleger GR, Fassler E. Can circuit lifetime be a quality indicator in continuous renal replacement therapy in the critically ill?. Int J Artif Organs. Mar. 2010;33(3):139-46. Exclusion reason: Wrong topic. [pmid: 20383858].
755 Klein AA, Nashef SA. Perception and reporting of cardiac surgical performance. Semin Cardiothorac Vasc Anesth. Sep. 2008;12(3):184-90. Exclusion reason: No outcome data. [pmid: 18805853].
756 Klein DH. The power of ‘report cards’. Inquiry. Winter94/95. 1994;31(4):361. Exclusion reason: No outcome data.
757 Klein LW, Ho KK, Singh M, et al. Quality assessment and improvement in interventional cardiology: a Position Statement of the Society of Cardiovascular Angiography and Interventions, Part II: public reporting and risk adjustment. Catheter Cardiovasc Interv. Oct. 1. 2011;78(4):493-502. Exclusion reason: No outcome data. [pmid: 21547998].
758 Knapp C. Bronson Methodist Hospital: journey to excellence in quality and safety. Jt Comm J Qual Patient Saf. Oct. 2006;32(10):556-63. Exclusion reason: No outcome data. [pmid: 17066993].
759 Kobak KA, Taylor L, Katzelnick DJ, et al. Antidepressant medication management and Health Plan Employer Data Information Set (HEDIS) criteria: reasons for nonadherence. J Clin Psychiatry. Aug. 2002;63(8):727-32. Exclusion reason: Wrong topic. [pmid: 12197454].
760 Koch S, Hagglund M. Health informatics and the delivery of care to older people. Maturitas. Jul. 20. 2009;63(3):195-9. Exclusion reason: Background. [pmid: 19487092].
761 Koizumi N, Rothbard AB, Kuno E. Distance matters in choice of mental health program: policy implications for reducing racial disparities in public mental health care. Adm Policy Ment Health. Nov. 2009;36(6):424-31. Exclusion reason: Wrong topic. [pmid: 19653093].
762 Kolstad JT, Chernew ME. Quality and consumer decision making in the market for health insurance and health care services. Med Care Res Rev. Feb. 2009;66(1 Suppl):28S-52S. Exclusion reason: Background. [pmid: 19029288].
763 Konetzka RT, Werner RM. Applying market-based reforms to long-term care. Health Aff (Millwood). Jan–Feb. 2010;29(1):74-80. Exclusion reason: Background. [pmid: 20048363].
764 Konig A, Geraedts M. Development of the quality of surgical gynaecological care in the State of Hesse, Germany under external quality assurance. Gesundheitswesen. Feb. 2006;68(2):128-33. Exclusion reason: Wrong topic. [pmid: 16482494].
765 Koska MT. Are severity data an effective consumer tool?. Hospitals. Aug. 20. 1989;63(16):24. Exclusion reason: No outcome data. [pmid: 2759587].
766 Krakauer H, Lin MJ, Schone EM, et al. ‘Best clinical practice’: assessment of processes of care and of outcomes in the US Military Health Services System. J Eval Clin Pract. Feb. 1998;4(1):11-29. Exclusion reason: Wrong topic. [pmid: 9524909].
767 Kronebusch K. Quality information and fragmented markets: patient responses to hospital volume thresholds. J Health Polit Policy Law. Oct. 2009;34(5):777-827. Exclusion reason: Wrong topic. [pmid: 19778932].
768 Krumholz HM, Normand SL. Public reporting of 30-day mortality for patients hospitalized with acute myocardial infarction and heart failure. Circulation. Sep. 23. 2008;118(13):1394-7. Exclusion reason: No outcome data. [pmid: 18725492].
769 Krumholz HM, Rathore SS, Chen J, et al. Evaluation of a consumer-oriented internet health care report card: the risk of quality ratings based on mortality data. JAMA. Mar. 13. 2002;287(10):1277-87. Exclusion reason: Methods. [pmid: 11886319].
770 Krupat E, Hsu J, Irish J, et al. Matching patients and practitioners based on beliefs about care: results of a randomized controlled trial. Am J Manag Care. Nov. 2004;10(11 Pt 1):814-22. Exclusion reason: Wrong topic. [pmid: 15623271].
771 Krupski TL. Standardization of reporting surgical complications--are we ready?. J Urol. May. 2010;183(5):1671-2. Exclusion reason: No outcome data. [pmid: 20299062].
772 Importance of stratification when measuring quality of care: Results from the Project for an Ontario Women’s Health Evidence-Based Report Card (POWER) study. 2009 May 29 – Jun 2. Orange County Convention Center, Orlando, Florida. 45th Annual Meeting of the American Society of Clinical Oncology. Exclusion reason: Methods.
773 Kuhlthau K, Walker DK, Perrin JM, et al. Assessing managed care for children with chronic conditions. Health Aff (Millwood) 1998. July. 1. 1998;17(4):42-52. Exclusion reason: No outcome data.
774 Kurtzman ET, Dawson EM, Johnson JE. The current state of nursing performance measurement, public reporting, and value-based purchasing. Policy Polit Nurs Pract. Aug. 2008;9(3):181-91. Exclusion reason: Background. [pmid: 18829604].
775 Labig C. Bad Measures Don’t Make Good Medicine: The Ethical Implications of Unreliable and Invalid Physician Performance Measures. J Bus Ethics. 2009;88(2):287-95. Exclusion reason: Background.
776 Lagu T, Lindenauer PK. Putting the public back in public reporting of health care quality. JAMA. Oct. 20. 2010;304(15):1711-2. Exclusion reason: No outcome data. [pmid: 20959582].
777 Lake ET, Shang J, Klaus S, et al. Patient falls: Association with hospital Magnet status and nursing unit staffing. Res Nurs Health. Oct. 2010;33(5):413-25. Exclusion reason: Wrong topic. [pmid: 20824686].
778 Lakhani A, Coles J, Eayres D, et al. Creative use of existing clinical and health outcomes data to assess NHS performance in England: Part 1--performance indicators closely linked to clinical care. BMJ. Jun. 18. 2005;330(7505):1426-31. Exclusion reason: Methods. [pmid: 15961815].
779 Lako CJ, Rosenau P. Demand-driven care and hospital choice. Dutch health policy toward demand-driven care: results from a survey into hospital choice. Health Care Anal. Mar. 2009;17(1):20-35. Exclusion reason: Background. [pmid: 18642083].
780 Lambert SD, Loiselle CG. Health information seeking behavior. Qual Health Res. Oct. 2007;17(8):1006-19. Exclusion reason: Background. [pmid: 17928475].
781 Lam-Po-Tang J, McKay D. Dr Google, MD: a survey of mental health-related internet use in a private practice sample. Australas Psychiatry. Apr. 2010;18(2):130-3. Exclusion reason: Wrong topic. [pmid: 20175669].
782 Landon BE, Rosenthal MB, Normand SL, et al. Quality monitoring and management in commercial health plans. Am J Manag Care. Jun. 2008;14(6):377-86. Exclusion reason: Background. [pmid: 18554076].
783 Lane A, Baggot M, Power M, et al. Benchmarking outcome in ICU. Ir Med J. Jul–Aug. 2005;98(7):213-5. Exclusion reason: Wrong topic. [pmid: 16185019].
784 Lang NM. Quality of health care for older people in America : a review of nursing studies. Kansas City, Mo. American Nurses Association. 1990. Exclusion reason: Wrong topic.
785 Langiano T, Martin SJ. Quality improvement measures adopted by the Italian National Health Service. Int J Artif Organs. Nov. 1998;21(11):726-9. Exclusion reason: Background. [pmid: 9894750].
786 Lansky D. Measuring what matters to the public. Health Aff (Millwood). Jul–Aug. 1998;17(4):40-1. Exclusion reason: No outcome data. [pmid: 9691548].
787 LaPar DJ, Hennessy S, Fonner E, et al. Does urgent or emergent status influence choice in mitral valve operations? An analysis of outcomes from the Virginia Cardiac Surgery Quality Initiative. Ann Thorac Surg. Jul. 2010;90(1):153-60. Exclusion reason: Unable to obtain. [pmid: 20609766].
788 Lauer CS. HCAHPS no hiccup. Mod Healthc. 2008;38(15):25. Exclusion reason: No outcome data.
789 Lavizzo-Mourey R. Measuring quality in health care reform. J Health Care Poor Underserved. 1994;5(3):202-11. discussion 12–3. Exclusion reason: Background. [pmid: 7918888].
790 Leatherman S, Chase D. Using report cards to grade health plan quality. J Am Health Policy. Jan–Feb. 1994;4(1):32-40. Exclusion reason: No outcome data. [pmid: 10131578].
791 Lee A, Skott LS, Hansen HP. Organizational and patient-related assessments in HTAs: state of the art. Int J Technol Assess Health Care. Oct. 2009;25(4):530-6. Exclusion reason: Wrong topic. [pmid: 19845983].
792 Lee EA. Hospital uses “report card” as entry to dialogue with employers. QRC Advis. Apr. 1994;10(6):4-5. Exclusion reason: No outcome data. [pmid: 10133300].
793 Lee P, Ness D, Queram C, et al. HCAHPS marks “milestone” for consumers. AHA News. 2005;41(18):7. Exclusion reason: No outcome data. [pmid: 18338192].
794 Lee RH, Wendling L. The extent of quality improvement activities in nursing homes. Am J Med Qual. Nov–Dec. 2004;19(6):255-65. Exclusion reason: Wrong topic. [pmid: 15620077].
795 Lee TH, Cleeman JI, Grundy SM, et al. Clinical goals and performance measures for cholesterol management in secondary prevention of coronary heart disease. JAMA. Jan. 5. 2000;283(1):94-8. Exclusion reason: Wrong topic. [pmid: 10632286].
796 Legido-Quigley H. Assuring the quality of health care in the European Union a case for action. Copenhagen. World Health Organization. 2008. Exclusion reason: Background.
797 Leister J, Stausberg J. Why do patients select a hospital? A conjoint analysis in two German hospitals. J Hosp Mark Public Relations. 2007;17(2):13-31. Exclusion reason: Background. [pmid: 18072702].
798 Lemley KB, Marks B. Patient satisfaction of young adults in rural clinics: policy implications for nurse practitioner practice. Policy Polit Nurs Pract. May. 2009;10(2):143-52. Exclusion reason: Wrong topic. [pmid: 19783536].
799 Lenox AC. HCFA mortality data: a tool for quality improvement efforts. J Healthc Qual. Mar–Apr. 1993;15(2):38-40. Exclusion reason: No outcome data. [pmid: 10124576].
800 Leonardi MJ, McGory ML, Ko CY. Publicly available hospital comparison web sites: determination of useful, valid, and appropriate information for comparing surgical quality. Arch Surg. Sep. 2007;142(9):863-8. discussion 8–9. Exclusion reason: Wrong topic. [pmid: 17875841].
801 Lerner JC. The National Patient Library. Evidence-based information for consumers. Int J Technol Assess Health Care. Winter. 1998;14(1):81-96. Exclusion reason: Background. [pmid: 9509797].
802 Lesley ML, Oermann MH, Vander Wal JS. Internet education of African American consumers on quality of care. J Community Health Nurs. Spring. 2004;21(1):1-14. Exclusion reason: Wrong topic. [pmid: 14979842].
803 Lesser CS, Ginsburg PB. Strategies to enhance price and quality competition in health care: lessons learned from tracking local markets. J Health Polit Policy Law. Jun. 2006;31(3):557-67. Exclusion reason: Background. [pmid: 16785297].
804 Lester HE, Hannon KL, Campbell SM. Identifying unintended consequences of quality indicators: a qualitative study. BMJ Qual Saf. Dec. 2011;20(12):1057-61. Exclusion reason: Wrong topic. [pmid: 21693464].
805 Levenson D. HEDIS score reporting in late 1990s was ineffective, study says. Rep Med Guidel Outcomes Res. Oct. 18. 2002;13(20):9-10. 2. Exclusion reason: No outcome data. [pmid: 12599390].
806 Levenson D. Transferred patients hurt referral hospitals’ quality ratings. Rep Med Guidel Outcomes Res. Jun. 27. 2003;14(12):1-2. 5. Exclusion reason: Methods. [pmid: 12903638].
807 Leventhal Stern A. Understanding the consumer perspective to improve design quality. Abstracts in Social Gerontology. 2003;46(3). Exclusion reason: Wrong topic.
808 Levine RE, Fowler FJ Jr, Brown JA. Role of cognitive testing in the development of the CAHPS Hospital Survey. Health Serv Res. Dec. 2005;40(6 Pt 2):2037-56. Exclusion reason: Methods. [pmid: 16316437].
809 Levknecht L, Schriefer J, Maconis B. Combining case management, pathways, and report cards for secondary cardiac prevention. Jt Comm J Qual Improv. Mar. 1997;23(3):162-74. Exclusion reason: No outcome data. [pmid: 9103970].
810 Levy FH, Henion JS, Harris JM 2nd. Journey toward meaningful pediatric quality metric reporting: the Texas experience. J Healthc Qual. May–Jun. 2008;30(3):36-42. 50. Exclusion reason: Methods. [pmid: 18507239].
811 Levy G, Goldstein L, Barenboim E, et al. Effect of a computerized online grading system on patient satisfaction in a military primary health care setting. Mil Med. Apr. 2007;172(4):431-5. Exclusion reason: Wrong topic. [pmid: 17484319].
812 Levy Merrick E, Garnick DW, Horgan CM, et al. Quality measurement and accountability for substance abuse and mental health services in managed care organizations. Med Care. Dec. 2002;40(12):1238-48. Exclusion reason: Wrong topic. [pmid: 12458305].
813 Levy N. Report cards for institutions, not individuals Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:41-51. Exclusion reason: Background.
814 Lewis JR. Patient views on quality care in general practice: literature review. Soc Sci Med. Sep. 1994;39(5):655-70. Exclusion reason: Wrong topic. [pmid: 7973865].
815 Lewis R. More patient choice in England’s national health service. Int J Health Serv. 2005;35(3):479-83. Exclusion reason: No outcome data. [pmid: 16119571].
816 Lewis SM, Kroner BA. Patient survey of a pharmacist-managed anticoagulation clinic. Manag Care Interface. Nov. 1997;10(11):66-70. Exclusion reason: Wrong topic. [pmid: 10174757].
817 Lexa FJ. 300,000,000 customers: patient perspectives on service and quality. J Am Coll Radiol. May. 2006;3(5):346-50. Exclusion reason: Wrong topic. [pmid: 17412079].
818 Lied TR. 2003 Medicaid versus commercial beneficiary experience with care. Health Care Financ Rev. Summer. 2005;26(4):109-16. Exclusion reason: PR as outcome. [pmid: 17288072].
819 Lied TR, Malsbary R, Eisenberg C, et al. Combining HEDIS indicators: a new approach to measuring plan performance. Health Care Financ Rev. Summer. 2002;23(4):117-29. Exclusion reason: Background. [pmid: 12500474].
820 Lilford R, Pronovost P. Using hospital mortality rates to judge hospital performance: a bad idea that just won’t go away. BMJ. 2010;340:c2016. Exclusion reason: Background. [pmid: 20406861].
821 Lim RF. Efforts of regulatory, professional, and accreditation authorities. Outcome measurement in psychiatry: A critical review. Arlington, VA. American Psychiatric Publishing, Inc; US. 2002:355-68. Exclusion reason: Background.
822 Lin HC, Chen CC, Hsu MK, et al. Do consumers in Taiwan need physician information?. Chang Gung Med J. Jun. 2004;27(6):416-28. Exclusion reason: Wrong topic. [pmid: 15455542].
823 Lindenauer PK, Remus D, Roman S, et al. Public reporting and pay for performance in hospital quality improvement. N Engl J Med. Feb. 1. 2007;356(5):486-96. Exclusion reason: Wrong topic. [pmid: 17259444].
824 Liptzin B. Quality improvement, pay for performance, and “outcomes measurement”: what makes sense?. Psychiatr Serv. Jan. 2009;60(1):108-11. Exclusion reason: No outcome data. [pmid: 19114579].
825 Liu D, Castle NG. Have facilities changed their nursing home compare quality measure scores over time? Long-. Term Care Interface. 2005;6(11):21-4. Exclusion Reason: Other - Incorrect Data and no way to verify.
826 Liu H, Phelps CE, Veazie PJ, et al. Managed care quality and disenrollment in New York SCHIP. Am J Manag Care. Dec. 2009;15(12):910-8. Exclusion reason: PR as outcome. [pmid: 20001172].
827 Livingston EH. Bariatric surgery outcomes at designated centers of excellence vs nondesignated programs. Arch Surg. Apr. 2009;144(4):319-25. discussion 25. Exclusion reason: Wrong topic. [pmid: 19380644].
828 Localio AR, Hamory BH, Fisher AC, et al. The public release of hospital and physician mortality data in Pennsylvania. A case study. Med Care. Mar. 1997;35(3):272-86. Exclusion reason: Methods. [pmid: 9071258].
829 Loden KC. Need to improve patient satisfaction? Consider a staffing matrix. Nurs Manage. Jul. 2011;42(7):46-8. Exclusion reason: Wrong topic. [pmid: 21712681].
830 Loke M, Honbo L. An update of Hawaii QUEST’s medical plans’ performance, using HEDIS measures, 1997–1998. Hawaii Med J. Nov. 2000;59(11):411-8. 24. Exclusion reason: PR as outcome. [pmid: 11149249].
831 Lopez L. Going public. HMO. Sep–Oct. 1995;36(5):52-6. Exclusion reason: No outcome data. [pmid: 10153128].
832 Lorenz S, Sederer LI. Risk adjustment of clinical outcome data Improving mental health care: Commitment to quality. Arlington, VA. American Psychiatric Publishing, Inc; US. 2001:89-99. Exclusion reason: Wrong topic.
833 Losina E, Plerhoples T, Fossel AH, et al. Offering patients the opportunity to choose their hospital for total knee replacement: impact on satisfaction with the surgery. Arthritis Rheum. Oct. 15. 2005;53(5):646-52. Exclusion reason: Wrong topic. [pmid: 16208651].
834 Lubalin JS, Harris-Kojetin LD. What do consumers want and need to know in making health care choices?. Med Care Res Rev. 1999;56(Suppl 1):67-102. discussion 3–12. Exclusion reason: Background. [pmid: 10354679].
835 Luft HS. HMOs and the quality of care. Inquiry. Spring. 1988;25(1):147-56. Exclusion reason: No outcome data. [pmid: 2966120].
836 Luft HS, Garnick DW, Mark DH, et al. Does quality influence choice of hospital?. JAMA. Jun. 6. 1990;263(21):2899-906. Exclusion reason: Wrong topic. [pmid: 2110985].
837 Luft HS, Garnick DW, Phibbs CS, et al. Modeling the effect of hospital charges and quality on choice. J Health Care Mark. Sep. 1991;11(3):2-11. Exclusion reason: Wrong topic. [pmid: 10116316].
838 Luft HS, Miller RH. Patient selection in a competitive health care system. Health Aff (Millwood). Summer. 1988;7(3):97-119. Exclusion reason: Wrong topic. [pmid: 3145918].
839 Luz C. Provider report cards: who’s best at the service I need?. Healthplan. May–Jun. 51. 2002;43(3):48-3. Exclusion reason: No outcome data. [pmid: 12068732].
840 Maciejewski ML, Wang V, Grabowski DC, et al. Early evidence on the quality of care provided by special needs plans. Med Care. Oct. 2011;49(10):891-6. Exclusion reason: No outcome data. [pmid: 21572358].
841 Macintosh D. Trust and the limits of knowledge Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:157-66. Exclusion reason: Background.
842 MacPherson P. Measure by measures. Policy Hosp Health Netw. Mar. 20. 1996;70(6):53-4. 6. Exclusion reason: No outcome data. [pmid: 8593506].
843 Maeng DD, Scanlon DP, Chernew ME, et al. The relationship between health plan performance measures and physician network overlap: implications for measuring plan quality. Health Serv Res. Aug. 2010;45(4):1005-23. Exclusion reason: Methods. [pmid: 20403064].
844 Magasi S, Durkin E, Wolf MS, et al. Rehabilitation consumers’ use and understanding of quality information: a health literacy perspective. Arch Phys Med Rehabil. Feb. 2009;90(2):206-12. Exclusion reason: Wrong topic. [pmid: 19236975].
845 Maibach EW, Weber D, Massett H, et al. Understanding consumers’ health information preferences: development and validation of a brief screening instrument. J Health Commun. Dec. 2006;11(8):717-36. Exclusion reason: Background. [pmid: 17190779].
846 Maio V, Hartmann CW, Goldfarb NI, et al. Are employers pursuing value-based purchasing?. Benefits Q. 2005;21(3):20-9. Exclusion reason: Wrong topic. [pmid: 16248228].
847 Mair N. A project management strategy for collection and reporting of casemix profiles and hospital clinical indicators. Health Inf Manag. Sep–Nov. 1997;27(3):109-15. Exclusion reason: Wrong topic. [pmid: 10178862].
848 Majeed A, Lester H, Bindman AB. Improving the quality of care with performance indicators. BMJ. Nov. 3. 2007;335(7626):916-8. Exclusion reason: No outcome data. [pmid: 17974688].
849 Mak YH. Information asymmetry, public report, and regulation. [Dissertation]. Massachusetts. Boston University. 2012. Exclusion reason: No outcome data.
850 Mallya G, Pollack CE, Polsky D. Are primary care physicians ready to practice in a consumer-driven environment?. Am J Manag Care. Oct. 2008;14(10):661-8. Exclusion reason: Wrong topic. [pmid: 18837644].
851 Manderscheid RW. From many into one: addressing the crisis of quality in managed behavioral health care at the millennium. J Behav Health Serv Res. May. 1998;25(2):233-7. Exclusion reason: Background. [pmid: 9595886].
852 Manderscheid RW, Ganju V, Johnson JR, et al. A data platform for the consumer-oriented report card. Behav Healthc Tomorrow. Dec. 1997;6(6):18-9. Exclusion reason: No outcome data. [pmid: 10177339].
853 Mani O, Mehta RH, Tsai T, et al. Assessing performance reports to individual providers in the care of acute coronary syndromes. Jt Comm J Qual Improv. May. 2002;28(5):220-32. Exclusion reason: Wrong topic. [pmid: 12053455].
854 Mannion R, Davies HT. Reporting health care performance: learning from the past, prospects for the future. J Eval Clin Pract. May. 2002;8(2):215-28. Exclusion reason: No outcome data. [pmid: 12180369].
855 Mano T, Kobayashi M, Mizuno S, et al. Perception gap of medical information services by hospitals and medical service consumers. Jpn Hosp. Jul. 2005;(24):9-15. Exclusion reason: Wrong topic. [pmid: 19195353].
856 Mantone J. Massachusetts site offers physician quality data. Mod Healthc. 2006;36(8):32. Exclusion reason: No outcome data.
857 Marang-van de Mheen PJ, Dijs-Elsinga J, Otten W, et al. The importance of experienced adverse outcomes on patients’ future choice of a hospital for surgery. Qual Saf Health Care. Dec. 2010;19(6):e16. Exclusion reason: Wrong topic. [pmid: 21127100].
858 Marasco SF, Ibrahim JE. Is the reporting of an individual surgeon’s clinical performance doing more harm than good for patient care?. [References]. Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:197-211. Exclusion reason: Background.
859 Marasco SF, Ibrahim JE, Oakley J. Public disclosure of surgeon-specific report cards: current status of the debate. ANZ J Surg. Nov. 2005;75(11):1000-4. Exclusion reason: Background. [pmid: 16336397].
860 Marcin JP, Li Z, Kravitz RL, et al. The CABG surgery volume-outcome relationship: temporal trends and selection effects in California, 1998–2004. Health Serv Res. Feb. 2008;43(1 Pt 1):174-92. Exclusion reason: Wrong topic. [pmid: 18211524].
861 Marcus M, Spolsky V. Concepts of quality and the provision of periodontal care: a survey. J Periodontol. Feb. 1998;69(2):228-40. Exclusion reason: Wrong provider. [pmid: 9526923].
862 Marlowe J, Lane C. Making sense of HMO report cards. Journal of Compensation &. Benefits. 1998;13(6):8. Exclusion reason: No outcome data. [pmid: 689445].
863 Marr TJ, Mullen DM. Balanced scorecards for specialists: a tool for quality improvement. Minn Med. Apr. 2004;87(4):46-50. Exclusion reason: No outcome data. [pmid: 15144164].
864 Marshall M, McLoughlin V. How do patients use information on health providers?. BMJ. 2010. Exclusion reason: No outcome data. [pmid: 21109576].
865 Marshall M, Shekelle P, Brook R, et al. Dying to Know Public Release of Information about Quality of Health Care. Ft. Belvoir. Defense Technical Information Center. 2000. http://handle.dtic.mil/100.2/ADA384942. Exclusion reason: No outcome data.
866 Marshall MN, Brook RH. Public reporting of comparative information about quality of healthcare. Med J Aust. Mar. 4. 2002;176(5):205-6. Exclusion reason: No outcome data. [pmid: 11999234].
867 Marshall MN, Romano PS. Impact of reporting hospital performance. Quality and Safety in Health Care 2005. April. 1. 2005;14(2):77-8. Exclusion reason: No outcome data.
868 Marshall MN, Romano PS, Davies HT. How do we maximize the impact of the public reporting of quality of care?. Int J Qual Health Care. Apr. 2004;16(Suppl 1):i57-63. Exclusion reason: Background. [pmid: 15059988].
869 Marshall MN, Shekelle PG, Davies HT, et al. Public reporting on quality in the United States and the United Kingdom. Health Aff (Millwood). May–Jun. 2003;22(3):134-48. Exclusion reason: No outcome data. [pmid: 12757278].
870 Marshall MN, Shekelle PG, Leatherman S, et al. Public disclosure of performance data: learning from the US experience. Qual Health Care. Mar. 2000;9(1):53-7. Exclusion reason: No outcome data. [pmid: 10848371].
871 Marshall MN, Shekelle PG, Leatherman S, et al. The public release of performance data: what do we expect to gain? A review of the evidence. JAMA. Apr. 12. 2000;283(14):1866-74. Exclusion reason: Background. [pmid: 10770149].
872 Marshall T, Mohammed MA, Rouse A. A randomized controlled trial of league tables and control charts as aids to health service decision-making. Int J Qual Health Care. Aug. 2004;16(4):309-15. Exclusion reason: Wrong topic. [pmid: 15252005].
873 Martin V, Kuster W, Baur M, et al. Incidence of coercive measures as an indicator of quality in psychiatric hospitals. Problems of data recording and processing, preliminary results of a benchmarking study. Psychiatr Prax. Jan. 2007;34(1):26-33. Exclusion reason: Wrong topic. [pmid: 17106840].
874 Mascitti KB, Manaker S, Rohrbach J, et al. Limitations in using aspiration pneumonia as a quality measure. Infect Control Hosp Epidemiol. Dec. 2009;30(12):1233-5. Exclusion reason: Wrong topic. [pmid: 19877817].
875 Mason A, Street A. Publishing outcome data: is it an effective approach?. J Eval Clin Pract. Feb. 2006;12(1):37-48. Exclusion reason: No outcome data. [pmid: 16422779].
876 Masoudi FA, Bonow RO, Brindis RG, et al. ACC/AHA 2008 statement on Performance Measurement and Reperfusion Therapy: a report of the ACC/AHA Task Force on Performance Measures (Work Group to address the challenges of Performance Measurement and Reperfusion Therapy). J Am Coll Cardiol. Dec. 9. 2008;52(24):2100-12. Exclusion reason: Wrong topic. [pmid: 19056001].
877 Masoudi FA, Peterson ED, Anderson JL, et al. Clinical guidelines and performance measures responsible guidance and accountability. J Card Fail. Dec. 2010;16(12):919-21. Exclusion reason: Wrong topic. [pmid: 21111979].
878 Matthews JC, Johnson ML, Koelling TM. The impact of patient-specific quality-of-care report cards on guideline adherence in heart failure. Am Heart J. Dec. 2007;154(6):1174-83. Exclusion reason: Wrong topic. [pmid: 18035092].
879 Mattivi KR. A multivariate approach to explore nursing home characteristics contributing to high performance on CMS’ publicly reported quality measures. [Dissertation]. University of Southern California- Dept: Applied Biostatistics and Epidemiology. 2012. Exclusion reason: PR as outcome.
880 Mattke S, Reilly K, Martinez-Vidal E, et al. Reporting quality of nursing home care to consumers: the Maryland experience. Int J Qual Health Care. Apr. 2003;15(2):169-77. Exclusion reason: No outcome data. [pmid: 12705711].
881 Maxwell CI. Public disclosure of performance information in Pennsylvania: impact on hospital charges and the views of hospital executives. Jt Comm J Qual Improv. Sep. 1998;24(9):491-502. Exclusion reason: Wrong topic. [pmid: 9770639].
882 Mazza G, Fazzi B. Five good reasons why CMS’s new CAHPS patient satisfaction survey is good for agencies and good for patients. Caring. Apr. 2009;28(4):50-1. Exclusion reason: No outcome data. [pmid: 19507364].
883 McAuley WJ, Travis SS, Safewright MP. Personal accounts of the nursing home search and selection process. Qualitative Health Research. 1997;7(2):236-54. Exclusion reason: Background.
884 McCarthy D. Commonwealth Fund. Commission on a High Performance Health S. Aiming higher results from a state scorecard on health system performance, 2009. [New York]. Commonwealth Fund. 2009. http://www.commonwealthfund.org/~/media/Files/Publications/Fund%20Report/2009/Oct/1326%5FMcCarthy%5Fstate%5Fscorecard%5F2009%5Ffull%5Freport%5FFINAL.pdf. Exclusion reason: No outcome data.
885 McClellan WM, Frederick PR, Helgerson SD, et al. A data-driven approach to improving the care of in-center hemodialysis patients. Health Care Financ Rev. Summer. 1995;16(4):129-40. Exclusion reason: Wrong topic. [pmid: 10151884].
886 McConnell J. Public reporting in the UK of hospital infections. J Hosp Infect. Jun. 2007;65(Suppl 2):189-90. Exclusion reason: No outcome data. [pmid: 17540268].
887 McCormack J. Getting the most out of HEDIS reporting. Health Data Manag. Apr. 1998;6(4):110-1. Exclusion reason: No outcome data. [pmid: 10179380].
888 McCormack LA, Burrus BB, Garfinkel SA, et al. Providing information to help Medicare beneficiaries choose a health plan. J Aging Soc Policy. 2001;12(2):49-72. Exclusion reason: Wrong topic. [pmid: 11303366].
889 McCormack LA, Garfinkel SA, Hibbard JH, et al. Health insurance knowledge among Medicare beneficiaries. Health Serv Res. Feb. 2002;37(1):43-63. Exclusion reason: Wrong topic. [pmid: 11949925].
890 McCormack LA, Garfinkel SA, Schnaier JA, et al. Consumer information development and use. Health Care Financ Rev. Fall. 1996;18(1):15-30. Exclusion reason: No outcome data. [pmid: 10165029].
891 McCormick D, Himmelstein DU, Woolhandler S, et al. Relationship between low quality-of-care scores and HMOs’ subsequent public disclosure of quality-of-care scores. JAMA. Sep. 25. 2002;288(12):1484-90. Exclusion reason: Wrong topic. [pmid: 12243635].
892 McDonald KM. Approach to improving quality: the role of quality measurement and a case study of the agency for healthcare research and quality pediatric quality indicators. Pediatr Clin North Am. Aug. 2009;56(4):815-29. Exclusion reason: Wrong topic. [pmid: 19660629].
893 McGee J, Hunter M. Employee response to health benefits survey results brochure: Findings from fall 1992 Interviews. Minnesota Department of Employee Relations. 1992. Exclusion reason: Unable to obtain.
894 McGee J, Kanouse DE, Sofaer S, et al. Making survey results easy to report to consumers: how reporting needs guided survey design in CAHPS. Consumer Assessment of Health Plans Study. Med Care. Mar. 1999;37(3 Suppl):MS32-40. Exclusion reason: Wrong topic. [pmid: 10098557].
895 McGee J, Knutson D. Health care report cards: what about consumers’ perspectives?. J Ambul Care Manage. Oct. 1994;17(4):1-14. Exclusion reason: Background. [pmid: 10137966].
896 McGee J, Sofaer S, Kreling B, et al. Medicare and Medicaid consumer information projects : findings from focus groups. Washington, D.C. National Committee for Quality Assurance. 1996. Exclusion reason: Unable to obtain.
897 McGill JF, Moo TA, Kato M, et al. World wide what? The quality of information on parathyroid disease available on the Internet. Surgery. Dec. 2009;146(6):1123-9. Exclusion reason: Wrong topic. [pmid: 19958939].
898 McGinty J, Anderson G. Predictors of physician compliance with American Heart Association guidelines for acute myocardial infarction. Crit Care Nurs Q. Apr–Jun. 2008;31(2):161-72. Exclusion reason: Wrong topic. [pmid: 18360146].
899 McGlone TA, Butler ES, McGlone VL. Factors influencing consumers’ selection of a primary care physician. Health Mark Q. 2002;19(3):21-37. Exclusion reason: Background. [pmid: 12077807].
900 McGlynn EA. Choosing and evaluating clinical performance measures. Jt Comm J Qual Improv. Sep. 1998;24(9):470-9. Exclusion reason: Methods. [pmid: 9770637].
901 McGlynn EA, Adams JL. Public Release of Information on Quality Changing the U S health care system: Key issues in health services policy and management. 3rd ed. San Francisco, CA. Jossey-Bass; US. 2007:245-72. Exclusion reason: Background.
902 McGlynn EA, Brook RH. Full disclosure: time for the naked truth about health care. Rand Review. Summer. 2001;25(2):8-11. Exclusion reason: Background.
903 McGuire D. Patients rate quality on a different scale from providers, survey shows. Qual Lett Healthc Lead. Jun. 1996;8(5):19. Exclusion reason: No outcome data. [pmid: 10158415].
904 McIntyre D, Rogers L, Heier EJ. Overview, history, and objectives of performance measurement. Healthcare Financing Review. Spring. 2001;22(3):7-21. Exclusion reason: No outcome data.
905 McKeever J. Mapping the patient experience. Charting patient experiences can uncover valuable information. Mark Health Serv. Winter. 2004;24(4):14-9. Exclusion reason: No outcome data. [pmid: 15612221].
906 McKibben L, Fowler G, Horan T, et al. Ensuring rational public reporting systems for health care-associated infections: systematic literature review and evaluation recommendations. Am J Infect Control. Apr. 2006;34(3):142-9. Exclusion reason: No outcome data. [pmid: 16630978].
907 McKibben L, Horan T, Tokars JI, et al. Guidance on public reporting of healthcare-associated infections: recommendations of the Healthcare Infection Control Practices Advisory Committee. Am J Infect Control. May. 2005;33(4):217-26. Exclusion reason: Methods. [pmid: 15877016].
908 McKinney M. Building a framework. NQF offers standards for adverse-events reporting. Mod Healthc. Oct. 18. 2010;40(42):12-3. Exclusion reason: Background. [pmid: 21049691].
909 McKinney M. Value-based concerns. Hospitals fear unfair penalties from program. Mod Healthc. Mar. 14. 2011;41(11):12. Exclusion reason: Wrong topic. [pmid: 21513038].
910 McKinney M. Data debate. HAC numbers on website draw criticism. Mod Healthc. Apr. 11. 2011;41(15):8-9. Exclusion reason: Background. [pmid: 21604405].
911 McKinney M. You get what you pay for. (cover story). Mod Healthc. 2011;41(3):6-7. Exclusion reason: Background. [pmid: 21370697].
912 McLachlan RS, Starreveld E, Lee MA. Impact of mandatory physician reporting on accident risk in epilepsy. Epilepsia. Aug. 2007;48(8):1500-5. Exclusion reason: Wrong topic. [pmid: 17442011].
913 McLean K, Taylor W. Identifying the barriers to implementing a quality initiative in primary care: the views of practices in Scotland on the Quality Practice Award. Qual Prim Care. 2007;15(6):353-9. Exclusion reason: No outcome data.
914 McMahon LF Jr. What to do when it’s you: Bill Clinton and hospital report cards. Am J Manag Care. Oct. 2004;10(10):664. Exclusion reason: No outcome data. [pmid: 15521157].
915 McMullan M. HCFA’s consumer information commitment. Health Care Financ Rev. Fall. 1996;18(1):9-14. Exclusion reason: No outcome data. [pmid: 10165039].
916 McNamara P. Provider-specific report cards: a tool for health sector accountability in developing countries. Health Policy Plan. Mar. 2006;21(2):101-9. Exclusion reason: Background. [pmid: 16431878].
917 Mechanic D. Consumer choice among health insurance options. Health Aff (Millwood). Spring. 1989;8(1):138-48. Exclusion reason: No outcome data. [pmid: 2496018].
918 Mehrotra A, Pearson SD, Coltin KL, et al. The response of physician groups to P4P incentives. Am J Manag Care. May. 2007;13(5):249-55. Exclusion reason: Background. [pmid: 17488190].
919 Menaker R. Making the cut: reporting on hospital performance in Ontario. Fraser Forum. Oct. 2006:14-7. Exclusion reason: No outcome data.
920 Menaker R. Accountability in Ontario’s Hospitals. Fraser Forum. 2007. Feb. 15. Exclusion reason: Background.
921 Mensik J. Describing the Essentials of Magnetism and Quality in Home Health. Tucson, Arizona. University of Arizona. 2006. http://etd.library.arizona.edu/etd/GetFileServlet?file=file:///data1/pdf/etd/azu%5Fetd%5F1606%5F1%5Fm.pdf&type=application/pdf. Exclusion reason: Wrong topic.
922 Merle V, Moret L, Pidhorz L, et al. Does comparison of performance lead to better care? A pilot observational study in patients admitted for hip fracture in three French public hospitals. Int J Qual Health Care. Oct. 2009;21(5):321-9. Exclusion reason: Wrong topic. [pmid: 19692425].
923 Merry MD. A physician’s perspective on proper design of quality assessment criteria. QRB Qual Rev Bull. Oct. 1982;8(10):3-4. Exclusion reason: No outcome data. [pmid: 6817254].
924 Mertens JR, Weisner C, Sterling S, et al. Primary care SBIRT implementation in integrated, private health care: Update on facilitators and barriers in an era of parity and HEDIS measurement. (Abstracts—Symposia). Alcoholism: Clinical and Experimental Research. 2010;34:277A. Exclusion reason: Wrong topic.
925 Meuwissen LE, de Bakker DH. ‘Consumer quality’-index ‘General practice care’ measures patients’ experiences and compares general practices with each other. Ned Tijdschr Geneeskd. 2009;153:A180. Exclusion reason: Methods. [pmid: 19900331].
926 Meyer JA, Lifson A. Commentary Med Care Res Rev. 1999;56(Suppl 1):103-12. Exclusion reason: Background.
927 Micheletti JA, Shlala TJ, Goodall CR. Evaluating performance outcomes measurement systems: concerns and considerations. J Healthc Qual. Mar–Apr. 1998;20(2):6-12. quiz -3–52. Exclusion reason: Wrong topic. [pmid: 10177271].
928 Middleton S, Harris J, Lusby R, et al. GPs’ views of quality initiatives to improve stroke outcomes following carotid endarterectomy. Aust Fam Physician. Oct. 2003;32(10):858-61. Exclusion reason: Wrong topic. [pmid: 14596085].
929 Mihalik GJ, Scherer MR. Understanding the intersection between quality improvement, managed behavioral health accreditation, and the private practitioner. Psychiatr Clin North Am. Jun. 2000;23(2):285-96. Exclusion reason: Background. [pmid: 10909108].
930 Millenson ML. The public interest in publishing quality information. Qual Lett Healthc Lead. Jul–Aug. 1993;5(6):25-9. Exclusion reason: No outcome data. [pmid: 10127855].
931 Millenson ML. The sea change of the see-through hospital--and how to stay afloat. Healthc Financ Manage. Oct. 2008;62(10):106-10. Exclusion reason: No outcome data. [pmid: 18839672].
932 Miller JA, Lowe PV. Improving managed care through coding, monitoring, and trending quality-of-care concerns. J Healthc Qual. Jan–Feb. 1998;20(1):20-3. 6. 8. Exclusion reason: Wrong topic. [pmid: 10177015].
933 Miller P, Yasin MM, Zimmerer TW. An empirical investigation of quality improvement initiatives in for-profit and not-for-profit hospitals: environmental, competitive and outcome concerns. Int J Health Care Qual Assur Inc Leadersh Health Serv. 2006;19(6-7):539-50. Exclusion reason: Wrong topic. [pmid: 17100223].
934 Miller R. Web portals and patient information-seeking behaviors. J Oncol Pract. Jul. 2009;5(4):182-3. Exclusion reason: Wrong topic. [pmid: 20856633].
935 Miller R, Lazar J. Public reporting of performance measures in home care. Jt Comm J Qual Improv. Mar. 1995;21(3):105-15. Exclusion reason: Wrong provider. [pmid: 7787958].
936 Miller TE, Gutmann VL. Changing expectations for board oversight of healthcare quality: the emerging paradigm. J Health Life Sci Law. Jul. 3. 2009;2(4):31-77. Exclusion reason: Background. [pmid: 19673177].
937 Miller TE, Horowitz CR. Disclosing doctors’ incentives: will consumers understand and value the information?. Health Aff (Millwood). Jul–Aug. 2000;19(4):149-55. Exclusion reason: Wrong topic. [pmid: 10916968].
938 Miller TE, Sage WM. Disclosing physician financial incentives. JAMA. Apr. 21. 1999;281(15):1424-30. Exclusion reason: Wrong topic. [pmid: 10217059].
939 Milstein A, Lee TH. Comparing physicians on efficiency. N Engl J Med. Dec. 2007;357(26):2649-52. Peer Reviewed Journal: 2008-00141-001. Exclusion reason: Background. [pmid: 18160682].
940 Minott J, Helms D, Luft H, et al. The group employed model as a foundation for health care delivery reform. Issue Brief (Commonw Fund). Apr. 2010;83:1-24. Exclusion reason: Wrong topic. [pmid: 20411624].
941 Mira JJ, Tirado S, Perez V, et al. Factors determining patients’ choice of hospital. Gac Sanit. May–Jun. 2004;18(3):205-12. Exclusion reason: Not English. [pmid: 15228919].
942 Miyata H, Motomura N, Ueda Y, et al. Effect of procedural volume on outcome of coronary artery bypass graft surgery in Japan: implication toward public reporting and minimal volume standards. J Thorac Cardiovasc Surg. Jun. 2008;135(6):1306-12. Exclusion reason: Methods. [pmid: 18544377].
943 Möller J, Panhorst H, Zieres G. Qualitätsberichterstattung für ambulante Pflegedienste. Gesundh ökon Qual manag. 05. 08. 2010. 2010;15(04):185-91. Exclusion reason: Methods.
944 Molnar C. Addressing challenges, creating opportunities: fostering consumer participation in Medicaid and Children’s Health Insurance managed care Programs. J Ambul Care Manage. Jul. 2001;24(3):61-7. Exclusion reason: No outcome data. [pmid: 11433557].
945 Monroe A. Consumer involvement--a vital piece of the quality quilt: the California HealthCare Foundation’s strategy for engaging California consumers. Qual Saf Health Care. Jun. 2002;11(2):181-5. Exclusion reason: No outcome data. [pmid: 12448813].
946 Montague J. Report card daze. Hosp Health Netw. Jan. 5. 1996;70(1):33-6. Exclusion reason: No outcome data. [pmid: 8541923].
947 Montoya ID, Perez BA. Access as a managed care marketing outcomes measure. Health Mark Q. 2000;17(3):1-12. Exclusion reason: No outcome data. [pmid: 11010216].
948 Moore JD Jr. Knowing the score. Mass. hospitals find out how patients rated them. Mod Healthc. Nov. 23. 1998;28(47):38. Exclusion reason: No outcome data. [pmid: 10187693].
949 Moore JD Jr. Real results. Pa. report gives consumers outcomes data they can use. Mod Healthc. May. 18. 1998;28(20):46. Exclusion reason: No outcome data. [pmid: 10179693].
950 Moore JD Jr. Study: HMOs moving toward quality. NCQA finds links between quality of care and member satisfaction, disclosure and performance. Mod Healthc. Sep. 13. 66. 1999;29(37):74. Exclusion reason: No outcome data. [pmid: 10623232].
951 Moore JD Jr. HEDIS 2000 emphasizes prevention. Mod Healthc. 1999;29(8):32. Exclusion reason: No outcome data. [pmid: 1622198].
952 Moore ST, Bopp KD. How consumers evaluate health care quality: Part II. Health Mark Q. 1999;17(1):1-8. Exclusion reason: Wrong topic. [pmid: 11066719].
953 Moore ST, Bopp KD. How consumers evaluate health care quality: Part I. Health Marketing Quarterly. 1999;16(4):1-6. Exclusion reason: Wrong topic. [pmid: 11066713].
954 Mor V, Miller EA, Clark M. The taste for regulation in long-term care. Med Care Res Rev. Aug. 2010;67(4 Suppl):38S-64S. Exclusion reason: Wrong topic. [pmid: 20448251].
955 Morahan-Martin JM. How internet users find, evaluate, and use online health information: a cross-cultural review. Cyberpsychol Behav. Oct. 2004;7(5):497-510. Exclusion reason: Wrong topic. [pmid: 15667044].
956 Morales LS, Elliott M, Brown J, et al. The applicability of the Consumer Assessments of Health Plans Survey (CAHPS) to Preferred Provider Organizations in the United States: a discussion of industry concerns. Int J Qual Health Care. Jun. 2004;16(3):219-27. Exclusion reason: Methods. [pmid: 15150153].
957 Morales LS. Rand Corp Santa Monica CA. Assessing Patient Experiences with Healthcare in Multi-Cultural Settings. Ft: Belvoir. Defense Technical Information Center. 2001. http://handle.dtic.mil/100.2/ADA393074. Exclusion reason: Methods.
958 Moretti C, Kalucy E, Hordacre AL, et al. South Australian Divisions of General Practice supporting diabetes care: insights from reporting data. Aust J Prim Health. 2010;16(1):60-5. Exclusion reason: Wrong topic. [pmid: 21133300].
959 Moriearty P, Bogdanich R, Dexter N, et al. Incorporating results of a provider attitudes survey in development of an outcomes assessment program. Am J Med Qual. Jul–Aug. 1999;14(4):178-84. Exclusion reason: Wrong topic. [pmid: 10452135].
960 Morley J. Cleveland Health Quality Choice Project. Rev Fed Am Health Syst. Nov–Dec. 1990;23(6):22-5. Exclusion reason: Background. [pmid: 10107706].
961 Morrato EH, Libby AM, Orton HD, et al. Frequency of provider contact after FDA advisory on risk of pediatric suicidality with SSRIs. Am J Psychiatry. Jan. 2008;165(1):42-50. Exclusion reason: Wrong topic. [pmid: 17986680].
962 Morreim EH. To tell the truth: disclosing the incentives and limits of managed care. Am J Manag Care. Jan. 1997;3(1):35-43. Exclusion reason: Wrong topic. [pmid: 10169248].
963 Morrison K. The road to JCAHO disease-specific care certification: a step-by-step process log. Dimens Crit Care Nurs. Sep–Oct. 2005;24(5):221-7. Exclusion reason: Methods. [pmid: 16258355].
964 Morrissey J. Feedback prompts HEDIS revisions. Mod Healthc. Oct. 21. 1996;26(43):76. Exclusion reason: No outcome data. [pmid: 10162889].
965 Morrissey J. HEDIS to expand performance guidelines. Mod Healthc. Jul. 22. 1996;26(30):2-3. Exclusion reason: No outcome data. [pmid: 10158836].
966 Morrissey J. Health measures move to next level. Mod Healthc. Jul. 15. 1996;26(29):8. Exclusion reason: No outcome data. [pmid: 10158834].
967 Morse JH, Koven SG, Mundt CJ, et al. The Kentucky initiative in health services contracting: The search for contracting of outcomes measures. Int J Public Adm. 2008;31(6):639-53. Exclusion reason: Background.
968 Mosen DM, Carlson MJ, Morales LS, et al. Satisfaction with provider communication among Spanish-speaking Medicaid enrollees. Ambul Pediatr. Nov–Dec. 2004;4(6):500-4. Exclusion reason: PR as outcome. [pmid: 15548101].
969 Moskowitz DB. Marketplace. Can health plan report cards spur competition on quality?. Faulkner Grays Med Health. Jul. 7. 1997;51(27):suppl 2. Exclusion reason: No outcome data. [pmid: 10168591].
970 Moskowitz DB. Marketplace. Utah and Maryland pioneer new look in HMO report cards. Faulkner Grays Med Health. Aug. 18. 1997;51(33):suppl 2. Exclusion reason: Background. [pmid: 10168968].
971 Moskowitz DB. New attempt by blue chip HMOs to rate how plans improve HEDIS. Med Health. Mar. 6. 2000;54(10):M1-2. Exclusion reason: No outcome data. [pmid: 10977498].
972 Mougeot M, Naegelen F. Using auctions for contracting with hospitals when quality matters. Int J Health Care Finance Econ. Mar. 2003;3(1):5-23. Exclusion reason: Wrong topic. [pmid: 14626010].
973 Mowll CA. The availability of health care information for consumer use. J Health Care Finance. Summer. 1995;21(4):31-44. Exclusion reason: No outcome data. [pmid: 7583781].
974 Moxey ED, O’Connor JP, White E, et al. Developing a quality measurement tool and reporting format for long- term care. Jt Comm J Qual Improv. Apr. 2002;28(4):180-96. Exclusion reason: Methods. [pmid: 11942261].
975 Mueller IL, Teslow M, Hallyburton A. A public life. Developing a consumer information role in HIM. J AHIMA. Apr. 2007;78(4):40-3. Exclusion reason: Wrong topic. [pmid: 17455845].
976 Mukamel DB, Glance LG, Dick AW, et al. Measuring quality for public reporting of health provider quality: making it meaningful to patients. Am J Public Health. Feb. 2010;100(2):264-9. Exclusion reason: Methods. [pmid: 20019317].
977 Mukamel DB, Mushlin AI. The impact of quality report cards on choice of physicians, hospitals, and HMOs: a midcourse evaluation. Jt Comm J Qual Improv. Jan. 2001;27(1):20-7. Exclusion reason: No outcome data. [pmid: 11147237].
978 Mukamel DB, Spector WD. Quality report cards and nursing home quality. Gerontologist. Apr. 2003;43(Spec No 2):58-66. Exclusion reason: No outcome data. [pmid: 12711725].
979 Mukamel DB, Weimer DL, Mushlin AI. Interpreting market share changes as evidence for effectiveness of quality report cards. Med Care. Dec. 2007;45(12):1227-32. Exclusion reason: Background. [pmid: 18007175].
980 Muller MP, Detsky AS. Public reporting of hospital hand hygiene compliance--helpful or harmful?. JAMA. Sep. 8. 2010;304(10):1116-7. Exclusion reason: No outcome data. [pmid: 20823438].
981 Mulvey GK, Wang Y, Lin Z, et al. Mortality and readmission for patients with heart failure among U.S. News & World Report’s top heart hospitals. Circ Cardiovasc Qual Outcomes. Nov. 2009;2(6):558-65. Exclusion reason: Methods. [pmid: 20031893].
982 Murray A, Safran DG. The Primary Care Assessment Survey: A tool for measuring, monitoring, and improving primary care. Handbook of psychological assessment in primary care settings. Mahwah, NJ. Lawrence Erlbaum Associates Publishers; US. 2000:623-51. Exclusion reason: Background.
983 Murtaugh CM, Peng T, Aykan H, et al. Risk adjustment and public reporting on home health care. Health Care Financ Rev. Spring. 2007;28(3):77-94. Exclusion reason: Methods. [pmid: 17645157].
984 Nadzam DM, Atkins PM. Quality toolbox. Shades of satisfaction -- using a stoplight chart for visual interpretation of data. Journal for Healthcare Quality: Promoting Excellence in Healthcare. 2005;27(4):W4-1-w4-6. Exclusion reason: Wrong topic.
985 Nagasawa Y. Surgeon report cards and the concept of defensive medicine Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:255-65. Exclusion reason: Background.
986 Nagy PG. Using informatics to improve the quality of radiology. Applied radiology. 2008;46:9. Exclusion reason: Wrong topic.
987 Nair KV. Evaluation of health and pharmacy benefit information in health plan information packages. Manag Care Interface. Dec. 2001;14(12):51-4. Exclusion reason: No outcome data. [pmid: 11794843].
988 Natale JE, Joseph JG, Honomichl RD, et al. Benchmarking, public reporting, and pay-for-performance: a mixed-methods survey of California pediatric intensive care unit medical directors. Pediatr Crit Care Med. Nov. 2011;12(6):e225-32. Exclusion reason: Wrong topic. [pmid: 21057357].
989 National Committee for Quality A, Commonwealth F, United States. Agency for Health Care P, et al. NCQA consumer information project-- focus group report. Washington, D.C. National Committee for Quality Assurance. 1995. Exclusion reason: Unable to obtain.
990 Neil D. Against the informed consent argument for surgeon report cards Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:147-56. Exclusion reason: Wrong topic.
991 Nelson EC, Batalden PB, Plume SK, et al. Report cards or instrument panels: who needs what?. Jt Comm J Qual Improv. Apr. 1995;21(4):155-66. Exclusion reason: Background. [pmid: 7780530].
992 Nelson P. Information and Consumer Behavior. J Polit Econ. 1970;78(2):311. Exclusion reason: Wrong topic.
993 Nerenz DR. Accountability for health outcomes and the proper unit of analysis: what do the experts think?. Int J Qual Health Care. Dec. 1998;10(6):539-46. Exclusion reason: Methods. [pmid: 9928593].
994 Neuhauser D, Harper DL. Too good to last: did Cleveland Health Quality Choice leave a legacy and lessons to be learned?. Qual Saf Health Care. Jun. 2002;11(2):202-3. Exclusion reason: Background. [pmid: 12448815].
995 Neuman KM, Ptak M. Managing managed care through accreditation standards. Soc Work. Jul. 2003;48(3):384-91. Exclusion reason: Background. [pmid: 12899285].
996 Neumann PJ, Levine BS. Do HEDIS measures reflect cost-effective practices?. Am J Prev Med. Nov. 2002;23(4):276-89. Exclusion reason: Methods. [pmid: 12406482].
997 Nguyen HQ, Carrieri-Kohlman V, Rankin SH, et al. Supporting cardiac recovery through eHealth technology. J Cardiovasc Nurs. May–Jun. 2004;19(3):200-8. Exclusion reason: Wrong topic. [pmid: 15191263].
998 Ni J. A dynamic structural analysis of health care service market with information asymmetry: Ni, Jian: Carnegie Mellon U, US. 2011. Exclusion reason: Wrong topic.
999 Nicholas LH, Dimick JB, Iwashyna TJ. Do hospitals alter patient care effort allocations under pay-for-performance?. Health Serv Res. Feb. 2011;46(1 Pt 1):61-81. Exclusion reason: No outcome data. [pmid: 21029088].
1000 Nicholas LH, Osborne NH, Birkmeyer JD, et al. Hospital process compliance and surgical outcomes in medicare beneficiaries. Arch Surg. Oct. 2010;145(10):999-1004. Exclusion reason: Methods. [pmid: 20956770].
1001 Noble J, Hann M, Sheaff R, et al. A survey and audit of the first ‘Guides to Local Health Services’ produced by Primary Care Trusts in England. Health Expect. Jun. 2005;8(2):138-48. Exclusion reason: Methods. [pmid: 15860054].
1002 Norem J, Moen MA. The Websites of Norwegian hospitals: do they meet national guidelines and patient’s expectations?. J Telemed Telecare. 2004;10(5):272-6. Exclusion reason: Wrong topic. [pmid: 15532132].
1003 Noyez L. Editorial comment: Quality measurement in adult cardiac surgery: a challenge. Eur J Cardiothorac Surg. May. 2009;35(5):758-9. Exclusion reason: No outcome data. [pmid: 19167905].
1004 Noyez L, Kievit PC, Verkroost MW, et al. Evaluation of quality in adult cardiac surgery: let us speak the same language. Neth Heart J. Aug. 2010;18(7–8):365-9. Exclusion reason: Wrong topic. [pmid: 20730004].
1005 Nugent WC, Schults WC. Playing by the numbers: how collecting outcomes data changed by life. Ann Thorac Surg. Dec. 1994;58(6):1866-70. Exclusion reason: Wrong topic. [pmid: 7979784].
1006 Nustad CJ. Measuring the value of health care dollars. Health Manag Technol. May. 1997;18(6):24-5. 52. Exclusion reason: No outcome data. [pmid: 10167514].
1007 Nutley S, Smith PC. League tables for performance improvement in health care. J Health Serv Res Policy. Jan. 1998;3(1):50-7. Exclusion reason: No outcome data. [pmid: 10180390].
1008 Oakley J. An ethical analysis of the defensive surgery objection to individual surgeon report cards. Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:243-54. Exclusion reason: No outcome data.
1009 Oertel PJ. Public health officers’ expert reports. Bundesgesundheitsblatt Gesundheitsforschung Gesundheitsschutz. Oct. 2005;48(10):1120-4. Exclusion reason: Wrong topic. [pmid: 16172788].
1010 Oetjen RM, Zhao M, Liu D, et al. Nursing home safety: does financial performance matter?. J Health Care Finance. Spring. 2011;37(3):51-61. Exclusion reason: Wrong topic. [pmid: 21528833].
1011 Ofri D. Quality measures and the individual physician. N Engl J Med. Aug. 12. 2010;363(7):606-7. Exclusion reason: No outcome data. [pmid: 20818853].
1012 O’Hagan J, Persaud D. Creating a culture of accountability in health care. Health Care Manag (Frederick). Apr–Jun. 2009;28(2):124-33. Exclusion reason: No outcome data. [pmid: 19433930].
1013 Ohldin A, Mims A. The search for value in health care: a review of the National Committee for Quality Assurance efforts. J Natl Med Assoc. May. 2002;94(5):344-50. Exclusion reason: Background. [pmid: 12069214].
1014 O’Kane ME, Margaret E. O’Kane on healthcare accreditation. Interview by Wanda Bishop and Kevin C. Park. J Healthc Qual. May–Jun. 2001;23(3):21-5. Exclusion reason: No outcome data. [pmid: 11378973].
1015 Olandt H, Krentz H. Patient satisfaction-subjective quality assessment by patients and success factor for clinics. Gesundheitswesen. Dec. 1998;60(12):721-8. Exclusion reason: Wrong topic. [pmid: 10024771].
1016 Olola CH, Narus S, Poynton M, et al. Patient-perceived usefulness of an emergency medical card and a continuity-of-care report in enhancing the quality of care. Int J Qual Health Care. Feb. 2011;23(1):60-7. Exclusion reason: Wrong topic. [pmid: 21163777].
1017 O’Malley C. Quality measurement for health systems: accreditation and report cards. Am J Health Syst Pharm. Jul. 1. 1997;54(13):1528-35. Exclusion reason: Wrong topic. [pmid: 9217945].
1018 O’Malley S. Report cards: how relevant are they for patients?. Qual Lett Healthc Lead. Mar. 1997;9(3):12-5. Exclusion reason: No outcome data. [pmid: 10165848].
1019 O’Malley S. HMOs: responding to bad report cards. Qual Lett Healthc Lead. Mar. 1997;9(3):2-11. Exclusion reason: No outcome data. [pmid: 10165851].
1020 O’Meara J, Kitchener M, Collier E, et al. Case study: development of and stakeholder responses to a nursing home consumer information system. Am J Med Qual. Jan–Feb. 2005;20(1):40-50. Exclusion reason: No outcome data. [pmid: 15782754].
1021 O’Neill E, Humphreys H. Use of surveillance data for prevention of healthcare-associated infection: risk adjustment and reporting dilemmas. Curr Opin Infect Dis. Aug. 2009;22(4):359-63. Exclusion reason: No outcome data. [pmid: 19474727].
1022 Organisation for Economic C-o, Development. Achieving better value for money in health care. Paris. OECD. 2009. Exclusion reason: Wrong topic.
1023 O’Rourke LM. Cleveland and Cincinnati: can releasing quality data make friends and influence care?. Qual Lett Healthc Lead. Jul–Aug. 1993;5(6):12-9. Exclusion reason: Background. [pmid: 10127853].
1024 O’Rourke LM. Do quality report cards make a difference? The New York and Pennsylvania experience with releasing physician-specific outcomes. Qual Lett Healthc Lead. Jul–Aug. 1993;5(6):2-11. Exclusion reason: Background. [pmid: 10130698].
1025 Osborne NH, Ghaferi AA, Nicholas LH, et al. Evaluating popular media and internet-based hospital quality ratings for cancer surgery. Arch Surg. May. 2011;146(5):600-4. Exclusion reason: Methods. [pmid: 21576612].
1026 Osborne NH, Nicholas LH, Ghaferi AA, et al. Do popular media and internet-based hospital quality ratings identify hospitals with better cardiovascular surgery outcomes?. J Am Coll Surg. Jan. 2010;210(1):87-92. Exclusion reason: Methods. [pmid: 20123337].
1027 Private sector assessment: Helping health plans move beyond the report card. American Public Health Association. 1997. Indianapolis, IN (USA). Exclusion reason: No outcome data.
1028 Otani K. Enrollees’ global rating process of health care with the national CAHPS Benchmarking Database. Health Care Manage Rev. Jul–Sep. 2006;31(3):205-12. Exclusion reason: Methods. [pmid: 16877888].
1029 Paarlberg KM, Lal M. Patient influence in OB/GYN: Does it improve quality of care?. (Abstracts Supplement). Journal of Obstetrics & Gynaecology. Jan. 2nd. 2011;31(Supplement):13-4. Exclusion reason: Wrong topic. [pmid: 21280986].
1030 Packer J. HCFA report names 161 ‘high-mortality’ hospitals. Mod Healthc. May. 6. 1991;21(18):4. Exclusion reason: No outcome data. [pmid: 10110316].
1031 Pai AB, Boyd A, Depczynski J, et al. Reduced drug use and hospitalization rates in patients undergoing hemodialysis who received pharmaceutical care: a 2-year, randomized, controlled study. Pharmacotherapy. Dec. 2009;29(12):1433-40. Exclusion reason: Wrong topic. [pmid: 19947803].
1032 Pallarito K. Pa. hospitals dispute bypass data. Mod Healthc. Dec. 19–26;. 1994;24(51):19. Exclusion reason: No outcome data. [pmid: 10138897].
1033 Palmer T. Management by report card: avoid suspension in a few easy lessons. Mater Manag Health Care. Oct. 1995;4(10):16-7. Exclusion reason: No outcome data. [pmid: 10151577].
1034 Pandey DK, Cursio JF. Data feedback for quality improvement of stroke care: CAPTURE Stroke experience. Am J Prev Med. Dec. 2006;31(6 Suppl 2):S224-9. Exclusion reason: Wrong topic. [pmid: 17178307].
1035 Papanikolaou F, Goldsmith CH. Testing Quality Improvement Interventions Clin Plast Surg Clinics in Plastic Surgery. 2008;35(2):297-303. Exclusion reason: Wrong topic.
1036 Parenteau MA. Informing consumers through simplified nursing home evaluations. J Leg Med. Oct–Dec. 2009;30(4):545-62. Exclusion reason: No outcome data. [pmid: 19953407].
1037 Parisi LL, Sulfaro M. Six steps to maximizing HEDIS results. J Nurs Care Qual. Dec. 1996;11(2):8. Exclusion reason: No outcome data. [pmid: 8987312].
1038 Parker M. Clinician report cards and the limits of evidence-based patient choice Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:27-40. Exclusion reason: Background.
1039 Parkinson J, Tsasis P, Porporato M. A critical review of financial measures as reported in the Ontario hospital balanced scorecard. J Health Care Finance. Winter. 2007;34(2):48-56. Exclusion reason: Wrong topic. [pmid: 18972993].
1040 Parkosewich J, Funk M, Bradley EH. Applying five key success factors to optimize the quality of care for patients hospitalized with coronary artery disease. Prog Cardiovasc Nurs. Summer. 2005;20(3):111-6. Exclusion reason: Background. [pmid: 16030411].
1041 Partridge L, Szlyk CI. National Medicaid HEDIS Database/Benchmark Project : pilot-year experience and benchmark results. New York, N.Y. Commonwealth Fund. 2000. Exclusion reason: Background.
1042 Patel AR. Information in Medicare HMO markets: The interplay of advertising and report cards. University of Pennsylvania. 2011. Exclusion reason: Wrong topic.
1043 Patel V. Raising awareness of consumers’ options in the individual health insurance market. Health Aff (Millwood). Jul–Dec. Suppl Web Exclusives. 2002:W367-71. Exclusion reason: Background. [pmid: 12703594].
1044 Pawlson G. Comprehensive HEDIS measures for diabetic patients. Manag Care. Aug. 2000;9(8 Suppl):5-10. discussion 24–8. Exclusion reason: Wrong topic. [pmid: 11729416].
1045 Peabody J. Why we love quality but hate to measure it. Qual Manag Health Care. Apr–Jun. 2006;15(2):116-20. Exclusion reason: Background. [pmid: 16622360].
1046 Pelonero AL, Johnson RL. Economic grand rounds: A pay-for-performance program for behavioral health care practitioners. Psychiatr Serv. Apr. 2007;58(4):442-4. Exclusion reason: Wrong topic. [pmid: 17412840].
1047 Pennbridge J, Moya R, Rodrigues L. Questionnaire survey of California consumers’ use and rating of sources of health care information including the Internet. West J Med. Nov–Dec. 1999;171(5–6):302-5. Exclusion reason: Wrong topic. [pmid: 10639865].
1048 Percy A. United States. Congressional Budget O. Quality initiatives undertaken by the Veterans Health Administration. Washington, DC. Congress of the United States, Congressional Budget Office. 2009. Exclusion reason: Wrong topic.
1049 Peters C, Cowley M, Standiford L. The process of outcomes management in an acute care facility. Nurs Adm Q. Fall. 1999;24(1):75-89. Exclusion reason: Wrong topic. [pmid: 10765248].
1050 Peters E, Hibbard J, Slovic P, et al. Numeracy skill and the communication, comprehension, and use of risk-benefit information. Health Aff (Millwood). May–Jun. 2007;26(3):741-8. Exclusion reason: Wrong topic. [pmid: 17485752].
1051 Petersen C. Evolution of HEDIS forces plans to reveal their results. Managed Healthcare. 2000;10(7):46. Exclusion reason: No outcome data.
1052 Peterson ED, Roe MT, Chen AY, et al. The NCDR ACTION Registry-GWTG: transforming contemporary acute myocardial infarction clinical care. Heart. Nov. 2010;96(22):1798-802. Exclusion reason: Wrong topic. [pmid: 20736202].
1053 Peterson ED, Roe MT, Rumsfeld JS, et al. A call to ACTION (acute coronary treatment and intervention outcomes network): a national effort to promote timely clinical feedback and support continuous quality improvement for acute myocardial infarction. Circ Cardiovasc Qual Outcomes. Sep. 2009;2(5):491-9. Exclusion reason: Wrong topic. [pmid: 20031882].
1054 Philibert I. Can hospital rankings measure clinical and educational quality?. Acad Med. Feb. 2009;84(2):177-84. Exclusion reason: Wrong topic. [pmid: 19174660].
1055 Phillips CD, Hawes C, Lieberman T, et al. Where should Momma go? Current nursing home performance measurement strategies and a less ambitious approach. BMC Health Serv Res. 2007;7:93. Exclusion reason: No outcome data. [pmid: 17592633].
1056 Phillips SA, Zorn MJ. Assessing consumer health information needs in a community hospital. Bull Med Libr Assoc. Jul. 1994;82(3):288-93. Exclusion reason: Wrong topic. [pmid: 7920339].
1057 Pine M, Harper DL. Designing and using case mix indices. Manag Care Q. Summer. 1994;2(3):1-11. Exclusion reason: Methods. [pmid: 10136805].
1058 Pinho P. Public reporting of surgical mortality: a survey of New York State cardiothoracic surgeons. Rev Port Cardiol. May. 2000;19(5):637-8. Exclusion reason: Not English. [pmid: 10916437].
1059 Pink GH, Slifkin RT, Coburn AF, et al. Comparative performance data for critical access hospitals. J Rural Health. Fall. 2004;20(4):374-82. Exclusion reason: No outcome data. [pmid: 15551855].
1060 Plumlee KB. Beyond physician referral: consumer information and referral systems as a marketing strategy for hospitals. Hosp Top. Mar–Apr. 1987;65(2):9-14. Exclusion reason: Wrong topic. [pmid: 10283053].
1061 Podratz KC. Quality improvement in gynecologic surgery: the new frontier. Am J Obstet Gynecol. Oct. 2006;195(4):891-5. Exclusion reason: Wrong topic. [pmid: 17000231].
1062 Polk HC Jr, Vallance S. Rapidly expanding demands on hospital quality personnel threaten the quality of their reports. J Am Coll Surg. Oct. 2008;207(4):604-6. Exclusion reason: Wrong topic. [pmid: 18926466].
1063 Pollitt C. The Struggle for Quality: the case of the National Health Service. policy polit Policy & Politics. 1993;21(3):161-70. Exclusion reason: Wrong topic.
1064 Pontes MC, Pontes NM. To treat or not to treat: evidence for “treatment bias” when consumers evaluate physicians. Health Mark Q. 2003;20(4):43-61. Exclusion reason: Wrong topic. [pmid: 15145784].
1065 Poss JW, Jutan NM, Hirdes JP, et al. A review of evidence on the reliability and validity of Minimum Data Set data. Healthc Manage Forum. Spring. 2008;21(1):33-9. Exclusion reason: Background. [pmid: 18814426].
1066 Post L, Allen N. A roadmap for CAHPS: what home health organizations need to know. Home Healthc Nurse. Jan. 2011;29(1):36-42. Exclusion reason: No outcome data. [pmid: 20585259].
1067 Pretzer M. Is the malpractice data bank going public?. Med Econ. Sep. 26. 1994;71(18):80-2. 5. 6. 9. Exclusion reason: No outcome data. [pmid: 10136388].
1068 Preuss GA. High Performance Work Systems and Organizational Outcomes: The Mediating Role of Information Quality. Industrial and Labor Relations Review. 2003;56(4):590-605. Exclusion reason: Wrong topic.
1069 Prins AH, Abu-Hanna A. Requirements analysis of information services for patients on a general practitioner’s website--patient and general practitioner’s perspectives. Methods Inf Med. 2007;46(6):629-35. Exclusion reason: Wrong topic. [pmid: 18066411].
1070 Probst C, Paffrath T, Krettek C, et al. Comparative Update on Documentation of Trauma in Seven National Registries. European Journal of Trauma. 2006;32(4):357-64. Exclusion reason: Wrong topic.
1071 Pronovost PJ, Miller M, Wachter RM. The GAAP in quality measurement and reporting. JAMA. Oct. 17. 2007;298(15):1800-2. Exclusion reason: No outcome data. [pmid: 17940238].
1072 Pugh MJ, Hanlon JT, Wang CP, et al. Trends in use of high-risk medications for older veterans: 2004 to 2006. J Am Geriatr Soc. Oct. 2011;59(10):1891-8. Exclusion reason: PR as outcome. [pmid: 21883108].
1073 Qaseem A, Snow V, Gosfield A, et al. Pay for performance through the lens of medical professionalism. Ann Intern Med. Mar. 16. 2010;152(6):366-9. Exclusion reason: Background. [pmid: 20231567].
1074 Qian F, Lustik SJ, Diachun CA, et al. Association between Leapfrog safe practices score and hospital mortality in major surgery. Med Care. Dec. 2011;49(12):1082-8. Exclusion reason: Methods. [pmid: 22082837].
1075 Quattromani E, Powell ES, Khare RK, et al. Hospital-reported data on the pneumonia quality measure “Time to First Antibiotic Dose” are not associated with inpatient mortality: results of a nationwide cross-sectional analysis. Acad Emerg Med. May. 2011;18(5):496-503. Exclusion reason: Methods. [pmid: 21545670].
1076 Quincy L. Making health insurance cost-sharing clear to consumers: challenges in implementing health reform’s insurance disclosure requirements. Issue Brief (Commonw Fund). Feb. 2011;2:1-17. Exclusion reason: Wrong topic. [pmid: 21348328].
1077 Quinn JB. Health care report cards. How good are the HMOs your company chooses?. Newsweek. Oct. 17. 1994;124(16):57. Exclusion reason: No outcome data. [pmid: 10137613].
1078 Rabson B. A push for higher quality care. Transparency, consumer education needed for health reform success. Mod Healthc. Oct. 25. 2010;40(43):26-7. Exclusion reason: No outcome data. [pmid: 21053448].
1079 Radford A, Pink G, Ricketts T. A comparative performance scorecard for federally funded community health centers in North Carolina. J Healthc Manag. Jan–Feb. 2007;52(1):20-31. discussion 2–3. Exclusion reason: Methods. [pmid: 17288115].
1080 Rains SA. Perceptions of traditional information sources and use of the world wide web to seek health information: findings from the health information national trends survey. J Health Commun. Oct–Nov. 2007;12(7):667-80. Exclusion reason: Background. [pmid: 17934943].
1081 Ramsey SD, Zeliadt SB, Arora NK, et al. Access to information sources and treatment considerations among men with local stage prostate cancer. Urology. Sep. 2009;74(3):509-15. Exclusion reason: Wrong topic. [pmid: 19589564].
1082 Randolph G, Esporas M, Provost L, et al. Model for improvement - Part Two: Measurement and feedback for quality improvement efforts. Pediatr Clin North Am. Aug. 2009;56(4):779-98. Exclusion reason: Background. [pmid: 19660627].
1083 Rao P. Selecting a rehabilitation program for people with stroke. Clin Geriatr Med. Nov. 1999;15(4):857-68. Exclusion reason: Background. [pmid: 10499939].
1084 Raval MV, Bilimoria KY, Stewart AK, et al. Using the NCDB for cancer care improvement: an introduction to available quality assessment tools. J Surg Oncol. Jun. 15. 2009;99(8):488-90. Exclusion reason: Wrong topic. [pmid: 19466738].
1085 Raymond AG. Giving consumers the quality information they need. Qual Lett Healthc Lead. Feb. 1995;7(1):15-8. Exclusion reason: No outcome data. [pmid: 10151586].
1086 Redberg RF, Benjamin EJ, Bittner V, et al. AHA/ACCF [corrected] 2009 performance measures for primary prevention of cardiovascular disease in adults: A report of the American College of Cardiology Foundation/American Heart Association task force on performance measures. Circulation. Sep. 29. 2009;120(13):1296-336. Exclusion reason: Wrong topic. [pmid: 19770388].
1087 Reeves D, Doran T, Valderas JM, et al. How to identify when a performance indicator has run its course. BMJ. 2010;340:c1717. Exclusion reason: Methods. [pmid: 20371570].
1088 Reeves MJ, Grau-Sepulveda MV, Fonarow GC, et al. Are quality improvements in the get with the guidelines: stroke program related to better care or better data documentation?. Circ Cardiovasc Qual Outcomes. Sep. 2011;4(5):503-11. Exclusion reason: Wrong topic. [pmid: 21828344].
1089 Remington L. HCAHPS: What is it? And what is the potential impact on home care. Deirdre Mylod Remington Report. 2008:14-5. Exclusion reason: Background.
1090 Resnic FS, Welt FG. The public health hazards of risk avoidance associated with public reporting of risk-adjusted outcomes in coronary intervention. J Am Coll Cardiol. Mar. 10. 2009;53(10):825-30. Exclusion reason: Methods. [pmid: 19264236].
1091 Resultan E. Physician report cards. Healthplan. Nov–Dec. 1997;38(6):69-72. Exclusion reason: No outcome data. [pmid: 10176888].
1092 Rhinehart E. Health care consumer report cards: what do patients and families really want to know? What should they want to know?. J Nurs Care Qual. Aug. 1997;11(6):38-41. Exclusion reason: No outcome data. [pmid: 9267118].
1093 Rice BA, Nelson C. Safety in the pediatric ICU: the key to quality outcomes. Crit Care Nurs Clin North Am. Dec. 2005;17(4):431-40. xi. Exclusion reason: Wrong topic. [pmid: 16344212].
1094 Rice T, Gabel J, Levitt L, et al. Workers and their health plans: free to choose?. Health Aff (Millwood). Jan–Feb. 2002;21(1):182-7. Exclusion reason: Wrong topic. [pmid: 11900075].
1095 Richard SA, Rawal S, Martin DK. An ethical framework for cardiac report cards: a qualitative study. BMC Med Ethics. Mar. 28. 2005;6:E3. Exclusion reason: Background. [pmid: 15794818].
1096 Richardson JD. Morbidity and mortality in vascular surgery: the Kentucky experience with a statewide database. Am Surg. Nov. 2006;72(11):1109-11. discussion 26–48. Exclusion reason: Wrong topic. [pmid: 17120956].
1097 Richman R, Lancaster DR. The clinical guideline process within a managed care organization. Int J Technol Assess Health Care. Autumn. 2000;16(4):1061-76. Exclusion reason: Wrong topic. [pmid: 11155828].
1098 Rigge M. Consumer information Dr who?. Health Serv J. Sep. 11. 1997;107(5570):24-6. Exclusion reason: No outcome data. [pmid: 10174002].
1099 Robeznieks A. Quality conundrum. Consumers will get more data, but questions remain about validity, usefulness. Mod Healthc. Nov. 20. 2006;36(46):30-1. Exclusion reason: No outcome data. [pmid: 17153790].
1100 Robinowitz DL, Dudley RA. Public reporting of provider performance: can its impact be made greater?. Annu Rev Public Health. 2006;27:517-36. Exclusion reason: Background. [pmid: 16533128].
1101 Robins CS, Heller A, Myers MA. Financial vulnerability among Medicare managed care enrollees. Health Care Financ Rev. Spring. 2005;26(3):81-92. Exclusion reason: Wrong topic. [pmid: 17290629].
1102 Robinson M. HCFA mortality data are only the beginning. Hospitals. Jan. 20. 1988;62(2):17-8. Exclusion reason: No outcome data. [pmid: 3275575].
1103 Robinson ML. OTA: consumers need better data. Hospitals. Jul. 20. 1988;62(14):24. Exclusion reason: No outcome data. [pmid: 3391544].
1104 Robinson ML. Nursing homes resist release of consumer guides. Hospitals. May. 5. 26. 1988;62(9):8. Exclusion reason: No outcome data. [pmid: 3360427].
1105 Robinson P. Data briefing. Patient reports are simple and useful. Health Serv J. Feb. 7. 2008:21. Exclusion reason: No outcome data. [pmid: 18338454].
1106 Robinson S, Brodie M. Understanding the quality challenge for health consumers: the Kaiser/AHCPR Survey. Jt Comm J Qual Improv. May. 1997;23(5):239-44. Exclusion reason: Wrong topic. [pmid: 9179715].
1107 Rodriguez HP, von Glahn T, Elliott MN, et al. The effect of performance-based financial incentives on improving patient care experiences: a statewide evaluation. J Gen Intern Med. Dec. 2009;24(12):1281-8. Exclusion reason: Background. [pmid: 19826881].
1108 Rodriguez HP, Wilson IB, Landon BE, et al. Voluntary physician switching by human immunodeficiency virus-infected individuals: a national study of patient, physician, and organizational factors. Med Care. Mar. 2007;45(3):189-98. Exclusion reason: Background. [pmid: 17304075].
1109 Rodwin MA. New standards for medical review organizations: holding them and health plans accountable for their decisions. Health Aff (Millwood). Mar. 2011;30(3):519-24. Exclusion reason: Wrong topic. [pmid: 21383371].
1110 Rogers CM. NCQA and HEDIS. Bull Am Coll Surg. Nov. 1998;83(11):8-10. Exclusion reason: No outcome data. [pmid: 10338862].
1111 Rogers G, Smith DP. Reporting comparative results from hospital patient surveys. Int J Qual Health Care. Jun. 1999;11(3):251-9. Exclusion reason: Background. [pmid: 10435847].
1112 Rollins G. HEDIS scores show health plan performance on the rise, but disparities remain. Rep Med Guidel Outcomes Res. Oct. 18. 2002;13(20):7-9. Exclusion reason: No outcome data. [pmid: 12599389].
1113 Rollins G. Sizing up HEDIS: experts take system’s measure. J AHIM A. Jan. 2002;73(1):30-4. quiz 5–6. Exclusion reason: Background. [pmid: 12469659].
1114 Rollins G. Leapfrog standards haven’t made much impact on hospital patient safety practices, report says. Rep Med Guidel Outcomes Res. Mar. 19. 2004;15(6):1-2. 5. 6. Exclusion reason: No outcome data. [pmid: 15040381].
1115 Romano M. Integration demonstration. The CMS’ latest pay-for-performance initiative will test the power of integrated delivery systems to alter doc practice patterns. Mod Healthc. Oct. 31. 2005;35(44):6-7. 16. 1. Exclusion reason: No outcome data. [pmid: 16300201].
1116 Romano PS, Remy LL, Luft HS. Second Report of the California Hospital Outcomes Project (1996): Acute Myocardial Infarction Volume Two: Technical Appendix (table of content). 1996. Exclusion reason: No outcome data.
1117 Romano PS, Zach A, Luft HS, et al. The California Hospital Outcomes Project: using administrative data to compare hospital performance. Jt Comm J Qual Improv. Dec. 1995;21(12):668-82. Exclusion reason: Methods. [pmid: 8688923].
1118 Roohan PJ. Integration of data and management tools into the new york state medicaid managed care encounter data system. J Ambul Care Manage. Oct–Dec. 2006;29(4):291-9. Exclusion reason: Background. [pmid: 16985387].
1119 Rooney HL. Strategic marketing: using information to grow your business. Remington Report. 2004:12-4. Exclusion reason: Wrong topic.
1120 Roper WL, Cutler CM. Health plan accountability and reporting: issues and challenges. Health Aff (Millwood). Mar–Apr. 1998;17(2):152-5. Exclusion reason: No outcome data. [pmid: 9558793].
1121 Rose JR. Uncle Sam seeks a better yardstick. Medical Economics. 1996;73(23):29. Exclusion reason: Background.
1122 Rosenstein AH. Hospital report cards: intent, impact, and illusion. Am J Med Qual. Sep–Oct. 2004;19(5):183-92. Exclusion reason: Background. [pmid: 15532910].
1123 Rosenthal GE, Chren MM, Lasek RJ, et al. What patients should ask of consumers’ guides to health care quality. Eval Health Prof. Sep. 1998;21(3):316-31. Exclusion reason: Background. [pmid: 10350954].
1124 Rosenthal GE, Harper DL. Cleveland health quality choice: a model for collaborative community-based outcomes assessment. Jt Comm J Qual Improv. Aug. 1994;20(8):425-42. Exclusion reason: Methods. [pmid: 8000481].
1125 Rosenthal M, Milstein A. Awakening consumer stewardship of health benefits: prevalence and differentiation of new health plan models. Health Serv Res. Aug. 2004;39(4 Pt 2):1055-70. Exclusion reason: Wrong topic. [pmid: 15230911].
1126 Rosenthal MB, de Brantes FS, Sinaiko AD, et al. Bridges to Excellence--recognizing high-quality care: analysis of physician quality and resource use. Am J Manag Care. Oct. 2008;14(10):670-7. Exclusion reason: Wrong topic. [pmid: 18837645].
1127 Rosenthal MB, Fernandopulle R, Song HR, et al. Paying for quality: providers’ incentives for quality improvement. Health Aff (Millwood). Mar–Apr. 2004;23(2):127-41. Exclusion reason: Wrong topic. [pmid: 15046137].
1128 Roski J, Gregory R. Performance measurement for ambulatory care: moving towards a new agenda. Int J Qual Health Care. Dec. 2001;13(6):447-53. Exclusion reason: Background. [pmid: 11769746].
1129 Roski J, Kim MG. Current efforts of regional and national performance measurement initiatives around the United States. Am J Med Qual. Jul–Aug. 2010;25(4):249-54. Exclusion reason: Background. [pmid: 19729554].
1130 Ross C. QAPI how do you measure up?: Preparing for public reporting in hospice: an overview for success. Home Healthc Nurse. Jan. 2011;29(1):45-51. quiz 2–3. Exclusion reason: Wrong topic. [pmid: 21160343].
1131 Ross EC. Managed behavioral health care premises, accountable systems of care, and AMBHA’S perms. American Managed Behavioral Healthcare Association. Eval Rev. Jun. 1997;21(3):318-21. Exclusion reason: Wrong topic. [pmid: 10183283].
1132 Ross JS, Keyhani S, Keenan PS, et al. Use of recommended ambulatory care services: is the Veterans Affairs quality gap narrowing?. Arch Intern Med. May. 12. 2008;168(9):950-8. Exclusion reason: Wrong topic. [pmid: 18474759].
1133 Ross JS, Sheth S, Krumholz HM. State-sponsored public reporting of hospital quality: results are hard to find and lack uniformity. Health Aff (Millwood). Dec. 2010;29(12):2317-22. Exclusion reason: Background. [pmid: 21134936].
1134 Rothberg MB, Benjamin EM, Lindenauer PK. Public reporting of hospital quality: recommendations to benefit patients and hospitals. J Hosp Med. Nov. 2009;4(9):541-5. Exclusion reason: Background. [pmid: 19514092].
1135 Rothberg MB, Morsi E, Benjamin EM, et al. Choosing the best hospital: the limitations of public quality reporting. Health Aff (Millwood). Nov–Dec. 2008;27(6):1680-7. Exclusion reason: Methods. [pmid: 18997226].
1136 Rothouse M. Providers issue brief: provider profiles. Issue Brief Health Policy Track Serv. Jun. 29. 1999:1-4. Exclusion reason: Background. [pmid: 11073384].
1137 Rowan MS, Hogg W, Martin C, et al. Family physicians’ reactions to performance assessment feedback. Can Fam Physician. Dec. 2006;52(12):1570-1. Exclusion reason: Wrong topic. [pmid: 17279238].
1138 Rowe JW. Pay-for-performance and accountability: related themes in improving health care. Ann Intern Med. Nov. 7. 2006;145(9):695-9. Exclusion reason: Background. [pmid: 17088584].
1139 Rudd J, Glanz K. How individuals use information for health action: Consumer information processing. Health behavior and health education: Theory, research, and practice. San Francisco, CA. Jossey-Bass; US. 1990:115-39. Exclusion reason: Background.
1140 Rudd J, Glanz K. A survey of newspaper coverage of HCFA hospital mortality data. Public Health Rep. Sep–Oct. 1991;106(5):517-23. Exclusion reason: Wrong topic. [pmid: 1910185].
1141 Rulon V, Sica J. The evolution of HEDIS: 3.0 and beyond. J AHIMA. Jun. 4. 1997;68(6):32-8. quiz 9–40. Exclusion reason: Background. [pmid: 10167801].
1142 Runy LA. The American Hospital Association-McKesson Quest for Quality Prize 2006 winner. Cincinnati Children’s Hospital Medical Center. Aiming to be ‘the best at getting better’. Hosp Health Netw. Sep. 2006;80(9):48-50. Exclusion reason: No outcome data. [pmid: 17036766].
1143 Ruskin A. Empowering Patients to Act Like Consumers: A Proposal Creating Price and Quality Choice Within Health Care. St. John’s Law Review. Winter99. 1999;73(1):651-99. Exclusion reason: Background.
1144 Rutherford GW, Backer HD. Medicaid managed care and public health data. Public Health Rep. May–Jun. 1999;114(3):225-30. Exclusion reason: Background. [pmid: 10476991].
1145 Ruthven L. Will NCQA/HEDIS take health care to the promised land?. Manag Care Interface. Dec. 2000;13(12):62-3. Exclusion reason: No outcome data. [pmid: 11141725].
1146 Rutledge N. The 411 on HCAHPS. Nurs Manage. Aug. 2008;39(8):29-32. Exclusion reason: Background. [pmid: 18690149].
1147 Ryan AM. Effects of the Premier Hospital Quality Incentive Demonstration on Medicare patient mortality and cost. Health Serv Res. Jun. 2009;44(3):821-42. Exclusion reason: Wrong topic. [pmid: 19674427].
1148 Ryan AM, Burgess JF Jr, Tompkins CP, et al. The relationship between Medicare’s process of care quality measures and mortality. Inquiry. Fall. 2009;46(3):274-90. Exclusion reason: Methods. [pmid: 19938724].
1149 Safavi K. Paying for efficiency. Journal of healthcare management/American College of Healthcare Executives. 2006;51(2). Exclusion reason: Wrong topic.
1150 Sage WM. Regulating through information: disclosure laws and American health care. Columbia Law Rev. Nov. 1999;99(7):1701-829. Exclusion reason: Background. [pmid: 10848100].
1151 Sainfort F, Booske BC. Role of information in consumer selection of health plans. Health Care Financ Rev. Fall. 1996;18(1):31-54. Exclusion reason: Wrong topic. [pmid: 10165036].
1152 Sandoval GA, Barnsley J, Berta W, et al. Sustained public preferences on hospital performance across Canadian provinces. Health Policy. Oct. 2007;83(2–3):246-56. Exclusion reason: Background. [pmid: 17335932].
1153 Sandrick K. For HEDIS to succeed, MCOs must get a read on labs’ needs. CAP Today. Jul. 2000;14(7):30. 4. 6. 8. Exclusion reason: No outcome data. [pmid: 11066544].
1154 Sandrick K. One giant leap for quality. When boards get behind quality initiatives, patient care benefits. Trustee. Mar. 2005;58(3):22-4. 6. 2. Exclusion reason: Wrong topic. [pmid: 15825940].
1155 Sandy LG. The future of physician profiling. J Ambul Care Manage. Jul. 1999;22(3):11-6. Exclusion reason: Background. [pmid: 11184875].
1156 Sangl JA, Wolf LF. Role of consumer information in today’s health care system. Health Care Financ Rev. Fall. 1996;18(1):1-8. Exclusion reason: Background. [pmid: 10165025].
1157 Santiago JM. Use of the balanced scorecard to improve the quality of behavioral health care. Psychiatr Serv. Dec. 1999;50(12):1571-6. Exclusion reason: No outcome data. [pmid: 10577875].
1158 Saphir A. Nursing homes embrace Internet. Mod Healthc. Jan. 24. 2000;30(4):36. Exclusion reason: No outcome data. [pmid: 11009990].
1159 Sari N. Do competition and managed care improve quality?. Health Econ. Oct. 2002;11(7):571-84. Exclusion reason: Background. [pmid: 12369060].
1160 Scalise D. What insurers know about your hospital and how they are using it. Hosp Health Netw. Jan. 2004;78(1):34-8. 2. Exclusion reason: No outcome data. [pmid: 14768449].
1161 Scalise D. Two states, two stories. Hosp Health Netw. Nov. 2005;79(11):40-2. 4. Exclusion reason: No outcome data. [pmid: 16396132].
1162 Scalise D. The Survey Says…. Hosp Health Netw. 2005;79(10):14. Exclusion reason: No outcome data. [pmid: 16333993].
1163 Scanlon DP, Chernew M. Managed Care and Performance Measurement: Implications for Insurance Markets. N Am Actuar J. 2000;4:128. Exclusion reason: Background.
1164 Scanlon DP, Chernew M, Lave JR. Consumer health plan choice: current knowledge and future directions. Annu Rev Public Health. 1997;18:507-28. Exclusion reason: No outcome data. [pmid: 9143729].
1165 Scanlon DP, Lindrooth RC, Christianson JB. Steering patients to safer hospitals? The effect of a tiered hospital network on hospital admissions. Health Serv Res. Oct. 2008;43(5 Pt 2):1849-68. Exclusion reason: Wrong topic. [pmid: 18761676].
1166 Scanlon DP, Swaminathan S, Lee W, et al. Does competition improve health care quality?. Health Serv Res. Dec. 2008;43(6):1931-51. Exclusion reason: PR as outcome. [pmid: 18793214].
1167 Scanlon M, Rice T, Wetzel R, et al. The VPS database - A multi-institutional pediatric critical care registry. Pediatric Critical Care Medicine. 2011;12(3):A27. Exclusion reason: Wrong topic.
1168 Schaefer C, Schwarz S. Doctor rating sites: which of them find the best doctors in Germany?. Z Evid Fortbild Qual Gesundhwes. 2010;104(7):572-7. Exclusion reason: No outcome data. [pmid: 21095610].
1169 Schallenberg J, Hasenbein U, Wallesch CWG. Contents of German Hospitals’ Standardized Quality Reports Covering the Year 2004 with Respect to Departments of Neurology. Aktuelle Neurologie. 2006;33(9):503-8. Exclusion reason: No outcome data.
1170 Schauffler HH, Mordavsky JK. Consumer reports in health care: do they make a difference?. Annu Rev Public Health. 2001;22:69-89. Exclusion reason: Background. [pmid: 11274512].
1171 Schiller Z, Galen M. A Consumer’s Guide for Health-Care Shoppers. BusinessWeek. 1993;(3317):52-4. Exclusion reason: No outcome data.
1172 Schnaier JA, Sweeny SF, Williams VS, et al. Special issues addressed in the CAHPS survey of Medicare managed care beneficiaries. Consumer Assessment of Health Plans Study. Med Care. Mar. 1999;37(3 Suppl):MS69-78. Exclusion reason: Methods. [pmid: 10098561].
1173 Schneider EC, Lieberman T. Publicly disclosed information about the quality of health care: response of the US public. Qual Health Care. Jun. 2001;10(2):96-103. Exclusion reason: No outcome data. [pmid: 11389318].
1174 Schneider EC, Zaslavsky AM, Epstein AM. Quality of care in for-profit and not-for-profit health plans enrolling Medicare beneficiaries. Am J Med. Dec. 2005;118(12):1392-400. Exclusion reason: PR as outcome. [pmid: 16378784].
1175 Schneidman D. The public dissemination of physician-specific mortality data: who has the right to know?. Bull Am Coll Surg. Aug. 1993;78(8):31-7. Exclusion reason: Background. [pmid: 10127505].
1176 Schnelle JF, Bates-Jensen BM, Chu L, et al. Accuracy of nursing home medical record information about care-process delivery: implications for staff management and improvement. J Am Geriatr Soc. Aug. 2004;52(8):1378-83. Exclusion reason: Background. [pmid: 15271130].
1177 Schoenbaum SC, McCarthy D, Schoen C, et al. The Agency for Healthcare Research and Quality’s National Healthcare Quality Report, 2006. [New York, NY]. Commonwealth Fund. 2007. Exclusion reason: Wrong topic.
1178 Schoenman JA, Sutton JP, Elixhauser A, et al. Understanding and enhancing the value of hospital discharge data. Med Care Res Rev. Aug. 2007;64(4):449-68. Exclusion reason: Wrong topic. [pmid: 17684112].
1179 Schold JD, Srinivas TR, Howard RJ, et al. The association of candidate mortality rates with kidney transplant outcomes and center performance evaluations. Transplantation. Jan. 15. 2008;85(1):1-6. Exclusion reason: Methods. [pmid: 18192903].
1180 Schostak M, Baumunk D, Jagota A, et al. Time trends in prostate cancer surgery: data from an Internet-based multicentre database. BJU Int. Feb. 2012;109(3):355-9. Exclusion reason: Wrong topic. [pmid: 21883819].
1181 Schriefer J, Urden LD, Rogers S. Report cards: tools for managing pathways and outcomes. Outcomes Manag Nurs Pract. Oct–Dec. 1997;1(1):14-9. Exclusion reason: Wrong topic. [pmid: 9432438].
1182 Schroeder J, Lamb S. Data initiatives: HEDIS and the New England Business Coalition. Am J Med Qual. Spring. 1996;11(1):S58-62. Exclusion reason: Methods. [pmid: 8763237].
1183 Schull MJ, Guttmann A, Leaver CA, et al. Prioritizing performance measurement for emergency department care: consensus on evidence-based quality of care indicators. CJEM. Sep. 2011;13(5):300-9. E28. 43. Exclusion reason: Methods. [pmid: 21955411].
1184 Schwamm L, Reeves MJ, Frankel M. Designing a sustainable national registry for stroke quality improvement. Am J Prev Med. Dec. 2006;31(6 Suppl 2):S251-7. Exclusion reason: Background. [pmid: 17178314].
1185 Schwappach DL, Schubert HJ. [To disclose or not to disclose? Chances and risks of the publication of medical quality comparisons]. Dtsch Med Wochenschr. Dec. 2007;132(49):2637-42. Exclusion reason: Unable to obtain. [pmid: 18050030].
1186 Schwartz KL, Roe T, Northrup J, et al. Family medicine patients’ use of the Internet for health information: a MetroNet study. J Am Board Fam Med. Jan–Feb. 2006;19(1):39-45. Exclusion reason: Wrong topic. [pmid: 16492004].
1187 Schwien T, McCaffrey K. Improving home health performance -- a new multi-dimensional approach. Remington Report. 2008:11-3. Exclusion reason: Wrong topic.
1188 Scott I. What are the most effective strategies for improving quality and safety of health care?. Intern Med J. Jun. 2009;39(6):389-400. Exclusion reason: Background. [pmid: 19580618].
1189 Scott IA. Pay for performance in health care: strategic issues for Australian experiments. Med J Aust. Jul. 2. 2007;187(1):31-5. Exclusion reason: Background. [pmid: 17605700].
1190 Scott IA, Brand CA, Phelps GE, et al. Using hospital standardised mortality ratios to assess quality of care--proceed with extreme caution. Med J Aust. Jun. 20. 2011;194(12):645-8. Exclusion reason: No outcome data. [pmid: 21692724].
1191 Scott IA, Ward M. Public reporting of hospital outcomes based on administrative data: risks and opportunities. Med J Aust. Jun. 5. 2006;184(11):571-5. Exclusion reason: No outcome data. [pmid: 16768665].
1192 Scott L. It’s all about the outcomes. (cover story). Hosp Health Netw. 2010;84(12):22-6. Exclusion reason: Background. [pmid: 21268499].
1193 Scott M. Patient satisfaction. Survey tools changing as result of CMS mandate. Hosp Health Netw. Feb. 2007;81(2):18. Exclusion reason: Wrong topic. [pmid: 17373528].
1194 Secco ML, Woodgate RL, Hodgson A, et al. A survey study of pediatric nurses’ use of information sources. Comput Inform Nurs. Mar–Apr. 2006;24(2):105-12. Exclusion reason: Wrong topic. [pmid: 16554694].
1195 Segal J. The role of the Internet in doctor performance rating. Pain Physician. May–Jun. 2009;12(3):659-64. Exclusion reason: Wrong topic. [pmid: 19461833].
1196 Seidman JJ, Bass EP, Rubin HR. Review of studies that compare the quality of cardiovascular care in HMO versus non-HMO settings. Med Care. Dec. 1998;36(12):1607-25. Exclusion reason: Wrong topic. [pmid: 9860052].
1197 Sennett C. Implementing the new HEDIS hypertension performance measure. Manag Care. Apr. 2000;9(4 Suppl):2-17. quiz 8–21. Exclusion reason: Wrong topic. [pmid: 11729402].
1198 Serb C. Performance. Hosp Health Netw. 1998;72(3):13. Exclusion reason: No outcome data.
1199 Setodji CM, Reise SP, Morales LS, et al. Differential item functioning by survey language among older Hispanics enrolled in Medicare managed care: a new method for anchor item selection. Med Care. 2011. May. 49(5):461-8. Exclusion reason: Methods. [pmid: 21422959].
1200 Shafi S, Parks J, Ahn C, et al. Centers for Medicare and Medicaid services quality indicators do not correlate with risk-adjusted mortality at trauma centers. J Trauma. Apr. 2010;68(4):771-7. Exclusion reason: Methods. [pmid: 20386272].
1201 Shahian DM. Public reporting of cardiac surgery outcomes--what do we know, what can we expect?. J Card Surg. Nov. 2010;25(6):710-2. Exclusion reason: No outcome data. [pmid: 21070355].
1202 Shahian DM. Public reporting of cardiac surgery performance: introduction. Ann Thorac Surg. Sep. 2011;92(3 Suppl):S1. Exclusion reason: No outcome data. [pmid: 21867787].
1203 Shahian DM, Edwards FH, Jacobs JP, et al. Public reporting of cardiac surgery performance: Part 1--history, rationale, consequences. Ann Thorac Surg. Sep. 2011;92(3 Suppl):S2-11. Exclusion reason: Background. [pmid: 21867789].
1204 Shahian DM, Normand SL, Torchiana DF, et al. Cardiac surgery report cards: comprehensive review and statistical critique. Ann Thorac Surg. Dec. 2001;72(6):2155-68. Exclusion reason: No outcome data. [pmid: 11789828].
1205 Shahian DM, Torchiana DF, Normand SL. Implementation of a cardiac surgery report card: lessons from the Massachusetts experience. Ann Thorac Surg. Sep. 2005;80(3):1146-50. Exclusion reason: Methods. [pmid: 16122520].
1206 Shahian DM, Wolf RE, Iezzoni LI, et al. Variability in the measurement of hospital-wide mortality rates. N Engl J Med. Dec. 23. 2010;363(26):2530-9. Exclusion reason: Methods. [pmid: 21175315].
1207 Shaikh BT, Rabbani F. Health management information system: a tool to gauge patient satisfaction and quality of care. East Mediterr Health J. Jan–Mar. 2005;11(1–2):192-8. Exclusion reason: Wrong topic. [pmid: 16532688].
1208 Shaller D. Implementing and using quality measures for children’s health care: perspectives on the state of the practice. Pediatrics. Jan. 2004;113(1 Pt 2):217-27. Exclusion reason: Wrong topic. [pmid: 14702504].
1209 Shaller D. Getting ready for H-CAHPS survey: How does your hospital compare?. AHA News. 2007;43(11):4-5. Exclusion reason: No outcome data.
1210 Shaller D, Sofaer S, Findlay SD, et al. Consumers and quality-driven health care: a call to action. Health Aff (Millwood). Mar–Apr. 2003;22(2):95-101. Exclusion reason: No outcome data. [pmid: 12674411].
1211 Shea JA, Aguirre AC, Sabatini J, et al. Developing an illustrated version of the Consumer Assessment of Health Plans (CAHPS). Jt Comm J Qual Patient Saf. Jan. 2005;31(1):32-42. Exclusion reason: Background. [pmid: 15691208].
1212 Shea JA, Guerra CE, Weiner J, et al. Adapting a patient satisfaction instrument for low literate and Spanish-speaking populations: comparison of three formats. Patient Educ Couns. Oct. 2008;73(1):132-40. Exclusion reason: PR as outcome. [pmid: 18486414].
1213 Sheahan M, Little R, Leggat SG. Performance reporting for consumers: issues for the Australian private hospital sector. Aust New Zealand Health Policy. 2007;4:5. Exclusion reason: Background. [pmid: 17537238].
1214 Shearer A, Cronin C. The state-of-the-art of online hospital public reporting : a review of fifty-one websites : report prepared for the CMS hospital three state pilot project. [Oakbrook Terrace]; [Easton, Md]; [Baltimore]. Joint Commission on Accreditation of Healthcare Organizations ; Delmarva Foundation ; Centers for Medicare & Medicaid Services. 2005. Exclusion reason: Background.
1215 Sheehan A, Manteuffel B, Stormann C, et al. Evaluation and continuous quality improvement. The system of care handbook: Transforming mental health services for children, youth, and families. Baltimore, MD. Paul H Brookes Publishing; US. 2008:329-58. Exclusion reason: No outcome data.
1216 Sheeran T. A survey of psychiatric outpatients on quality of care. Psychiatr Serv. Jul. 2003;54(7):1031-3. Exclusion reason: Wrong topic. [pmid: 12851443].
1217 Shekelle PG, Staff HF. Does Public Release of Performance Results Improve Quality of Care?: A Systematic Review Health Foundation, The. 2008. Exclusion reason: No outcome data.
1218 Shen Y. Selection incentives in a performance-based contracting system. Health Serv Res. Apr. 2003;38(2):535-52. Exclusion reason: Wrong topic. [pmid: 12785560].
1219 Shih SC, Bost JE, Pawlson LG. Standardized health plan reporting in four areas of preventive health care. Am J Prev Med. May. 2003;24(4):293-300. Exclusion reason: PR as outcome. [pmid: 12726866].
1220 Shimada SL, Zaslavsky AM, Zaborski LB, et al. Market and beneficiary characteristics associated with enrollment in Medicare managed care plans and fee-for-service. Med Care. May. 2009;47(5):517-23. Exclusion reason: Wrong topic. [pmid: 19365291].
1221 Shinkman R. Report cards target hidden cost of illness. Mod Healthc. Oct. 18. 8. 1999;29(42):76-9. Exclusion reason: Wrong topic. [pmid: 10623233].
1222 Shipton H, Armstrong C, West M, et al. The impact of leadership and quality climate on hospital performance. Int J Qual Health Care. Dec. 2008;20(6):439-45. Exclusion reason: Wrong topic. [pmid: 18786932].
1223 Shoemaker W. Benchmarking boon: tapping publicly available data to improve performance. Healthc Financ Manage. Jun. 2011;65(6):88-94. Exclusion reason: No outcome data. [pmid: 21692380].
1224 Shojania KG, Forster AJ. Hospital mortality: when failure is not a good measure of success. CMAJ. Jul. 15. 2008;179(2):153-7. Exclusion reason: Methods. [pmid: 18625987].
1225 Short PF, Taylor AK. Premiums, benefits, and employee choice of health insurance options. J Health Econ. Dec. 1989;8(3):293-311. Exclusion reason: Wrong topic. [pmid: 10296710].
1226 Shortell SM, Schmittdiel J, Wang MC, et al. An empirical assessment of high-performing medical groups: results from a national study. Med Care Res Rev. Aug. 2005;62(4):407-34. Exclusion reason: Wrong topic. [pmid: 16049132].
1227 Shroyer AL, Dauber I, Jones RH, et al. Provider perceptions in using outcomes data to improve clinical practice. Ann Thorac Surg. Dec. 1994;58(6):1877-80. Exclusion reason: Background. [pmid: 7979786].
1228 Shueman SA, Allen K. Critical indicators of quality of a service system: What graduate school never taught you about accountability. Handbook of quality management in behavioral health. Dordrecht, Netherlands. Kluwer Academic Publishers; Netherlands. 2000:145-56. Exclusion reason: Background.
1229 Shueman SA, Troy WG. Quality assurance in managed systems Managed behavioral health care: An industry perspective. Springfield, IL, England. Charles C Thomas, Publisher; England. 1994:131-48. Exclusion reason: Background.
1230 Shugarman LR, Brown J. Nursing home selection : how do consumers choose? Volume I, Findings from focus groups of consumers and information intermediaries. Washington, D.C. United States. Dept. of Health and Human Services, Office of Disability, Aging and Long-Term Care Policy. 2007. Exclusion reason: No outcome data.
1231 Shwartz M, Cohen AB, Restuccia JD, et al. How well can we identify the high-performing hospital?. Med Care Res Rev. Jun. 2011;68(3):290-310. Exclusion reason: Methods. [pmid: 21156708].
1232 Siegel C, Haugland G, Chambers ED. Performance measures and their benchmarks for assessing organizational cultural competency in behavioral health care service delivery. Adm Policy Ment Health. Nov. 2003;31(2):141-70. Exclusion reason: Wrong topic. [pmid: 14756197].
1233 Siegel CA. Creating quality measures in IBD. Gastroenterol Hepatol Gastroenterology and Hepatology. 2010;6(4):218-20. Exclusion reason: Wrong topic.
1234 Sikka R. Pay for performance in emergency medicine. Ann Emerg Med. Jun. 2007;49(6):756-61. Exclusion reason: Background. [pmid: 16979264].
1235 Silow-Carroll S, Alteras T, Meyer AJ. Hospital Quality Improvement: Strategies and Lessons From US Hospitals: The Commonwealth Fund. 2007. Exclusion reason: Background.
1236 Silverstein B, Findley PA, Bode RK. Usefulness of the nursing home quality measures and quality indicators for assessing skilled nursing facility rehabilitation outcomes. Arch Phys Med Rehabil. Aug. 2006;87(8):1021-5. Exclusion reason: Methods. [pmid: 16876545].
1237 Simone JV. Origins of the quality oncology practice initiative. J Oncol Pract. Nov. 2009;5(6):269-70. Exclusion reason: No outcome data. [pmid: 21479076].
1238 Simpson AG, DeGuzman PB, Barbieri KE, et al. Implementation of an Electronic Health Record with an Embedded Quality Improvement Program to Improve the Longitudinal Care of Outpatients with Coronary Artery. J Clinical Outcomes Management. 2008;15(7):338-43. Exclusion reason: Wrong topic.
1239 Simon A. Patient involvement and information preferences on hospital quality: Results of an empirical analysis. Unfallchirurg. 2011;114(1):73-8. Exclusion reason: Unable to obtain. [pmid: 21136034].
1240 Sims B. Government responds to report. Nursing & Residential Care. 2005;7(10):436. Exclusion reason: No outcome data.
1241 Sinaiko AD. Essays on consumer behavior in health care. 2010. Exclusion reason: Wrong topic.
1242 Sinaiko AD. How do quality information and cost affect patient choice of provider in a tiered network setting? Results from a survey. Health Serv Res. Apr. 2011;46(2):437-56. Exclusion reason: Wrong topic. [pmid: 21143478].
1243 Sinaiko AD, Rosenthal MB. Consumer experience with a tiered physician network: early evidence. Am J Manag Care. Feb. 2010;16(2):123-30. Exclusion reason: Wrong topic. [pmid: 20148617].
1244 Singh H, Kalavar J. Quality of care for hypertension and diabetes in federal- versus commercial-managed care organizations. Am J Med Qual. Jan–Feb. 2004;19(1):19-24. Exclusion reason: Wrong topic. [pmid: 14977021].
1245 Siomos EE, Newsom RS, Camponeschi J, et al. A statewide collaboration to monitor diabetes quality improvement among Wisconsin health plans. Am J Manag Care. May. 2005;11(5):332-6. Exclusion reason: Wrong topic. [pmid: 15898222].
1246 Sirio CA, Angus DC, Rosenthal GE. Cleveland Health Quality Choice (CHQC)--an ongoing collaborative, community-based outcomes assessment program. New Horiz. Aug. 1994;2(3):321-5. Exclusion reason: Background. [pmid: 8087590].
1247 Sirio CA, Harper D. Designing the Optimal Health Assessment System: the Cleveland Quality Choice (CHQC) example. Am J Med Qual. Spring. 1996;11(1):S66-9. Exclusion reason: No outcome data. [pmid: 8763239].
1248 Siu AL, Rand C, John AHF, et al. Choosing quality-of-care measures based on the expected impact of improved quality of care for the major causes of mortality and morbidity. Santa Monica, CA. RAND. 1992. Exclusion reason: Background.
1249 Skolnick AA. A FACCT-filled agenda for public information. Foundation for Accountability. JAMA. Nov. 19. 1997;278(19):1558. Exclusion reason: No outcome data. [pmid: 9370481].
1250 Skriabikova O, Pavlova M, Groot W. Empirical models of demand for out-patient physician services and their relevance to the assessment of patient payment policies: a critical review of the literature. Int J Environ Res Public Health. Jun. 2010;7(6):2708-25. Exclusion reason: Wrong topic. [pmid: 20644697].
1251 Sloane PD, Wroth T, Halladay J, et al. How eight primary care practices initiated and maintained quality monitoring and reporting. J Am Board Fam Med. Jul–Aug. 2011;24(4):360-9. Exclusion reason: Methods. [pmid: 21737760].
1252 Sloane T. Transparent motives. Hospitals caught between a Newt and a hard place on pricing. Mod Healthc. Mar. 27. 2006;36(13):28. Exclusion reason: Background. [pmid: 16617903].
1253 Slovensky DJ, Fottler MD, Houser HW. Developing an outcomes report card for hospitals: a case study and implementation guidelines. J Healthc Manag. Jan–Feb. 1998;43(1):15-34. discussion 5. Exclusion reason: No outcome data. [pmid: 10178790].
1254 Smart DT. Ensuring health care quality: perspective from a member of NCQA’s Committee on performance measurement. National Committee on Quality Assurance. Clin Ther. Nov–Dec. 1997;19(6):1532-9. Exclusion reason: No outcome data. [pmid: 9444458].
1255 Smith B, Dews P. The Validity and Reliability of the UIMS Physician Satisfaction Survey. Ethnicity & disease. 2007;17(4):S5-16-S5-7. Exclusion reason: Methods.
1256 Smith BD. Adherence to the National Quality Forum (NQF) Breast Cancer Measures Within Cancer Clinical Trials: A Review From ACOSOG Z0010: Wilke LG, Ballman KV, McCall LM, et al (Duke Univ Med Ctr, Durham, NC; Mayo Clinic, Rochester, MN; et al). Ann Surg Oncol. 2010;17:1989-1994. Breast Diseases: A Year Book Quarterly. 2011;22(1):26–8. Exclusion reason: Wrong topic. [pmid: 20309640].
1257 Smith BD, Smith GL, Roberts KB, et al. Baseline utilization of breast radiotherapy before institution of the Medicare practice quality reporting initiative. Int J Radiat Oncol Biol Phys. Aug. 1. 2009;74(5):1506-12. Exclusion reason: Wrong topic. [pmid: 19395182].
1258 Smith D, Caragian N, Kazlo E, et al. Can we make reports of end-of-life care quality more consumer-focused? results of a nationwide quality measurement program. J Palliat Med. Mar. 2011;14(3):301-7. Exclusion reason: Methods. [pmid: 21288125].
1259 Smith DB. Reducing racial inequalities in health care use and outcomes: The role of report cards. American Public Health Association. 1996. New York, NY (USA). Exclusion reason: Unable to obtain.
1260 Smith DP, Rogers G, Dreyfus A, et al. Balancing accountability and improvement: a case study from Massachusetts. Jt Comm J Qual Improv. May. 2000;26(5):299-312. Exclusion reason: No outcome data. [pmid: 18350774].
1261 Smith P. On the Unintended Consequences of Publishing Performance Data in the Public Sector. Int J of Public Administration. 1995;18(2/3):277. Exclusion reason: No outcome data.
1262 Smith PC. Performance Measurement in Health Care: History, Challenges and Prospects. Public Money & Management. 2005;25(4):213-20. Exclusion reason: Background.
1263 Smith VK. The role of states in improving health and health care for young children. Issue Brief (Commonw Fund). Jul. 2005;(843):1-8. Exclusion reason: Background. [pmid: 16184683].
1264 Sofaer S. What information do consumers need? A conversation with Shoshanna Sofaer, DrPH. Interview by Diana Madden. Internist. Sep. 1993;34(8):9-12. 8. Exclusion reason: No outcome data. [pmid: 10129088].
1265 Sofaer S. Informing and protecting consumers under managed competition. Health Aff (Millwood). 1993;12(Suppl):76-86. Exclusion reason: No outcome data. [pmid: 8477946].
1266 Sofaer S, Gruman J. Consumers of health information and health care: challenging assumptions and defining alternatives. Am J Health Promot. Nov–Dec. 2003;18(2):151-6. Exclusion reason: Background. [pmid: 14621411].
1267 Sofaer S, Gruman J, Connaughton S, et al. Developing performance indicators that reflect an expanded view of health: findings from the use of an innovative methodology. Jt Comm J Qual Improv. Apr. 2000;26(4):189-202. Exclusion reason: Wrong topic. [pmid: 10749004].
1268 Sofaer S, Kreling B, Kenney E, et al. Family members and friends who help beneficiaries make health decisions. Health Care Financ Rev. Fall. 2001;23(1):105-21. Exclusion reason: No outcome data. [pmid: 12500366].
1269 Sofaer S. Public Reporting of the CAHPS Hospital Survey: Research to Support Understanding and use of the Hospital Compare Website. American Public Health Association. 2006. Exclusion reason: Unable to obtain.
1270 Solomon LS. Assessing patient-reported quality in medical group practices : an analysis of data from the National field test of the group-level CAHPS instrument. 2001. Exclusion reason: Methods.
1271 Solovy A, Hoppszallern S, Brown SB. Are patients happier at most wired hospitals?. Hosp Health Netw. Jul. 2008;82(7):30-45. 1. Exclusion reason: Wrong topic. [pmid: 18714701].
1272 Sorell T. Safety, accountability, and ‘choice’ after the Bristol Inquiry Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:52-64. Exclusion reason: Background.
1273 Southwick K. HEDIS sharper but still coming up short. CAP Today. Oct. 20. 1996;10(10):17-2. Exclusion reason: No outcome data. [pmid: 10166413].
1274 Southwick K. Report card paradox: ignored by the consumers for whom they are targeted, report cards spur providers to clean house. Strateg Healthc Excell. Sep. 1999;12(9):9-12. Exclusion reason: No outcome data. [pmid: 10620899].
1275 Southwick K. Report card paradox. Healthc Strateg. Sep. 1999;3(9):7-8. Exclusion reason: No outcome data. [pmid: 10558156].
1276 Sower V, Duffy J, Kilbourne W, et al. The dimensions of service quality for hospitals: development and use of the KQCAH scale. Health Care Manage Rev. Spring. 2001;26(2):47-59. Exclusion reason: Wrong topic. [pmid: 11293010].
1277 Spath PL. Are report cards measuring up?. J AHIM A. Nov–Dec. 2000;71(10):28-35. quiz 7–8. Exclusion reason: No outcome data. [pmid: 11185856].
1278 Speir AM, Rich JB, Crosby I, et al. Regional collaboration as a model for fostering accountability and transforming health care. Semin Thorac Cardiovasc Surg. Spring. 2009;21(1):12-9. Exclusion reason: Wrong topic. [pmid: 19632558].
1279 Speros CI. A system to evaluate provider performance within the Shelby County healthcare network. 2001. Exclusion reason: Methods.
1280 Spertus JA, Bonow RO, Chan P, et al. ACCF/AHA new insights into the methodology of performance measurement: a report of the American College of Cardiology Foundation/American Heart Association Task Force on performance measures. J Am Coll Cardiol. Nov. 16. 2010;56(21):1767-82. Exclusion reason: Wrong topic. [pmid: 21070935].
1281 Spoeri RK, Ullman R. Measuring and reporting managed care performance: lessons learned and new initiatives. Ann Intern Med. Oct. 15. 1997;127(8 Pt 2):726-32. Exclusion reason: Background. [pmid: 9382388].
1282 Spoerke N, Martindale R. Should the principle of “pay for performance” be applied to nutrition support?. Curr Gastroenterol Rep. Aug. 2009;11(4):332-5. Exclusion reason: Wrong topic. [pmid: 19615310].
1283 Sprague CC, Pennington JC, Greenfield J. Public information. Transplant Proc. Feb. 1988;20(1 Suppl 1):1033-40. Exclusion reason: No outcome data. [pmid: 11652535].
1284 Sprague L. Converging on nursing home quality. NHPF Issue Brief. Jan. 9. 2003;(787):1-6. Exclusion reason: Background. [pmid: 12542076].
1285 Stadt J, Molare E. Best practices: that improved patient outcomes and agency operational performance. Home Healthc Nurse. Sep. 2005;23(9):587-93. Exclusion reason: Wrong topic. [pmid: 16160555].
1286 Stafoggia M, Lallo A, Fusco D, et al. Spie charts, target plots, and radar plots for displaying comparative outcomes of health care. J Clin Epidemiol. Jul. 2011;64(7):770-8. Exclusion reason: Background. [pmid: 21227651].
1287 Stanley J, Lieb MA. (Scientific Section). A blood bank tool for managerial decision making. Transfusion. Sept. 2009;49(Supplement 3):235A. Exclusion reason: Wrong topic. [pmid: 18980619].
1288 Stausberg J, Fuchs J, Husing J, et al. Health care providers on the World Wide Web: quality of presentations of surgical departments in Germany. Med Inform Internet Med. Jan–Mar. 2001;26(1):17-24. Exclusion reason: Wrong topic. [pmid: 11583405].
1289 Steinbrook R. Public report cards--cardiac surgery and beyond. N Engl J Med. Nov. 2. 2006;355(18):1847-9. Exclusion reason: No outcome data. [pmid: 17079758].
1290 Stephenson GM, Findlay S. HEDIS: almost ready for prime time. Bus Health. Mar. 1995;13(3):39. 42. 4 passim. Exclusion reason: No outcome data. [pmid: 10164490].
1291 Stevenson DG. Nursing home consumer complaints and quality of care: a national view. Med Care Res Rev. Jun. 2006;63(3):347-68. Exclusion reason: Wrong topic. [pmid: 16651397].
1292 Stewart DW, Hickson GB, Pechmann C, et al. Information search and decision making in the selection of family health care. J Health Care Mark. Jun. 1989;9(2):29-39. Exclusion reason: Wrong topic. [pmid: 10293672].
1293 Steyerberg EW, Lingsma HF. Complexities in quality-of-care information. Med Decis Making. Sep–Oct. 2010;30(5):529-30. Exclusion reason: No outcome data. [pmid: 20959506].
1294 Stoneham L. Physician report cards. Tex Med. Sep. 1999;95(9):44-7. Exclusion reason: No outcome data. [pmid: 10518437].
1295 Stoop AP, Vrangbaek K, Berg M. Theory and practice of waiting time data as a performance indicator in health care. A case study from The Netherlands. Health Policy. Jul. 2005;73(1):41-51. Exclusion reason: Methods. [pmid: 15911055].
1296 Straube B, Blum JD. The policy on paying for treating hospital-acquired conditions: CMS officials respond. Health Aff (Millwood). Sep–Oct. 2009;28(5):1494-7. Exclusion reason: Wrong topic. [pmid: 19738268].
1297 Straube BM. Commentary. The imperatives for change in the US health care payment and delivery systems are clear. Adv Chronic Kidney Dis. Jan. 2008;15(1):7-9. Exclusion reason: Background. [pmid: 18155103].
1298 Street A. The resurrection of hospital mortality statistics in England. J Health Serv Res Policy. Apr. 2002;7(2):104-10. Exclusion reason: Background. [pmid: 11934375].
1299 Styles AK, Koprowski WR. The Disclosure of Financial Information via the Internet by the 100 “Most Wired” Healthcare Systems. Journal of public budgeting, accounting & financial management. 2008;20(3):387-404. Exclusion reason: Background.
1300 Suchy K. A lack of standardization: the basis for the ethical issues surrounding quality and performance reports. J Healthc Manag. Jul–Aug. 2010;55(4):241-51. Exclusion reason: Background. [pmid: 20812525].
1301 Summer SJ. Hospital mortality data: to review or not to review. Trustee. Sep. 1986;39(9):28-9. Exclusion reason: Wrong topic. [pmid: 10277834].
1302 Swaminathan S, Chernew M, Scanlon DP. Persistence of HMO performance measures. Health Serv Res. Dec. 2008;43(6):2033-49. Exclusion reason: Methods. [pmid: 18783460].
1303 Talaga T, Cribb R. Hospitals Resist Ranking System: Message to Ontario Patients: “Trust Us.” Critics Say It’s Time for Data to be Public. Fraser Forum. Nov. 2006:31-2. Exclusion reason: No outcome data.
1304 Tay A. Assessing competition in hospital care markets: the importance of accounting for quality differentiation. Rand J Econ. Winter. 2003;34(4):786-814. Exclusion reason: Background. [pmid: 15025031].
1305 Taylor M. Straight shooting. Texas consumers at last get look at hospital report card. Mod Healthc. Oct. 14. 2002;32(41):18. Exclusion reason: No outcome data. [pmid: 12415993].
1306 Taylor M. Hospitals compare quality. CMS’ release of quality data may change behavior. Mod Healthc. Apr. 4. 2005;35(14):4. Exclusion reason: No outcome data. [pmid: 15825944].
1307 Teleki S, Shaw RN, Mea Sprnanca. Lessons learned about designing, desseminating and using reports on health care quality. The Rand Coporation. 2007. (Unpublished Report). Exclusion reason: Unable to obtain.
1308 Terry K. Look who’s rating doctors on clinical quality--patients. Med Econ. Apr. 13. 50. 1998;75(7):3. Exclusion reason: No outcome data. [pmid: 10178249].
1309 Terry K. Now patients will rate you online. Med Econ. Apr. 24. 5. 2000;77(8):42-6. 9. Exclusion reason: No outcome data. [pmid: 10947588].
1310 Terry K. Physician report cards: help, ho-hum or horror?. Med Econ. Jul. 21. 2006;83(14):22-4. Exclusion reason: No outcome data. [pmid: 16958359].
1311 Thompson JM, Howard JE. HMO Web sites: what do they tell consumers?. Manag Care Q. Autumn. 2000;8(4):33-41. Exclusion reason: Background. [pmid: 11146842].
1312 Thompson JW, Pinidiya SD, Ryan KW, et al. Health plan quality-of-care information is undermined by voluntary reporting. Am J Prev Med. Jan. 2003;24(1):62-70. Exclusion reason: Wrong topic. [pmid: 12554025].
1313 Thompson JW, Pinidiya SD, Ryan KWea, Health Plan. Quality Data: The Importance of Public Reporting. American Journal of Preventive Medicine. Jan. 2003;24(1):62-70. Exclusion reason: No outcome data. [pmid: 12554025].
1314 Thompson MR, Tekkis PP, Stamatakis J, et al. The National Bowel Cancer Audit: the risks and benefits of moving to open reporting of clinical outcomes. Colorectal Dis. Aug. 2010;12(8):783-91. Exclusion reason: Background. [pmid: 20041920].
1315 Thomson O’Brien MA, Oxman AD, Davis DA, et al. Audit and feedback: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2000;(2):CD000259. Exclusion reason: Background. [pmid: 10796520].
1316 Thomson RG, McElroy H, Kazandjian VA. Maryland Hospital Quality Indicator Project in the United Kingdom: an approach for promoting continuous quality improvement. Qual Health Care. Mar. 1997;6(1):49-55. Exclusion reason: Wrong topic. [pmid: 10166603].
1317 Thrall TH. Defining and Meeting Consumer Expectations. Hosp Health Netw. 2008;82(7):LS-4-LS. Exclusion reason: No outcome data.
1318 Tieman J. How to kill a mandate. Hospital lobby persuades Scully, CMS to scuttle proposal that would have required hospitals to measure patient satisfaction. Mod Healthc. Jul. 7. 2003;33(27):4-5. 1. Exclusion reason: Background. [pmid: 12884717].
1319 Tieman J. Who will take charge on quality? Plethora of initiatives has providers wondering what to report and to whom. Mod Healthc. Jan. 26. 2004;34(4):30. Exclusion reason: No outcome data. [pmid: 14959558].
1320 Tjia J, Field TS, Fischer SH, et al. Quality measurement of medication monitoring in the “meaningful use” era. Am J Manag Care. Sep. 2011;17(9):633-7. Exclusion reason: Methods. [pmid: 21902449].
1321 Tokarski C. HCFA issues mortality data. Mod Healthc. Dec. 23. 1988;18(52):2. Exclusion reason: No outcome data. [pmid: 10291267].
1322 Trabin T. Accountability for quality in the real world: From 30,000 feet to ground level and back up. Integrated behavioral healthcare: Positioning mental health practice with medical/surgical practice. San Diego, CA. Academic Press; US. 2001:149-81. Exclusion reason: Wrong topic.
1323 Trigg L. Patients’ opinions of health care providers for supporting choice and quality improvement. J Health Serv Res Policy. Apr. 2011;16(2):102-7. Exclusion reason: Background. [pmid: 20870690].
1324 Trivedi AN, Gibbs B, Nsiah-Jefferson L, et al. Creating a state minority health policy report card. Health Aff (Millwood). Mar–Apr. 2005;24(2):388-96. Exclusion reason: Methods. [pmid: 15757922].
1325 Trivedi AN, Zaslavsky AM, Schneider EC, et al. Relationship between quality of care and racial disparities in Medicare health plans. JAMA. Oct. 25. 2006;296(16):1998-2004. Exclusion reason: Background. [pmid: 17062863].
1326 Tu HT, Lauer JR. Word of mouth and physician referrals still drive health care provider choice. Res Briefs. Dec. 2008;(9):1-8. Exclusion reason: Background. [pmid: 19054900].
1327 Tu HT, Lauer JR. Impact of health care price transparency on price variation: the New Hampshire experience. Issue Brief Cent Stud Health Syst Change. Nov. 2009;(128):1-4. Exclusion reason: Wrong topic. [pmid: 19908405].
1328 Tu HT, Lauer JR. Designing effective health care quality transparency initiatives. Issue Brief Cent Stud Health Syst Change. Jul. 2009;(126):1-6. Exclusion reason: Background. [pmid: 19630193].
1329 Tumlinson A, Bottigheimer H, Mahoney P, et al. Choosing a health plan: what information will consumers use?. Health Aff (Millwood). May–Jun. 1997;16(3):229-38. Exclusion reason: Wrong topic. [pmid: 9141340].
1330 Turi ZG. The big chill: the deleterious effects of public reporting on access to health care for the sickest patients. J Am Coll Cardiol. Jun. 7. 2005;45(11):1766-8. Exclusion reason: No outcome data. [pmid: 15936603].
1331 Turk A. Overview of HEDIS 2000 asthma measurement. Am J Manag Care. 2000;6(7):S342. Exclusion reason: Background.
1332 Turk A. Understanding the impact of asthma in the 21st century. J Manag Care Pharm. Sep–Oct. 2002;8(5 Suppl):3-7. Exclusion reason: Wrong topic. [pmid: 14613396].
1333 Turnbull JE, Hembree WE. Consumer information, patient satisfaction surveys, and public reports. Am J Med Qual. Spring. 1996;11(1):S42-5. Exclusion reason: Background. [pmid: 8763233].
1334 Turner PD, Pol LG. Beyond Patient Satisfaction. Journal of Health Care Marketing. Fall95. 1995;15(3):45-53. Exclusion reason: No outcome data. [pmid: 10152794].
1335 Tynan A, Liebhaber A, Ginsburg PB. A health plan work in progress hospital-physician price and quality transparency. Res Briefs. Aug. 2008;(7):1-8. Exclusion reason: No outcome data. [pmid: 18831095].
1336 Ulecia Martínez MÁ, Gómez Doblas JJ. Quality of Care in Cardiology. From Theory to Practice. Revista Espanola de Cardiología. 2007;7(Supl. C):47-54. Exclusion reason: Wrong topic.
1337 United States General Accounting O. Health care reform “report cards” are useful but significant issues need to be addressed : report to the chairman, Committee on Labor and Human Resources, US Senate Washington, DC (441 G St, NW, Rm LM, Washington, 20548). U.S. General Accounting Office. 1994. Exclusion reason: Background.
1338 United States. General Accounting O. California Nursing Homes: care problems persist despite federal and state oversight. 1998. Exclusion reason: Wrong topic.
1339 United States General Accounting O. Nursing homes : public reporting of quality indicators has merit, but national implementation is premature : report to congressional requesters. Washington, DC. United States General Accounting Office. 2002. Exclusion reason: Background.
1340 United States Government Accountability O. Health care 20 years from now: taking steps today to meet tomorrow’s challenges. Washington, D.C. United States Government Accountability Office. 2007. Exclusion reason: Background.
1341 United States Government Accountability O. Nursing homes CMS’s special focus facility methodology should better target the most poorly performing homes, which tended to be chain affiliated and for-profit : report to congressional requesters. [WashingtonD.C.]. U.S. Govt. Accountability Office. 2009. Exclusion reason: Wrong topic.
1342 Unroe KT, Greiner MA, Colon-Emeric C, et al. Associations between published quality ratings of skilled nursing facilities and outcomes of medicare beneficiaries with heart failure. J Am Med Dir Assoc. Feb. 2012;13(2):188 e1-6. Exclusion reason: Methods. [pmid: 21621479].
1343 Urbanek J. Informed and Empowered. Advisor Today. 2011;106(4):26. Exclusion reason: No outcome data.
1344 Vaiana ME, McGlynn EA. What cognitive science tells us about the design of reports for consumers. Med Care Res Rev. Mar. 2002;59(1):3-35. Exclusion reason: Background. [pmid: 11877877].
1345 Vallet G, Perrin A, Keller C, et al. Public access to information about the services and quality of care in public hospitals: the need for methodologic clarity. A survey of 44 university hospital directors and administrators. Presse Med. Mar. 2006;35(3 Pt 1):388-92. Exclusion reason: Not English. [pmid: 16550127].
1346 Van Beek K, Duchemin S, Gersh G, et al. Counseling and wellness services integrated with primary care: a delivery system that works. Perm J. Fall. 2008;12(4):20-4. Exclusion reason: PR as outcome. [pmid: 21339917].
1347 van den Berg B, Van Dommelen P, Stam P, et al. Preferences and choices for care and health insurance. Soc Sci Med. Jun. 2008;66(12):2448-59. Exclusion reason: Background. [pmid: 18400349].
1348 van der Weijden T, van Veenendaal H, Timmermans D. Shared decision-making in the Netherlands--current state and future perspectives. Z Arztl Fortbild Qualitatssich. 2007;101(4):241-6. Exclusion reason: No outcome data. [pmid: 17601179].
1349 Van Spall H. Report cards for cardiac care. JAMA. Apr. 14. 2010;303(14):1367. author reply -8. Exclusion reason: No outcome data. [pmid: 20388887].
1350 Varner T, Christy J. Consumer information needs in a competitive health care environment. Health Care Financ Rev. 1986;(Spec No):99-104. Exclusion reason: No outcome data. [pmid: 10311937].
1351 Virnig BA, Scholle SH, Chou AF, et al. Efforts to reduce racial disparities in Medicare managed care must consider the disproportionate effects of geography. Am J Manag Care. Jan. 2007;13(1):51-6. Exclusion reason: PR as outcome. [pmid: 17227203].
1352 Voelker R. HCFA focuses on new plans for quality care. Health Care Financing Administration. JAMA. Nov. 19. 1997;278(19):1559. Exclusion reason: No outcome data. [pmid: 9370482].
1353 Vonberg RP, Sander C, Gastmeier P. Consumer attitudes about health care acquired infections: a German survey on factors considered important in the choice of a hospital. Am J Med Qual. Jan–Feb. 2008;23(1):56-9. Exclusion reason: Wrong topic. [pmid: 18187591].
1354 Vrangbaek K, Ostergren K, Birk HO, et al. Patient reactions to hospital choice in Norway, Denmark, and Sweden. Health Econ Policy Law. Apr. 2007;2(Pt 2):125-52. Exclusion reason: Wrong topic. [pmid: 18634659].
1355 Wade J. NCQA checks up on HMOs. National Committee for Quality Assurance. RT: The Journal for Respiratory Care Practitioners. 1996;9(1):41-3. Exclusion reason: No outcome data.
1356 Waggoner DM. Interpreting HCFA mortality data for the public. Healthc Financ Manage. Aug. 1992;46(8):20-1. 3. Exclusion reason: No outcome data. [pmid: 10145661].
1357 Wagner JT, Meier C, Higdon T. A perspective from clinical and business ethics on adverse events in hospitalized patients. J Fla Med Assoc. Nov. 1997;84(8):502-5. Exclusion reason: Wrong topic. [pmid: 9401346].
1358 Wainstein BK, Sterling-Levis K, Baker SA, et al. Use of the Internet by parents of paediatric patients. J Paediatr Child Health. Sep. 2006;42(9):528-32. Exclusion reason: Wrong topic. [pmid: 16925539].
1359 Walker T. PPOs face more quality measures. Managed Healthcare Executive. 2007;17(9):9. Exclusion reason: No outcome data.
1360 Walton M. Public reports: Putting patients in the picture requires a new relationship between doctors and patients. Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:65-75. Exclusion reason: Background.
1361 Wang MC, Hyun JK, Harrison M, et al. Redesigning health systems for quality: Lessons from emerging practices. Jt Comm J Qual Patient Saf. Nov. 2006;32(11):599-611. Exclusion reason: Background. [pmid: 17120919].
1362 Ware JE Jr. What information do consumers want and how will they use it?. Med Care. Jan. 1995;33(1 Suppl):JS25-30. Exclusion reason: No outcome data. [pmid: 7823654].
1363 Warren E. The QOF…making exceptions. Practice Nurse. 2011;41(6):23-5. Exclusion reason: Wrong topic.
1364 Weber DO. Saddleback Memorial issues annual “Quality Report Card” to grade itself in private--and in public. Strateg Healthc Excell. May. 1997;10(5):1-6. Exclusion reason: No outcome data. [pmid: 10173001].
1365 Weber DO. A new generation of report cards is forcing health plans and providers to strive for better grades. Healthc Strateg. Jun. 1998;2(6):1-7. Exclusion reason: No outcome data. [pmid: 10346002].
1366 Website. Hospital Report Research Collaborative: public reports by year. www.hospitalreport.ca/downloads/annual.html. Exclusion reason: No outcome data.
1367 Website. Joint Commission on Accreditation of Healthcare Organizations: Qualitycheck. www.qualitycheck.org. Exclusion reason: No outcome data.
1368 Website. National Health Service: Performance Ratings 2005. 2005. http://ratings2005healthcarecommission.org.uk/home.asp. Exclusion reason: No outcome data.
1369 Webster TR, Curry L, Berg D, et al. Organizational resiliency: how top-performing hospitals respond to setbacks in improving quality of cardiac care. J Healthc Manag. May–Jun. 2008;53(3):169-81. discussion 81–2. Exclusion reason: Wrong topic. [pmid: 18546919].
1370 Wechsler J, Walker T. MCO quality was tops in 1999, according to NCQA. Managed Healthcare. 2000;10(10):12. Exclusion reason: No outcome data.
1371 Weeks WB, Fisher ES. Characteristics of VA patients who use low-quality private-sector CABG centers in New York. Med Care Res Rev. Dec. 2007;64(6):691-705. Exclusion reason: Wrong topic. [pmid: 17878291].
1372 Weidmer-Ocampo B, Johansson P, Dalpoas D, et al. Adapting CAHPS for an American Indian population. J Health Care Poor Underserved. Aug. 2009;20(3):695-712. Exclusion reason: Methods. [pmid: 19648698].
1373 Weiner BJ, Alexander JA, Shortell SM, et al. Quality improvement implementation and hospital performance on quality indicators. Health Serv Res. Apr. 2006;41(2):307-34. Exclusion reason: Wrong topic. [pmid: 16584451].
1374 Weingarten JP Jr, Fan W, Peacher-Ryan H, et al. Hospital quality improvement activities and the effects of interventions on pneumonia: a multistate study of Medicare beneficiaries. Am J Med Qual. Jul–Aug. 2004;19(4):157-65. Exclusion reason: Wrong topic. [pmid: 15368780].
1375 Weir E, d’Entremont N, Stalker S, et al. Applying the balanced scorecard to local public health performance measurement: deliberations and decisions. BMC Public Health. 2009;9:127. Exclusion reason: No outcome data. [pmid: 19426508].
1376 Weiser RR, Mansfield C. Data and information requirements for healthcare performance monitoring and improvement. N C Med J. Sep–Oct. 2004;65(5):282-4. Exclusion reason: No outcome data. [pmid: 15536789].
1377 Weiss KB, Wagner R. Performance measurement through audit, feedback, and profiling as tools for improving clinical care. Chest. Aug. 5. 2000;118(2 Suppl):3S-8S. Exclusion reason: Wrong topic. [pmid: 10940000].
1378 Weiss M. The informed patient: friend or foe?. Pharmaceutical Journal. 2007;278(7437):143. Exclusion reason: No outcome data.
1379 Weissman JS, Annas CL, Epstein AM, et al. Error reporting and disclosure systems: views from hospital leaders. JAMA. Mar. 16. 2005;293(11):1359-66. Exclusion reason: Wrong topic. [pmid: 15769969].
1380 Weller CD. The Cleveland Health Quality Choice Program. QA Rev. Oct. 1991;3(7):4-5. Exclusion reason: No outcome data. [pmid: 10115951].
1381 Wenghofer EF, Williams AP, Klass DJ. Factors affecting physician performance: implications for performance improvement and governance. Healthc Policy. Nov. 2009;5(2):e141-60. Exclusion reason: Background. [pmid: 21037818].
1382 Werner RM, Asch DA. The unintended consequences of publicly reporting quality information. JAMA. Mar. 9. 2005;293(10):1239-44. Exclusion reason: Background. [pmid: 15755946].
1383 Werner RM, Asch DA. Examining the link between publicly reporting healthcare quality and quality improvement. Informed consent and clinician accountability: The ethics of report cards on surgeon performance. New York, NY. Cambridge University Press; US. 2007:212-25. Exclusion reason: No outcome data.
1384 Werner RM, Asch DA. Clinical concerns about clinical performance measurement. Ann Fam Med. Mar–Apr. 2007;5(2):159-63. Exclusion reason: Background. [pmid: 17389541].
1385 Werner RM, Bradlow ET. Relationship between Medicare’s hospital compare performance measures and mortality rates. JAMA. Dec. 13. 2006;296(22):2694-702. Exclusion reason: Methods. [pmid: 17164455].
1386 Werner RM, Bradlow ET. “Relationship between Medicare’s hospital compare performance measures and mortality rates”: Erratum. JAMA. 2007;297(7):700. Exclusion reason: Methods.
1387 Werner RM, Bradlow ET, Asch DA. Hospital performance measures and quality of care. LDI Issue Brief. Mar–Apr. 2008;13(5):1-4. Exclusion reason: No outcome data. [pmid: 18441608].
1388 Werner RM, Konetzka RT. Advancing nursing home quality through quality improvement itself. Health Aff (Millwood). Jan–Feb. 2010;29(1):81-6. Exclusion reason: No outcome data. [pmid: 20048364].
1389 Werner RM, McNutt R. A new strategy to improve quality: rewarding actions rather than measures. JAMA. Apr. 1. 2009;301(13):1375-7. Exclusion reason: No outcome data. [pmid: 19336714].
1390 Werner RM, Polsky D, Konetzka RT. The pay-off on nursing home report cards. LDI Issue Brief. Apr. 2011;16(6):1-4. Exclusion reason: No outcome data. [pmid: 21688691].
1391 West D. ‘Unpolished’ data to support patient choice. Health Serv J. Oct. 21. 2010;120(6229):4-5. Exclusion reason: No outcome data. [pmid: 21132912].
1392 West DM, Miller EA. The digital divide in public e-health: barriers to accessibility and privacy in state health department websites. J Health Care Poor Underserved. Aug. 2006;17(3):652-67. Exclusion reason: Background. [pmid: 16960328].
1393 Whitman GR. Nursing-sensitive outcomes in cardiac surgery patients. J Cardiovasc Nurs. Sep–Oct. 2004;19(5):293-8. quiz 9–300. Exclusion reason: Background. [pmid: 15495889].
1394 Whitton AC, Green E, Evans WK, et al. The utility of publicly reported cancer treatment wait time information for patients and health care providers. Clin Oncol (R Coll Radiol). Apr. 2009;21(3):218-25. Exclusion reason: Wrong provider. [pmid: 19157813].
1395 Wholey DR, Christianson JB, Finch M, et al. Evaluating health plan quality 2: survey design principles for measuring health plan quality. Am J Manag Care. Jun. 2003;9(Spec No 2):SP65-75. Exclusion reason: Methods. [pmid: 12822716].
1396 Wholey DR, Christianson JB, Finch M, et al. Evaluating health plan quality 1: a conceptual model. Am J Manag Care. Jun. 2003;9(Spec No 2):SP53-64. Exclusion reason: Background. [pmid: 12822715].
1397 Wholey DR, Christianson JB, Jones KF, et al. What do physician recommendations of health plans mean?. Am J Manag Care. Jun. 2003;9(Spec No 2):SP88-99. Exclusion reason: Wrong topic. [pmid: 12822718].
1398 Wholey DR, Christianson JB, Sanchez SM, et al. The voluntary dissemination of performance information by health care organizations. Adv Health Econ Health Serv Res. 1992;13:1-26. Exclusion reason: Methods. [pmid: 10129440].
1399 Wicks AM, St Clair L. Competing values in healthcare: balancing the (un)balanced scorecard. J Healthc Manag. Sep–Oct. 2007;52(5):309-23. discussion 23–4. Exclusion reason: Wrong topic. [pmid: 17933187].
1400 Wicks EK, Meyer JA. Making report cards work. Health Aff (Millwood). Mar–Apr. 1999;18(2):152-5. Exclusion reason: No outcome data. [pmid: 10091443].
1401 Wiljer D, Bogomilsky S, Catton P, et al. Getting results for hematology patients through access to the electronic health record. Can Oncol Nurs J. Fall. 2006;16(3):154-64. Exclusion reason: Wrong topic. [pmid: 17523576].
1402 Williams B. Provider profiles on-line--making health care choices easier for consumers. Tenn Med. Jul. 1999;92(7):253-4. Exclusion reason: No outcome data. [pmid: 10396172].
1403 Website. Measuring Nursing Home Quality: The Five-Star Rating System. 2010. Washington State Convention and Trade Center, Washington SAS Global Forum. Exclusion reason: Methods.
1404 Wills CE, Holmes-Rovner M. Patient comprehension of information for shared treatment decision making: state of the art and future directions. Patient Educ Couns. Jul. 2003;50(3):285-90. Exclusion reason: Wrong topic. [pmid: 12900101].
1405 Wilson CT, Woloshin S, Schwartz LM. Choosing where to have major surgery: who makes the decision?. Arch Surg. Mar. 2007;142(3):242-6. Exclusion reason: Background. [pmid: 17372048].
1406 Wilson E. Getting the FAccts (Foundation for Accountability) straight. Health Syst Rev. Nov–Dec. 1995;28(6):12-4. 8. Exclusion reason: No outcome data. [pmid: 10153028].
1407 Wilson EV, Lankton NK. Modeling patients’ acceptance of provider-delivered e-health. J Am Med Inform Assoc. Jul–Aug. 2004;11(4):241-8. Exclusion reason: Background. [pmid: 15064290].
1408 Winkler JD, Lohr KN, Brook RH. Persuasive communication and medical technology assessment. Arch Intern Med. Feb. 1985;145(2):314-7. Exclusion reason: No outcome data. [pmid: 3977492].
1409 Wong CY, Wu E, Wong TY. Examining the effect of publishing of bill sizes to reduce information asymmetry on healthcare costs. Singapore Med J. Jan. 2007;48(1):16-24. Exclusion reason: Wrong topic. [pmid: 17245511].
1410 Wong HS. Market structure and the role of consumer information in the physician services industry: an empirical test. J Health Econ. Apr. 1996;15(2):139-60. Exclusion reason: Wrong topic. [pmid: 10159107].
1411 Woods P. Shopping for quality: the Greater Cleveland Health Quality Choice Project. Nurs Econ. Sep–Oct. 1990;8(5):319-21. 32. Exclusion reason: Background. [pmid: 2234138].
1412 Woolf NH, Burns ME, Bosworth TW, et al. Purchasing health insurance coverage for smoking cessation treatment: employers describe the most influential information in this decision. Nicotine Tob Res. Dec. 2006;8(6):717-25. Exclusion reason: Wrong topic. [pmid: 17132519].
1413 Wouters MW, Gooiker GA, van Sandick JW, et al. The volume-outcome relation in the surgical treatment of esophageal cancer: A systematic review and meta-analysis. Cancer. 2011. Aug. 25. Exclusion reason: Wrong topic. [pmid: 22009562].
1414 Wright J, Fiocchi F, Kehoe K, et al. Building quality improvement from the ground up: Lessons from the design and implementation of the IC3 program national practice-based quality improvement program. (Abstracts From the World Congress of Cardiology Scientific Sessions). Circulation. July. 13. 2010;122(2):e84. Exclusion reason: Wrong topic.
1415 Xian Y, Pan W, Peterson ED, et al. Are quality improvements associated with the Get With the Guidelines-Coronary Artery Disease (GWTG-CAD) program sustained over time? A longitudinal comparison of GWTG-CAD hospitals versus non-GWTG-CAD hospitals. Am Heart J. Feb. 2010;159(2):207-14. Exclusion reason: PR as outcome. [pmid: 20152218].
1416 Xie B, Youash S. The effects of publishing emergency department wait time on patient utilization patterns in a community with two emergency department sites: a retrospective, quasi-experiment design. Int J Emerg Med. 2011;4(1):29. Exclusion reason: Wrong topic. [pmid: 21672236].
1417 Xuewei H, Xiuli W, Ying Z. Information Needs of Cancer Patients: (3) A Comparison of Views between Cancer Patients, Their Relatives, Doctors and Nurses. Chinese Mental Health Journal. Nov. 2003;17(11):757-73. Exclusion reason: Wrong topic.
1418 Yi JS. Visualized decision making: development and applications of information visualization techniques to improve decision quality of nursing home choice: Georgia Institute of Technology. 2008. Exclusion reason: Background.
1419 Young DW, Barrett D, Kenagy JW, et al. Value-based partnering in healthcare: a framework for analysis. J Healthc Manag. Mar–Apr. 2001;46(2):112-32. discussion 33. Exclusion reason: Background. [pmid: 11277013].
1420 Zablocki E. Are you providing the information purchasers and consumers need to make informed decisions?. Qual Lett Healthc Lead. Feb. 1995;7(1):2-14. Exclusion reason: No outcome data. [pmid: 10151588].
1421 Zablocki E. Measuring up. With the release of HEDIS 3.0, health plans are working to improve how they measure quality. Healthplan. May–Jun. 1997;38(3):76-83. Exclusion reason: No outcome data. [pmid: 10176867].
1422 Zablocki E. Informed choices. Healthplan. Jan–Feb. 1997;38(1):52-3. 5. 6. 8. Exclusion reason: No outcome data. [pmid: 10165668].
1423 Zablocki E. State-issued report cards. Healthplan. Mar–Apr. 1998;39(2):48-52. Exclusion reason: No outcome data. [pmid: 10181741].
1424 Zaslavsky AM, Beaulieu ND, Landon BE, et al. Dimensions of consumer-assessed quality of Medicare managed-care health plans. Med Care. Feb. 2000;38(2):162-74. Exclusion reason: Methods. [pmid: 10659690].
1425 Zaslavsky AM, Landon BE, Beaulieu ND, et al. How consumer assessments of managed care vary within and among markets. Inquiry. Summer. 2000;37(2):146-61. Exclusion reason: Methods. [pmid: 10985109].
1426 Zaslavsky AM, Shaul JA, Zaborski LB, et al. Combining health plan performance indicators into simpler composite measures. Health Care Financ Rev. Summer. 2002;23(4):101-15. Exclusion reason: Background. [pmid: 12500473].
1427 Zhao M, Haley DR. Nursing home quality, staffing, and malpractice paid-losses. J Health Care Finance. Fall. 2011;38(1):1-10. Exclusion reason: Wrong topic. [pmid: 22043643].
1428 Zhou X. Information in healthcare: An ethnographic analysis of a hospital ward: Zhou, Xiaomu: U Michigan, US. 2011. Exclusion reason: Wrong topic.
1429 Zikmund-Fisher BJ, Fagerlin A, Ubel PA. “Is 28% good or bad?” Evaluability and preference reversals in health care decisions. Med Decis Making. Mar–Apr. 2004;24(2):142-8. Exclusion reason: Background. [pmid: 15090100].
1430 Zima BT, Mangione-Smith R. Gaps in quality measures for child mental health care: an opportunity for a collaborative agenda. J Am Acad Child Adolesc Psychiatry. Aug. 2011;50(8):735-7. Exclusion reason: No outcome data. [pmid: 21784290].
1431 Zimmerman C. Public gives hospitals scores in customer satisfaction. NAHAM Access Manag J. 2001;27(2):17. Exclusion reason: No outcome data. [pmid: 11577382].
1432 Zoccali C. Medical knowledge, quality of life and accreditation of quality in health care. The perspective of the clinical nephrologist. Int J Artif Organs. Nov. 1998;21(11):717-20. Exclusion reason: Wrong topic. [pmid: 9894748].
1433 Zoler ML. Consumers get hospital scores. Med World News. Aug. 14. 1989;30(15):62-3. Exclusion reason: No outcome data. [pmid: 10294473].
1434 Zuvekas A, Hur R, Richmond D, et al. Applying HEDIS clinical measures to community health centers: a feasibility study. J Ambul Care Manage. Oct. 1999;22(4):53-62. Exclusion reason: PR as outcome. [pmid: 11184889].