# Inclusion and Exclusion Criteria

Abstract and Title Triage

Full Text Review