# Literature Search Databases and Strings

## List of Electronic Databases for Searches

Name | Platform Provider
Primary Search
Medline | OvidSP
Current Index to Nursing and Allied Health Literature (CINAHL) | EBSCO
PsycINFO | OvidSP
Embase | Embase
Econlit | EBSCO
EBM Reviews: Cochrane Database of Systematic Reviews (CDSR) Database of Abstracts of Reviews of Effects (DARE) National Health Service Economic Evaluation Database (NHS EED) Health Economic Evaluations Database (HEED) | OvidSP
Business Source Premier | EBSCO
Public Affairs Information Service (PAIS) | ProQuest CSA
EPOC Register of Studies | Cochrane Effective Practice and Organisation of Care Group
Pearling/Citation search of identified studies
SCOPUS | SciVerse
Grey Literature
NYAM Grey Literature Database | New York Academy of Medicine Library
Conference Papers | ProQuest CSA
AARP Ageline | OvidSP

## Specific Searches

Medline/CINAHL Search

Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1947 to May Week 2 2011 and Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations May 18, 2011

Date Searched: 05/18/2011; updated search through 12/31/2011 conducted on 1/12/2012

1 | Benchmarking/ or Information Services/ or Information Dissemination/ or Disclosure/ or Access to Information/ or Mandatory Reporting/
2 | Quality indicators, health care/ or Quality assurance, health care/ or Quality improvement/ or “process assessment (health care)”/ or “outcome assessment (health care)”/ or (quality adj2 indicator$).ti,ab.
3 | 1 or 2
4 | exp Hospitals/ or exp Physicians/ or Nursing Homes/ or Home Care Services/ or Competitive Medical Plans/ or Health Maintenance Organizations/ or Managed Care Programs/ or Insurance, Health/ or Medicare/ or Medicaid/ or Hospices/ or Ambulatory Care/ or Skilled Nursing Facilities/ or Group Practice/ or exp Primary Health Care/ or Institutional Practice/ or Private Practice/ or Family Practice/ or Physicians, Family/ or Professional Practice/ or Allied Health Personnel/ or Outpatient clinics, hospital/ or Academic Medical Center/ or Health Care Sector/ or Hospital Administration/ or Public Health Administration/ or Long Term Care Facilit$.ti,ab. or health care cent$3.ti,ab. or health care provider$.ti,ab. or (coronary or cardiac or cardiolog$).ti,ab.
5 | (((Dissem$ or Disclos$ or Profil$ or Inform$ or Indicator$ or Metric$ or Rank$ or Compar$ or Score$ or Rating$ or Rate$ or data or measure$ or criteria or standard$ or account$ or report$ or release$ or initiative$ or Star) adj5 (Performan$ or assessment$ or evaluat$ or quality or public$ or consumer$ or patient$ or transparen$ or provider$)) or score card$ or (quality adj2 report$) or report card$ or league table$ or (star adj2 rating) or (Star adj2 performance)).ti,ab.
6 | Consumer Participation/ or Consumer Advocacy/ or Consumer Satisfaction/ or Patient Satisfaction/ or Decision Making/ or Choice Behavior/ or Attitude of Health Personnel/ or Physician’s Practice Patterns/ or Nurse’s Practice Patterns/ or Professional Practice/ or Guideline Adherence/ or Patient Selection/ or Patient Participation/ or Hospital Mortality/ or (decision$ or choice$ or choos$ or behav$ or patient outcome$).ti,ab.
7 | (Medicare Compare or nursing home compare or Calhospital Compare or California State Report Card or California Hospital Outcomes or myhealthcareadvisor or Massachusetts Health Quality or (Pennsylvania adj3 coronary) or (Hospital Quality adj2 Safety Survey) or Home health Compare or Physician Compare or (New York adj2 Cardiac adj2 Report$) or (New York adj5 surg$) or Cleveland Health Quality Choice or (HCFA adj5 mortality) or (HCFA adj5 death) or Federal employee health benefit guide or QualityCounts or CAHPS or HEDIS).ti,ab.
8 | 3 and 4 and 5 and 6
9 | 7 or 8
10 | limit 9 to yr=“1980 -Current”
11 | remove duplicates from 10
12 | limit 11 to (comment or editorial or letter)
13 | 11 not 12

Ovid PsycINFO 1806 to May Week 1 2011

Date Searched: 05/10/2011; updated search through 12/31/2011 conducted on 1/12/2012

1 | information/
2 | “quality of services”/ or quality of care/ or quality control/ or (quality adj2 indicator$).ti,ab.
3 | 1 or 2
4 | Consumer attitudes/ or Client attitudes/ or Patients/ or Consumer Behavior/ or job performance/ or consumer satisfaction/ or (decision$ or choice$ or choos$ or behav$ or patient outcome$).ti,ab.
5 | exp Hospitals/ or exp Physicians/ or Nursing Homes/ or exp allied health personnel/ or clinicians/ or outpatient treatment/ or home visiting programs/ or Health Maintenance Organizations/ or Managed Care/ or Medicare/ or Medicaid/ or health insurance/ or Palliative Care/ or private practice/ or health care delivery/ or health care services/ or facilities/ or primary health care/ or public health services/ or long term care/ or Long Term Care Facilit$.ti,ab. or health care cent$3.ti,ab. or health care provider$.ti,ab. or (coronary or cardiac or cardiolog$).ti,ab.
6 | (((Dissem$ or Disclos$ or Profil$ or Inform$ or Indicator$ or Metric$ or Rank$ or Compar$ or Score$ or Rating$ or Rate$ or data or measure$ or criteria or standard$ or account$ or report$ or release$ or initiative$ or Star) adj5 (Performan$ or assessment$ or evaluat$ or quality or public$ or consumer$ or patient$ or transparen$ or provider$)) or score card$ or (quality adj2 report$) or report card$ or league table$ or (star adj2 rating) or (Star adj2 performance)).ti,ab.
7 | (Medicare Compare or nursing home compare or Calhospital Compare or California State Report Card or California Hospital Outcomes or myhealthcareadvisor or Massachusetts Health Quality or (Pennsylvania adj3 coronary) or (Hospital Quality adj2 Safety Survey) or Home health Compare or Physician Compare or (New York adj2 Cardiac adj2 Report$) or (New York adj5 surg$) or Cleveland Health Quality Choice or (HCFA adj5 mortality) or (HCFA adj5 death) or Federal employee health benefit guide or QualityCounts or CAHPS or HEDIS).ti,ab.
8 | 3 and 4 and 5 and 6
9 | 7 or 8
10 | limit 9 to yr=“1980 -Current”

CINAHL EBSCO Plus with Full Text

Date Searched: 05/18/2011; updated search through 12/31/2011 conducted on 1/12/2012

S51 | S49 NOT S50
S50 | S42 or S48 Limiters – Publication Type: Commentary, Editorial, Letter; Exclude MEDLINE records; Published Date from: 9800101-20111231
S49 | S42 or S48 Limiters – Exclude MEDLINE records; Published Date from: 19800101-20111231
S48 | S43 and S44 and S46 and S47
S47 | S32 or S33 or S34 or S35 or S36 or S37 or S38 or S39 or S40 or S41
S46 | S26 or S27 or S28 or S29 or S30 or S31 or S45
S45 | S24 and S25
S44 | S5 or S6 or S7 or S8 or S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23
S43 | S1 or S2 or S3 or S4
S42 | AB (“Medicare Compare” or “nursing home compare” or “Calhospital compare” or “California State Report Card” or “California Hospital Outcomes” or myhealthcareadvisor or “Massachusetts Health Quality” or (Pennsylvania n3 coronary) or (“hospital quality” n2 “safety survey”) or “home health compare” or “physician compare” or (“New York” n2 cardiac n2 report*) or (“New York” n5 surg*) or “Cleveland Health Quality Choice” or (HCFA n5 mortality) or (HCFA n5 death) or “Federal Employee Health Benefit Guide” or QualityCounts or CAHPS or HEDIS)AB (“Medicare Compare” or “nursing home compare” or “Calhospital compare” or “California State Report Card” or “California Hospital Outcomes” or myhealthcareadvisor or “Massachusetts Health Quality” or (Pennsylvania n3 coronary) or (“hospital quality” n2 “safety survey”) or “home health compare” or “physician compare” or (“New York” n2 cardiac n2 report*) or (“New York” n5 surg*) or “Cleveland Health Quality Choice” or (HCFA n5 mortality) or (HCFA n5 death) or “Federal Employee Health Benefit Guide” or QualityCounts or CAHPS or HEDIS)
S41 | (MH “Decision Making+”)
S40 | (MH “consumer satisfaction”)
S39 | (MH “consumer advocacy”)
S38 | (MH “consumer participation”)
S37 | (MH “Hospital Mortality”)
S36 | (MH “Patient Selection”)
S35 | (MH “Guideline Adherence”)
S34 | (MH “Professional Practice+”)
S33 | (MH “Attitude of Health Personnel”)
S32 | (MH “Patient Satisfaction”)
S31 | AB star w2 performance
S30 | AB star n2 rating*
S29 | AB league w1 table*
S28 | AB report w1 card*
S27 | AB quality n2 report*
S26 | AB score w1 card*
S25 | AB (performan* or assessment* or evaluat* or quality or public* or consumer* or patient* or transparen* or provider*)
S24 | AB (dissemin* or disclos* or profil* or inform* or indicator* or metric* or rank* or compar* or score* or rating* or data or measure* or criteria or standard* or account* or report* or release* or initiative* or star)
S23 | AB (“health care cent*” or “Health care provider?” or coronary or cardiac or cardiologist?)
S22 | (MH “Public Health Administration”)
S21 | (MH “Health Facility Administration”)
S20 | (MH “Health Care Industry”)
S19 | (MH “Professional Practice”)
S18 | (MH “Family Practice”)
S17 | (MH “Private Practice”)
S16 | (MH “Primary Health Care”)
S15 | (MH “Group Practice”) OR (MH “Joint Practice”)
S14 | (MH “Hospices”) OR (MH “Hospice Care”)
S13 | (MH “Medicaid”)
S12 | (MH “Medicare”)
S11 | (MH “Health Maintenance Organizations”)
S10 | (MH “Insurance, Health+”) OR (MH “Managed Care Programs+”)
S9 | (MH “Home Health Care+”) OR (MH “Home Nursing, Professional”)
S8 | (MH “Nursing Homes+”) OR (MH “Skilled Nursing Facilities”)
S7 | (MH “Physicians+”) OR (MH “Allied Health Personnel+”)
S6 | (MH “Long Term Care”) OR “long term care facilit*”
S5 | (MH “Hospitals+”) OR (MH “Ambulatory Care Facilities+”) OR (MH “Academic Medical Centers”) OR (MH “Hospitals, Public+”) OR (MH “Hospitals, Rural”) OR (MH “Hospitals, Special+”) OR (MH “Hospitals, Urban”) OR (MH “Magnet Hospitals”) OR (MH “Housing for the Elderly”) OR (MH “Ancillary Services, Hospital”) OR (MH “Hospitals, Community”)
S4 | (MH “Truth Disclosure”) or (MH “Access to Information”) or (MH “Mandatory Reporting”)
S3 | AB quality n2 indicator*
S2 | (MH “Quality Assurance”) OR (MH “Clinical Indicators”) OR (MH “Performance Measurement Systems”) OR (MH “Health Plan Employer Data and Information Set”) OR (MH “Outcome Assessment Information Set”) OR (MH “Nursing Audit”) OR (MH “Quality of Care Research”)
S1 | (MH “Benchmarking”) OR (MH “Quality Improvement”) OR (MH “Quality of Health Care”) OR (MH “Performance Measurement Systems”) OR (MH “Quality Assessment”)

EMBASE - Elsevier (1973-present)

Date searched: 06/29/2011; updated search through 12/31/2011 conducted on 1/12/2012

9 | #7 NOT #8
8 | #5 OR #6 AND (‘editorial’/it OR ‘letter’/it)
7 | #5 OR #6
6 | #1 AND #2 AND #3 AND #4
5 | ‘medicare compare’:ab,ti OR ‘nursing home compare’:ab,ti OR ‘calhospital compare’:ab,ti OR ‘california state report card’:ab,ti OR ‘california hospital outcomes’:ab,ti OR myhealthcareadvisor:ab,ti OR ‘massachusetts health quality’:ab,ti OR (pennsylvania NEAR/3 coronary):ab,ti OR (‘hospital quality’ NEAR/2 ‘safety survey’):ab,ti OR ‘home health compare’:ab,ti OR ‘physician compare’:ab,ti OR (‘new york’ NEAR/2 cardiac):ab,ti OR (‘new york’ NEAR/5 surg*):ab,ti OR ‘cleveland health quality choice’:ab,ti OR (hcfa NEAR/5 mortality):ab,ti OR (hcfa NEAR/5 death):ab,ti OR ‘federal employees health benefit guide’:ab,ti OR qualitycounts:ab,ti OR cahps:ab,ti OR hedis:ab,ti AND [embase]/lim AND [2006–2011]/py
4 | ‘hospital’/exp OR ‘physician’/exp OR ‘hospice’/de OR ‘hospital management’/exp OR ‘public health service’/de OR ‘health care facility’/de OR ‘nursing home’/de OR ‘home care’/de OR ‘health insurance’/de OR ‘health maintenance organization’/de OR ‘medicare’/de OR ‘medicaid’/de OR ‘ambulatory care’/de OR ‘group practice’/de OR ‘primary health care’/de OR ‘private practice’/de OR ‘general practice’/de OR ‘paramedical personnel’/de OR ‘outpatient department’/de OR ‘university hospital’/de OR (‘long term care facilities’:ab,ti OR ‘health care center’:ab,ti AND ‘health care centers’:ab,ti OR ‘health care centre’:ab,ti OR ‘health care centres’:ab,ti OR ‘health care provider’:ab,ti AND ‘health care providers’:ab,ti) OR coronary:ab,ti OR cardiac:ab,ti OR cardiologist:ab,ti OR cardiologists:ab,ti AND [embase]/lim AND [2006–2011]/py
3 | ‘consumer advocacy’/de OR ‘consumer attitude’/de OR ‘decision making’/de OR ‘patient decision making’/de OR ‘patient attitude’/de OR ‘health personnel attitudes’ OR ‘physician attitudes’ OR ‘nurse attitudes’ OR ‘clinical practice’/de OR ‘professional practice’/de OR ‘practice guideline’/de OR ‘patient selection’/de OR ‘patient participation’/de OR ‘mortality’/de OR decision*:ab,ti OR decide*:ab,ti OR choice*:ab,ti OR choos*:ab,ti OR behav*:ab,ti AND [embase]/lim AND [2006–2011]/py
2 | ((disseminat* OR disclos* OR profil* OR inform* OR indicator* OR metric* OR rank* OR compar* OR score* OR rating* OR rate* OR data OR measure* OR criteria OR standard* OR account* OR report* OR releas* OR initiative* OR star) NEAR/5 (perform* OR assessment* OR evaluat* OR quality OR public* OR consumer* OR patient* OR transparen* OR provider*)):ab,ti OR ‘score card’:ab,ti OR ‘score cards’:ab,ti OR (quality NEAR/2 report*):ab,ti OR ‘report card’:ab,ti OR ‘report cards’:ab,ti OR ‘league table’:ab,ti OR ‘league tables’:ab,ti OR (star NEAR/2 rating):ab,ti OR (star NEAR/2 performance):ab,ti AND [embase]/lim AND [2006–2011]/py
1 | ‘information service’/de OR ‘information dissemination’/de OR ‘mandatory reporting’/de OR ‘access to information’/de OR ‘performance measurement system’/de OR ‘quality of nursing care’/de OR ‘health care quality’/de OR ‘quality control’/de OR ‘health services research’/de AND [embase]/lim AND [2006–2011]/py

EBSCO Econlit (1969-present)

Date Searched: 05/25/2011; updated search through 12/31/2011 conducted on 1/13/2012

S7 | s1 or s6
S6 | S2 and S3 and S4 and S5
S5 | (AB (benchmark* or disclos* or rank* or compar* or score* or rating* or rate* or standard* or account* or report*)) and (AB (perform* or assessment* or evaluat* or quality* or public* or transparen*)) or (AB (score n1 card* or quality w2 report* or report n1 card* or league n1 table* or star w2 rating or star w1 perfomance))
S4 | AB (decision* or decid* or attitud* or choice* or choos* or behav* or effect* or incentiv* or select*)
S3 | (AB (consumer* or patient* or doctor* or physician* or surgeon* or nurse* or nursing w1 home* or hospice* or long w1 term w1 care w1 facilit* or medicare or medicaid or allied w1 health or provider* or insurance or HMO or health w1 maintenance w1 organization* or hospital* or group w1 practice* or private w1 practice* or public w1 health))
S2 | SU “Health: Government Policy; Regulation; Public Health” or SU “analysis of health care markets “
S1 | AB medicare n1 compare or nursing w1 home w1 compare or Calhospital w1 compare or California w1 State w1 Report w1 Card or myhealthcareadvisor or California w1 Hospital w1 Outcomes or Massachusetts w1 Health w1 Quality or Pennsylvania n3 coronary or Hospital w1 Quality n2 Safety Home w1 Health w1 Compare or Physician w1 Compare or New w1 York n2 Cardiac w2 Report* or New w1 York n5 surg* or Cleveland w1 Health w1 QualityHCFA n5 mortality or HCFA n5 death or Federal w1 Employee w1 Health w1 Benefit w1 Guide or QualityCounts or CAHPS or HEDIS

EBSCO BUSINESS SOURCE PREMIER

Date Searched: 05/25/2011; updated search through 12/31/2011 conducted on 1/13/2012

S12 | s1 or s10
S11 | s1 or s10
S10 | S4 and S5 and S6 and S9
S9 | S7 or S8
S8 | AB (dissem* or disclos* or profil* or inform* or indicator* or metric* or rank* or compar* or score* or rating* or rate* or data or measure* or criteria or standard* or account* or report* or releas* or initiative* or star) and AB (performan* or assessment* or evaluat* or quality or public* or consumer* or patient* or transparen* or provider*)
S7 | AB “public report*” or “score card*” or scorecard* or (quality n2 report*) or “quality n2 measur*” or “report card*” or “league table*” or (star n2 rating) or (star n2 performance)
S6 | SU “patient education” or “patients” or “patient satisfaction” or “patient selection” or “decision making” or “consumer attitudes” or “consumer satisfaction” or “consumers’ preferences” or “consumer behavior” or “consumer activism” or “organizational behavior” or “information behavior”
S5 | DE “HOSPITALS” OR DE “CANCER hospitals” OR DE “CHRONIC disease hospitals” OR DE “MEDICAL hospitals” OR DE “NEUROLOGY hospitals” OR DE “SURGICAL hospitals” or DE “medical care” or DE “health services administration” or DE surgeons or DE “Insurance companies” or DE “nursing care facilities” or DE medicare or DE medicaid or DE physicians or DE “health care industry” or DE “health insurance” or DE “long-term care facilities” or DE “nursing homes” or DE “hospitals-administration” or DE nurses or DE “nursing care facilities” or DE “nursing home chains” or DE “health maintenance organizations” or DE “managed care plans” or DE “group medical practice” or DE “allied health practitioners”
S4 | S2 or S3
S3 | SU benchmarking or SU key performance indicators orSU evaluation or SU quality control or SU quality standards or SU quality assurance or SU standards or AB quality n2 indicat*
S2 | SU disclosure of information or SU disclosure or SU access to information or SU report writing or SU databases
S1 | AB “medicare compare” or “nursing home compare” or “calhospital compare” or “california state report card” or “california hospital outcomes” or myhealthcareadvisor or “massachusetts health quality” or (pennsylvania n3 coronary) or (“hospital quality” n2 “safety survey”) or “home health care compare” or “physician compare” or (“new york” n2 cardiac n2 report*) or (“New York” n5 surg*) or “Cleveland Health Quality Choice” or “health care finance administration” or “Federal Employees Health Benefit Guide” or QualityCounts or CAHPS or HEDIS

Public Affairs Information Service International (PAIS)

ProQuest CSA

Searched 5/25/2011; updated search through 12/31/2011 conducted on 1/13/2012

(AB=((Medicare Compare) or (Nursing Home Compare) or (Calhospital Compare)) or AB=((California State Report Card) or (California Hospital Outcomes) or myhealthcareadvisor) or AB=((Massachusetts Health Quality) or (Pennsylvania within 3 coronary) or (hospital quality within 2 safety survey)) or AB=((home health compare) or (physician compare) or (new york within 2 cardiac within 2 report*)) or AB=((New York within 5 surg*) or (Cleveland Health Quality Choice) or HCFA) or AB=(QualityCounts or (Federal Employee Health Benefit Guide) or HEDIS) or AB=CAHPS) or(((DE=(medical service or physicians or nurses or surgeons or medical workers or medical profession: group practice or hospitals or nursing homes or home care or hospices (terminal care) or outpatient services or medical centers or public health or public health administration or medicare or medicaid program or health insurance or managed care or health maintenance organizations))
and(DE=(quality control or performance or measurement or standards)))
and((AB=((dissem* or disclos* or profil* or inform* or indicator* or metric* or rank* or compar* or score* or rating* or rate* or data or measure* or criteria or standard* or account* or report* or release* or initiative* or star) within 10 (perform* or assessment* or evaluat* or quality or public* or consumer* or patient* or transparen* or provider*))) or(AB=(score card* or scorecard* or (quality within 2 report*) or report card* or league table* or (star within 2 rating) or (star within 2 performance)))))

Search strategies for the grey literature databases comprised keyword/phrase searching (e.g., public report*, Medicare compare, etc) primarily, due to the unavailability of relevant subject searching capability in most of the databases. The NYAM Grey Literature database search was comprised of keyword/phrase searching ‘ANDed’ together with their subject term ‘quality of health care.’

AARP Ageline (OvidSP)

Searched 07/22/2011; updated search through 12/31/2011 conducted on 1/13/2012

1 | report card$.ti,ab. | 40
2 | ((Performan$ or assessment$ or evaluat$ or public$ or consumer$ or patient$ or transparen$ or provider$) adj5 (quality adj2 report$)).ti,ab. | 77
3 | (Medicare Compare or nursing home compare or Calhospital Compare or California State Report Card or California Hospital Outcomes or myhealthcareadvisor or Massachusetts Health Quality or (Pennsylvania adj3 coronary) or (Hospital Quality adj2 Safety Survey) or Home health Compare or Physician Compare or (New York adj2 Cardiac adj2 Report$) or (New York adj5 surg$) or Cleveland Health Quality Choice or (HCFA adj5 mortality) or (HCFA adj5 death) or Federal employee health benefit guide or QualityCounts or CAHPS or HEDIS).ti,ab. | 107
4 | 1 or 2 or 3 | 206