# Acknowledgments

We would like to acknowledge the guidance provided by our Technical Expert Panel and consultants. Several people at the Oregon Evidence-based Practice Center assisted us at various stages with this report. They are: Elaine Graham, M.L.S; Robyn Paynter, M.L.S.; Leah Williams, B.S.; Basmah Rahman, M.P.H.; Pau Motu’apuaka, B.S; Ngoc Wasson, M.P.H; Andrew Hamilton, M.L.S., M.S.; and Gabriel Valles. We were also assisted by two consultants, Judith Hibbard, Dr.P.H., and Ellen Peters, Ph.D., who shared their expertise with us. We would also like to thank Mary Nix, M.S., M.T. (A.S.C.P.) S.B.B., and Peggy McNamara, M.S.P.H., at AHRQ and the lead investigator for the Closing the Quality Gap series, Kathryn McDonald, M.M., as well as the other investigators and AHRQ staff associated with the Closing the Quality Gap series for their guidance.